# Appendix C Excluded Studies With Reasons

Aberg-Wistedt A, Cressell T, Lidberg Y, . Two-year outcome of team-based intensive case management for patients with schizophrenia. Psychiatr Serv. 1995 Dec;46(12):1263–6. PMID: 8590112. Study covered in a systematic review.8590112
Abraham KR, Kulhara P. The efficacy of electroconvulsive therapy in the treatment of schizophrenia. A comparative study. Br J Psychiatry. 1987 Aug;151:152–5. PMID: 3318990. Intervention not included in review.3318990
Addington DE, McKenzie E, Norman R, . Essential evidence-based components of first-episode psychosis services. Psychiatr Serv. 2013 May 1;64(5):452–7. doi: 10.1176/appi.ps.201200156. PMID: 23370444. Systematic review/meta-analysis used as a source document to identify individual studies.23370444
Addington DE, Mohamed S, Rosenheck RA, . Impact of second-generation antipsychotics and perphenazine on depressive symptoms in a randomized trial of treatment for chronic schizophrenia. J Clin Psychiatry. 2011 Jan;72(1):75–80. doi: 10.4088/JCP.09m05258gre. PMID: 20868641. Outcome not included in review.20868641
Addington J, McCleery A, Collins A, . Family work in early psychosis. J Fam Psychother. 2006;17(3–4):137–53. doi: 10.1300/J085v17n03_09. Study design not included in review.
Agid O, Schulze L, Arenovich T, . Antipsychotic response in first-episode schizophrenia: efficacy of high doses and switching. Eur Neuropsychopharmacol. 2013;23(9):1017–22. PMID: 23706529. Study design not included in review.23706529
Agius M, Shah S, Ramkisson R, . Three year outcomes of an early intervention for psychosis service as compared with treatment as usual for first psychotic episodes in a standard community mental health team. Preliminary results. Psychiatr Danub. 2007 Jun;19(1–2):10–9. PMID: 17603411. Study design not included in review.17603411
Aguglia E, Pascolo-Fabrici E, Bertossi F, . Psychoeducational intervention and prevention of relapse among schizophrenic disorders in the Italian community psychiatric network. Clin Pract Epidemiol Ment Health. 2007;3:7. doi: 10.1186/1745-0179-3-7. PMID: 17593299. Not a study.17593299
Ahmed AO, Hunter KM, Goodrum NM, . A randomized study of cognitive remediation for forensic and mental health patients with schizophrenia. J Psychiatr Res. 2015 Sep;68:8–18. doi: 10.1016/j.jpsychires.2015.05.013. PMID: 26228394. Setting ineligible for review (i.e., inpatient only).26228394
Aho-Mustonen K, Tiihonen J, Repo-Tiihonen E, . Group psychoeducation for long-term offender patients with schizophrenia: an exploratory randomised controlled trial. Crim Behav Ment Health. 2011 Jul;21(3):163–76. doi: 10.1002/cbm.788. PMID: 20859932. Population ineligible for review.20859932
Almerie MQ, Okba Al Marhi M, Jawoosh M, . Social skills programmes for schizophrenia. Cochrane Database Syst Rev. 2015 Jun 09(6):Cd009006. doi: 10.1002/14651858.CD009006.pub2. PMID: 26059249. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.26059249
Alphs L, Benson C, Cheshire-Kinney K, . Real-world outcomes of paliperidone palmitate compared to daily oral antipsychotic therapy in schizophrenia: a randomized, open-label, review board-blinded 15-month study. J Clin Psychiatry. 2015 May;76(5):554–61. doi: 10.4088/JCP.14m09584. PMID: 25938474. Intervention not included in review.25938474
Alphs L, Bossie CA, Fu DJ, . Onset and persistence of efficacy by symptom domain with long-acting injectable paliperidone palmitate in patients with schizophrenia. Expert Opin Pharmacother. 2014 May;15(7):1029–42. doi: 10.1517/14656566.2014.909409. PMID: 24754314. Study design not included in review.24754314
Alphs L, Bossie CA, Sliwa JK, . Paliperidone palmitate and risperidone long-acting injectable in subjects with schizophrenia recently treated with oral risperidone or other oral antipsychotics. Neuropsychiatr Dis Treat. 2013 Mar;9:341–50. PMID: 23493643. Not a study.23493643
Alphs L, Mao L, Rodriguez SC, . Design and rationale of the Paliperidone Palmitate Research in Demonstrating Effectiveness (PRIDE) study: a novel comparative trial of once-monthly paliperidone palmitate versus daily oral antipsychotic treatment for delaying time to treatment failure in persons with schizophrenia. J Clin Psychiatry. 2014 Dec;75(12):1388–93. PMID: 25375367. Not a study.25375367
Anaya C, Martinez Aran A, Ayuso-Mateos JL, . A systematic review of cognitive remediation for schizo-affective and affective disorders. J Affect Disord. 2012 Dec;142(1–3):13–21. doi: 10.1016/j.jad.2012.04.020. PMID: 22840620. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.22840620
Andres K, Pfammatter M, Fries A, . The significance of coping as a therapeutic variable for the outcome of psychological therapy in schizophrenia. Eur Psychiatry. 2003 Jun;18(4):149–54. PMID: 12814846. Intervention not included in review.12814846
Andres K, Pfammatter M, Garst F, . Effects of a coping-orientated group therapy for schizophrenia and schizoaffective patients: a pilot study. Acta Psychiatr Scand. 2000 Apr;101(4):318–22. PMID: 10782553. Intervention not included in review.10782553
Anthony WA. Cognitive remediation and psychiatric rehabilitation. Psychiatr Rehabil J. 2008 Fall;32(2):87–8. doi: 10.2975/32.2.2008.87.88. PMID: 18840561. Not a study.18840561
Anttinen E, Stenij P. The care and rehabilitation of schizophrenic out-patients with home-care. Psychiatria Fennica. 1974;145–154:100. Study design not included in review.
Armando M, Pontillo M, Vicari S. Psychosocial interventions for very early and early-onset schizophrenia: a review of treatment efficacy. Curr Opin Psychiatry. 2015 Jul;28(4):312–23. doi: 10.1097/YCO.0000000000000165. PMID: 26001923. Study design not included in review.26001923
Armijo J, Mendez E, Morales R, . Efficacy of community treatments for schizophrenia and other psychotic disorders: a literature review. Front Psychiatry. 2013 Oct;4:116. doi: 10.3389/fpsyt.2013.00116. PMID: 24130534. Not a study.24130534
Arslan M, Kurt E, Eryildiz D, . Effects of a psychosocial rehabilitation program in addition to medication in schizophrenic patients: a controlled study. Klinik Psikofarmakol Bulteni. 2014;24(4):360–7. doi: 10.5455/bcp.20140701074403. Study design not included in review.
Arslan M, Yazici A, Yilmaz T, . Long-term effects of a rehabilitation program on the clinical outcomes, social functionality, and life quality of schizophrenic patients-a follow-up study. Anadolu Psikiyatri Dergisi. 2015 Dec;16(4):238–46. Not English language.
Asenjo Lobos C, Komossa K, Rummel-Kluge C, . Clozapine versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2010 Nov 10(11):Cd006633. doi: 10.1002/14651858.CD006633.pub2. PMID: 21069690. Study covered in a systematic review.21069690
Askey R, Gamble C, Gray R. Family work in first-onset psychosis: a literature review. J Psychiatr Ment Health Nurs. 2007 Jun;14(4):356–65. doi: 10.1111/j.1365-2850.2007.01093.x. PMID: 17517026. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.17517026
Asmal L, Flegar SJ, Wang J, . Quetiapine versus other atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2013 Nov 18(11):Cd006625. doi: 10.1002/14651858.CD006625.pub3. PMID: 24249315. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.24249315
Atkinson JM, Coia DA, Gilmour WH, . The impact of education groups for people with schizophrenia on social functioning and quality of life. Br J Psychiatry. 1996 Feb;168(2):199–204. PMID: 8837910. Intervention not included in review.8837910
Au DW, Tsang HW, So WW, . Effects of integrated supported employment plus cognitive remediation training for people with schizophrenia and schizoaffective disorders. Schizophr Res. 2015 Aug;166(1–3):297–303. doi: 10.1016/j.schres.2015.05.013. PMID: 26044114. Country not eligible.26044114
Audini B, Marks IM, Lawrence RE, . Home-based versus out-patient/in-patient care for people with serious mental illness. Phase II of a controlled study. Br J Psychiatry. 1994 Aug;165(2):204–10. PMID: 7953033. Comparator not included in review.7953033
Awad G, Ng-Mak D, Rajagopalan K, . Long-term health-related quality of life improvements among patients treated with lurasidone: results from the open-label extension of a switch trial in schizophrenia. BMC Psychiatry. 2016 Jun 01;16:176. doi: 10.1186/s12888-016-0879-5. PMID: 27245981. Comparator not included in review.27245981
Ayesa-Arriola R, Rodriguez-Sanchez JM, Perez-Iglesias R, . Long-term (3-year) neurocognitive effectiveness of antipsychotic medications in first-episode non-affective psychosis: a randomized comparison of haloperidol, olanzapine, and risperidone. Psychopharmacology (Berl). 2013 Jun;227(4):615–25. doi: 10.1007/s00213-013-2994-z. PMID: 23455591. Outcome not included in review.23455591
Ayub M, Saeed K, Munshi TA, . Clozapine for psychotic disorders in adults with intellectual disabilities. Cochrane Database Syst Rev. 2015 Sep 23(9):Cd010625. doi: 10.1002/14651858.CD010625.pub2. PMID: 26397173. Population ineligible for review.26397173
Azrin NH, Teichner G. Evaluation of an instructional program for improving medication compliance for chronically mentally ill outpatients. Behav Res Ther. 1998;36:849–61. PMID: 9701860. Intervention not included in review.9701860
Bademli K, Cetinkaya Duman Z. Family to family support programs for the caregivers of schizophrenia patients: a systematic review. Turk Psikiyatri Derg. 2011;22(4):255–65. PMID: 22143951. Systematic review/meta-analysis used as a source document to identify individual studies.22143951
Bai Z, Wang G, Cai S, . Efficacy, acceptability and tolerability of 8 atypical antipsychotics in chinese patients with acute schizophrenia: A network meta-analysis. Schizophr Res. 2017 Jandoi: 10.1016/j.schres.2017.01.002. PMID: 28108226. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.28108226
Bais L, Vercammen A, Stewart R, . Short and long term effects of left and bilateral repetitive transcranial magnetic stimulation in schizophrenia patients with auditory verbal hallucinations: a randomized controlled trial. PLoS ONE. 2014;9(10):e108828. doi: 10.1371/journal.pone.0108828. PMID: 25329799. Intervention not included in review.25329799
Bak M, Fransen A, Janssen J, . Almost all antipsychotics result in weight gain: a meta-analysis. PLoS One. 2014;9(4):e94112. doi: 10.1371/journal.pone.0094112. PMID: 24763306. Comparator not included in review.24763306
Bak M, van Os J, Delespaul P, . An observational, “real life” trial of the introduction of assertive community treatment in a geographically defined area using clinical rather than service use outcome criteria. Soc Psychiatry Psychiatr Epidemiol. 2007 Feb;42(2):125–30. PMID: 17235445. Study design not included in review.17235445
Baker A, Bucci S, Lewin TJ, . Cognitive-behavioural therapy for substance use disorders in people with psychotic disorders: randomised controlled trial. Br J Psychiatry. 2006 May;188:439–48. doi: 10.1192/bjp.188.5.439. PMID: 16648530. Study covered in a systematic review.16648530
Balhara Y, Verma R. Schizophrenia and suicide. East Asian Arch Psychiatry. 2012 Sep;22(3):126–33. PMID: 23019287. Not a study.23019287
Barak Y, Savorai O, Mavashev S, . Animal-assisted therapy for elderly schizophrenic patients: a one-year controlled trial. Am J Geriatr Psychiatry. 2001;9(4):439–42. PMID: 11739071. Intervention not included in review.11739071
Barbato A, D’Avanzo B. Family interventions in schizophrenia and related disorders: a critical review of clinical trials. Acta Psychiatr Scand. 2000 Aug;102(2):81–97. PMID: 10937780. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.10937780
Barbui C, Accordini S, Nose M, . Aripiprazole versus haloperidol in combination with clozapine for treatment-resistant schizophrenia in routine clinical care: a randomized, controlled trial. J Clin Psychopharmacol. 2011 Jun;31(3):266–73. doi: 10.1097/JCP.0b013e318219cba3. PMID: 21508849. Intervention not included in review.21508849
Bark N, Revheim N, Huq F, . The impact of cognitive remediation on psychiatric symptoms of schizophrenia. Schizophr Res. 2003 Oct 1;63(3):229–35. PMID: 12957702. Setting ineligible for review (i.e., inpatient only).12957702
Barkhof E, Meijer CJ, de Sonneville LM, . The effect of motivational interviewing on medication adherence and hospitalization rates in nonadherent patients with multi-episode schizophrenia. Schizophr Bull. 2013 Nov;39(6):1242–51. doi: 10.1093/schbul/sbt138. PMID: 24072808. Comparator not included in review.24072808
Barlati S, De Peri L, Deste G, . Cognitive remediation in the early course of schizophrenia: a critical review. Curr Pharm Des. 2012;18(4):534–41. PMID: 22239585. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.22239585
Barnes TRE, Drake RJ, Dunn G, . Effect of prior treatment with antipsychotic long-acting injection on randomised clinical trial treatment outcomes. Br J Psychiatry. 2013;203(3):215–20. PMID: 23888001. Study design not included in review.23888001
Barretto EM, Kayo M, Avrichir BS, . A preliminary controlled trial of cognitive behavioral therapy in clozapine-resistant schizophrenia. J Nerv Ment Dis. 2009 Nov;197(11):865–8. doi: 10.1097/NMD.0b013e3181be7422. PMID: 19996727. Study design not included in review.19996727
Barrio C, Yamada A-M. Culturally based intervention development: the case of Latino families dealing with schizophrenia. Res Soc Work Pract. 2010 Sep;20(5):483–92. doi: 10.1177/1049731510361613. PMID: 22121328. Outcome not included in review.22121328
Barrowclough C, Haddock G, Tarrier N, . Randomized controlled trial of motivational interviewing, cognitive behavior therapy, and family intervention for patients with comorbid schizophrenia and substance use disorders. Am J Psychiatry. 2001 Oct;158(10):1706–13. PMID: 11579006. Study covered in a systematic review.11579006
Barrowclough C, Haddock G, Wykes T, . Integrated motivational interviewing and cognitive behavioural therapy for people with psychosis and comorbid substance misuse: randomised controlled trial. BMJ. 2010;341 PMID: 21106618. Study covered in a systematic review.21106618
Barry SJ, Gaughan TM, Hunter R. Schizophrenia BMJ Clin Evid. 2012 PMID: 23870705. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23870705
Bateman K, Hansen L, Turkington D, . Cognitive behavioral therapy reduces suicidal ideation in schizophrenia: results from a randomized controlled trial. Suicide Life Threat Behav. 2007 Jun;37(3):284–90. PMID: 17579541. Study covered in a systematic review.17579541
Bauml J, Frobose T, Kraemer S, . Psychoeducation: a basic psychotherapeutic intervention for patients with schizophrenia and their families. Schizophr Bull. 2006 Oct;32(Suppl1):S1–S9. doi: 10.1093/schbul/sbl017. PMID: 16920788. Outcome not included in review.16920788
Bauml J, Pitschel-Walz G, Volz A, . Psychoeducation in schizophrenia: 7-year follow-up concerning rehospitalization and days in hospital in the Munich Psychosis Information Project Study. J Clin Psychiatry. 2007 Jun;68(6):854–61. PMID: 17592908. Outcome not included in review.17592908
Bechdolf A, Knost B, Kuntermann C, . A randomized comparison of group cognitive-behavioural therapy and group psychoeducation in patients with schizophrenia.[Erratum appears in Acta Psychiatr Scand. 2004 Dec;110(6):483]. Acta Psychiatr Scand. 2004 Jul;110(1):21–8. PMID: 15180776. Comparator not included in review.15180776
Bechdolf A, Knost B, Nelson B, . Randomized comparison of group cognitive behaviour therapy and group psychoeducation in acute patients with schizophrenia: effects on subjective quality of life. Aust N Z J Psychiatry. 2010 Feb;44(2):144–50. doi: 10.3109/00048670903393571. PMID: 20113303. Population ineligible for review.20113303
Bechdolf A, Kohn D, Knost B, . A randomized comparison of group cognitive-behavioural therapy and group psychoeducation in acute patients with schizophrenia: outcome at 24 months. Acta Psychiatr Scand. 2005 Sep;112(3):173–9. PMID: 16095471. Comparator not included in review.16095471
Bechdolf A, Phillips LJ, Francey SM, . Recent approaches to psychological interventions for people at risk of psychosis. Eur Arch Psychiatry Clin Neurosci. 2006 Apr;256(3):159–73. PMID: 16639521. Not a study.16639521
Bechi M, Spangaro M, Bosia M, . Theory of mind intervention for outpatients with schizophrenia. Neuropsychol Rehabil. 2013;23(3):383–400. PMID: 23379271. Outcome not included in review.23379271
Beck K, McCutcheon R, Bloomfield MA, . The practical management of refractory schizophrenia--the Maudsley Treatment REview and Assessment Team service approach. Acta Psychiatrica Scandinavica. 2014 Dec;130(6):427–38. doi: 10.1111/acps.12327. PMID: 25201058. Study design not included in review.25201058
Becker DR, Drake RE, Bond GR, . Job terminations among persons with severe mental illness participating in supported employment. Community Ment Health J. 1998 Feb;34(1):71–82. PMID: 9559241. Comparator not included in review.9559241
Beebe LH. Community nursing support for clients with schizophrenia. Arch Psychiatr Nurs. 2001 Oct;15(5):214–22. doi: 10.1053/apnu.2001.27018. PMID: 11584350. Outcome not included in review.11584350
Behere RV, Arasappa R, Jagannathan A, . Effect of yoga therapy on facial emotion recognition deficits, symptoms and functioning in patients with schizophrenia. Acta Psychiatr Scand. 2011 Feb;123(2):147–53. doi: 10.1111/j.1600-0447.2010.01605.x. PMID: 20846271. Intervention not included in review.20846271
Bell M, Bryson G, Greig T, . Neurocognitive enhancement therapy with work therapy: effects on neuropsychological test performance. Arch Gen Psychiatry. 2001 Aug;58(8):763–8. PMID: 11483142. Comparator not included in review.11483142
Bell M, Bryson G, Wexler BE. Cognitive remediation of working memory deficits: durability of training effects in severely impaired and less severely impaired schizophrenia. Acta Psychiatr Scand. 2003 Aug;108(2):101–9. PMID: 12823166. Outcome not included in review.12823166
Bell M, Fiszdon J, Greig T, . Neurocognitive enhancement therapy with work therapy in schizophrenia: 6-month follow-up of neuropsychological performance. J Rehabil Res Dev. 2007;44(5):761–70. PMID: 17943687. Outcome not included in review.17943687
Bell M, Lysaker P, Bryson G. A behavioral intervention to improve work performance in schizophrenia: work behavior inventory feedback. J Vocat Rehabil. 2003;18(1):43–50. Intervention not included in review.
Bell MD, Bryson GJ, Greig TC, . Neurocognitive enhancement therapy with work therapy: productivity outcomes at 6- and 12-month follow-ups. J Rehabil Res Dev. 2005 Nov–Dec;42(6):829–38. PMID: 16680620. Study covered in a systematic review.16680620
Bell MD, Choi KH, Dyer C, . Benefits of cognitive remediation and supported employment for schizophrenia patients with poor community functioning. Psychiatr Serv. 2014 Apr 1;65(4):469–75. doi: 10.1176/appi.ps.201200505. PMID: 24382594. Study design not included in review.24382594
Bell MD, Lysaker PH. Clinical benefits of paid work activity in schizophrenia: 1-year followup. Schizophr Bull. 1997;23(2):317–28. PMID: 9165640. Intervention not included in review.9165640
Bell MD, Lysaker PH, Milstein RM. Clinical benefits of paid work activity in schizophrenia. Schizophr Bull. 1996;22(1):51–67. PMID: 8685664. Study covered in a systematic review.8685664
Bell MD, Zito W, Greig T, . Neurocognitive enhancement therapy with vocational services: work outcomes at two-year follow-up. Schizophr Res. 2008 Oct;105(1–3):18–29. doi: 10.1016/j.schres.2008.06.026. PMID: 18715755. Comparator not included in review.18715755
Bender S, Dittmann-Balcar A, Schall U, . Influence of atypical neuroleptics on executive functioning in patients with schizophrenia: a randomized, double-blind comparison of olanzapine vs. clozapine. Int J Neuropsychopharmacol. 2006 Apr;9(2):135–45. PMID: 16174427. Outcome not included in review.16174427
Benton MK, Schroeder HE. Social skills training with schizophrenics: a meta-analytic evaluation. J Consult Clin Psychol. 1990 Dec;58(6):741–7. PMID: 2149858. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.2149858
Bhugra D, Ayonrinde O, Butler G, . A randomised controlled trial of assertive outreach vs. treatment as usual for black people with severe mental illness. Epidemiol Psychiatr Sci. 2011 Mar;20(1):83–9. PMID: 21657119. Country not eligible.21657119
Bio DS, Gattaz WF. Vocational rehabilitation improves cognition and negative symptoms in schizophrenia. Schizophr Res. 2011 Mar;126(1–3):265–9. doi: 10.1016/j.schres.2010.08.003. PMID: 20800453. Intervention not included in review.20800453
Birchwood M, Michail M, Meaden A, . The MRC command trial: results of a multi-centre, randomised controlled trial of cognitive therapy to prevent harmful compliance with command hallucinations. Schizophr Res. 2014;153(5)doi: 10.1016/S0920-9964(14)70239-7. Not a study.
Birchwood M, Trower P. Cognitive therapy for command hallucinations: not a quasi-neuroleptic. J Contemp Psychother. 2006 Mar;36(1):1–7. doi: 10.1007/s10879-005-9000-y. Outcome not included in review.
Boczkowski JA, Zeichner A, DeSanto N. Neuroleptic compliance among chronic schizophrenic outpeople: an intervention outcome report. J Consult Clin Psychol. 1985;53:666–71. PMID: 2865281. Outcome not included in review.2865281
Bola JR, Lehtinen K, Cullberg J, . Psychosocial treatment, antipsychotic postponement, and low-dose medication strategies in first-episode psychosis: a review of the literature. Psychosis. 2009 Feb;1(1):4–18. Not a study.
Bola JR, Mosher LR. Treatment of acute psychosis without neuroleptics: two-year outcomes from the Soteria project. J Nerv Ment Dis. 2003 Apr;191(4):219–29. PMID: 12695732. Comparator not included in review.12695732
Bond GR, Miller LD, Krumwied RD, . Assertive case management in three CMHCs: a controlled study. Hosp Community Psychiatry. 1988 Apr;39(4):411–8. PMID: 2836295. Study covered in a systematic review.2836295
Bond GR, Salyers MP, Dincin J, . A randomized controlled trial comparing two vocational models for persons with severe mental illness. J Consult Clin Psychol. 2007 Dec;75(6):968–82. doi: 10.1037/0022-006x.75.6.968. PMID: 18085913. Study covered in a systematic review.18085913
Bond GR, Witheridge TF, Dincin J, . Assertive community treatment for frequent users of psychiatric hospitals in a large city: a controlled study. Am J Community Psychol. 1990 Dec;18(6):865–91. PMID: 2091459. Study covered in a systematic review.2091459
Borlido C, Remington G, Graff-Guerrero A, . Switching From 2 antipsychotics to 1 Antipsychotic in schizophrenia: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2016;77(1):e14–e20. PMID: 26845273. Study design not included in review.26845273
Bosch P, van den Noort M, Staudte H, . Schizophrenia and depression: a systematic review of the effectiveness and the working mechanisms behind acupuncture. Explore (NY). 2015 Jul–Aug;11(4):281–91. doi: 10.1016/j.explore.2015.04.004. PMID: 26007331. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.26007331
Bosch P, van den Noort M, Yeo S, . The effect of acupuncture on mood and working memory in patients with depression and schizophrenia. J Integr Med. 2015 Nov;13(6):380–90. doi: 10.1016/S2095-4964(15)60204-7. PMID: 26559363. Intervention not included in review.26559363
Boter H, Derks EM, Fleischhacker WW, . Generalizability of the results of efficacy trials in first-episode schizophrenia: comparisons between subgroups of participants of the European First Episode Schizophrenia Trial (EUFEST). J Clin Psychiatry. 2010 Jan;71(1):58–65. PMID: 19852905. Study design not included in review.19852905
Bourque J, Lakis N, Champagne J, . Clozapine and visuospatial processing in treatment-resistant schizophrenia. Cogn Neuropsychiatry. 2013;18(6):615–30. PMID: 23343453. Outcome not included in review.23343453
Bowie CR, Grossman M, Gupta M, . Cognitive remediation in schizophrenia: efficacy and effectiveness in patients with early versus long-term course of illness. Early Interv Psychiatry. 2014 Feb;8(1):32–8. doi: 10.1111/eip.12029. PMID: 23343011. Comparator not included in review.23343011
Bowie CR, McGurk SR, Mausbach B, . Combined cognitive remediation and functional skills training for schizophrenia: effects on cognition, functional competence, and real-world behavior. Am J Psychiatry. 2012 Jul;169(7):710–8. doi: 10.1176/appi.ajp.2012.11091337. PMID: 22581070. Comparator not included in review.22581070
Boyer L, Lancon C, Baumstarck K, . Evaluating the impact of a quality of life assessment with feedback to clinicians in patients with schizophrenia: randomised controlled trial. Br J Psychiatry. 2013;202:447–53. PMID: 23661768. Interventions evaluated in a single study.23661768
Brabban A, Tai S, Turkington D. Predictors of outcome in brief cognitive behavior therapy for schizophrenia. Schizophr Bull. 2009;35(5):859–64. doi: 10.1093/schbul/sbp065. PMID: 19571248. Study design not included in review.19571248
Bradley GM, Couchman GM, Perlesz A, . Multiple-family group treatment for English- and Vietnamese-speaking families living with schizophrenia. Psychiatr Serv. 2006 Apr;57(4):521–30. doi: 10.1176/appi.ps.57.4.521. PMID: 16603748. Study covered in a systematic review.16603748
Bradshaw W. Structured group work for individuals with schizophrenia: a coping skills approach. Res Soc Work Pract. 1996 Apr;6(2):139–54. doi: 10.1177/104973159600600201. Outcome not included in review.
Bradshaw W. Integrating cognitive-behavioral psychotherapy for persons with schizophrenia into a psychiatric rehabilitation program: results of a three year trial. Community Ment Health J. 2000 Oct;36(5):491–500. PMID: 10994682. Not a study.10994682
Bradshaw WH. Coping-skills training versus a problem-solving approach with schizophrenic patients. Hosp Community Psychiatry. 1993 Nov;44(11):1102–4. PMID: 8288183. Intervention not included in review.8288183
Brandon S, Cowley P, McDonald C, . Leicester ECT trial: results in schizophrenia. Br J Psychiatry. 1985 Feb;146:177–83. PMID: 3884080. Intervention not included in review.3884080
Bressi C, Manenti S, Frongia P, . Systemic family therapy in schizophrenia: a randomized clinical trial of effectiveness. Psychother Psychosom. 2008;77(1):43–9. PMID: 18087207. Study design not included in review.18087207
Briand C, Belanger R, Hamel V, . [Implementation of the multi-site Integrated Psychological Treatment (IPT) program for people with schizophrenia. Elaboration of renewed version]. Sante Ment Que. 2005 Spring;30(1):73–95. PMID: 16170424. Not English language.16170424
Briand C, Lesage A, Lalonde P, . The integrated psychological treatment (IPT) for patients with schizophrenia: evidence of effectiveness during program implementation in various sites in Quebec, Canada. Schizophr Res. 2003;60(1, Supplement):320. doi: 10.1016/S0920-9964(03)80275-X. Not English language.
Briki M, Monnin J, Haffen E, . Metacognitive training for schizophrenia: a multicentre randomised controlled trial. Schizophr Res. 2014 Aug;157(1–3):99–106. doi: 10.1016/j.schres.2014.06.005. PMID: 24972754. Study covered in a systematic review.24972754
Broderick J, Knowles A, Chadwick J, . Yoga versus standard care for schizophrenia. Cochrane Database Syst Rev. 2015 Oct 21(10):Cd010554. doi: 10.1002/14651858.CD010554.pub2. PMID: 26488850. Intervention not included in review.26488850
Brooker C, Falloon I, Butterworth A, . The outcome of training community psychiatric nurses to deliver psychosocial intervention. Br J Psychiatry. 1994 Aug;165(2):222–30. PMID: 7953037. Not a study.7953037
Bryson G, Lysaker P, Bell M. Quality of life benefits of paid work activity in schizophrenia. Schizophr Bull. 2002;28(2):249–57. PMID: 12693431. Comparator not included in review.12693431
Bucci P, Piegari G, Mucci A, . Neurocognitive individualized training versus social skills individualized training: a randomized trial in patients with schizophrenia. Schizophr Res. 2013 Oct;150(1):69–75. doi: 10.1016/j.schres.2013.07.053. PMID: 23962828. Comparator not included in review.23962828
Buchain PC, Vizzotto AD, Henna Neto J, . Randomized controlled trial of occupational therapy in patients with treatment-resistant schizophrenia. Rev Bras Psiquiatr. 2003 Mar;1999) 25(1):26–30. PMID: 12975676. Intervention not included in review.12975676
Buchkremer G, Klingberg S, Holle R, . Psychoeducational psychotherapy for schizophrenic patients and their key relatives or care-givers: results of a 2-year follow-up. Acta Psychiatr Scand. 1997 Dec;96(6):483–91. PMID: 9421346. Study covered in a systematic review.9421346
Burns T, Catty J, Becker T, . The effectiveness of supported employment for people with severe mental illness: a randomised controlled trial. Lancet. 2007 Sep 29;370(9593):1146–52. doi: 10.1016/s0140-6736(07)61516-5. PMID: 17905167. Study covered in a systematic review.17905167
Burns T, Catty J, White S, . The impact of supported employment and working on clinical and social functioning: results of an international study of individual placement and support. Schizophr Bull. 2009 Sep;35(5):949–58. doi: 10.1093/schbul/sbn024. PMID: 18403375. Intervention not included in review.18403375
Burns T, White SJ, Catty J. Individual placement and support in Europe: the EQOLISE trial. Int Rev Psychiatry. 2008;20(6):498–502. PMID: 19085404. Study covered in a systematic review.19085404
Bustillo JR, Lauriello J, Horan WP, . The psychosocial treatment of schizophrenia: an update. Am J Psychiatry. 2001 Feb;158(2):163–75. doi: 10.1176/appi.ajp.158.2.163. PMID: 11156795. Not a study.11156795
Byerly MJ, Fisher R, Carmody T, . A trial of compliance therapy in outpatients with schizophrenia or schizoaffective disorder. J Clin Psychiatry. 2005 Aug;66(8):997–1001. PMID: 16086614. Study design not included in review.16086614
Cacciotti-Saija C, Langdon R, Ward PB, . A double-blind randomized controlled trial of oxytocin nasal spray and social cognition training for young people with early psychosis. Schizophr Bull. 2015 Mar;41(2):483–93. PMID: 24962607. Intervention not included in review.24962607
Caforio G, Di Giorgio A, Rampino A, . Mirtazapine add-on improves olanzapine effect on negative symptoms of schizophrenia. J Clin Psychopharmacol. 2013 Dec;33(6):810–2. PMID: 24113675. Intervention not included in review.24113675
Calvo P, Fortuny JR, Guzman S, . Animal assisted therapy (AAT) program as a useful adjunct to conventional psychosocial rehabilitation for patients with schizophrenia: Results of a small-scale randomized controlled trial. Frontiers in Psychology Vol 7 2016, ArtID 631. 2016 May;7 PMID: 27199859. Intervention not included in review.27199859
Campbell K, Bond GR, Drake RE. Who benefits from supported employment: a meta-analytic study. Schizophr Bull. 2011 Mar;37(2):370–80. doi: 10.1093/schbul/sbp066. PMID: 19661196. Comparator not included in review.19661196
Campbell LA, Kisely SR. Advance treatment directives for people with severe mental illness. Cochrane Database Syst Rev. 2009 Jan 21(8): Cd005963. doi: 10.1002/14651858.CD005963.pub2. PMID: 19160260. Intervention not included in review.19160260
Caplan B, Schutt RK, Turner WM, . Change in neurocognition by housing type and substance abuse among formerly homeless seriously mentally ill persons. Schizophr Res. 2006 Mar;83(1):77–86. PMID: 16504484. Outcome not included in review.16504484
Carpenter WT, Heinrichs DW, Hanlon TE. A comparative trial of pharmacologic strategies in schizophrenia. Am J Psychiatry. 1987 Nov;144(11):1466–70. PMID: 2890307. Intervention not included in review.2890307
Carra G, Montomoli C, Clerici M, . Family interventions for schizophrenia in Italy: randomized controlled trial. Eur Arch Psychiatry Clin Neurosci. 2007 Feb;257(1):23–30. PMID: 16917681. Study covered in a systematic review.16917681
Castelein S, Bruggeman R, van Busschbach JT, . The effectiveness of peer support groups in psychosis: a randomized controlled trial. Acta Psychiatr Scand. 2008 Jul;118(1):64–72. PMID: 18595176. Interventions evaluated in a single study.18595176
Castelein S, Knegtering H, van Meijel B, . Dutch guideline on schizophrenia 2012: basic care within the areas of psychosocial interventions and nursing care. Tijdschr Psychiatr. 2013;55(9):707–14. PMID: 24046249. Not English language.24046249
Cather C, Penn D, Otto MW, . A pilot study of functional Cognitive Behavioral Therapy (fCBT) for schizophrenia. Schizophr Res. 2005 May 1;74(2–3):201–9. PMID: 15722000. Study covered in a systematic review.15722000
Catty J, Lissouba P, White S, . Predictors of employment for people with severe mental illness: results of an international six-centre randomised controlled trial. Br J Psychiatry. 2008 Mar;192(3):224–31. doi: 10.1192/bjp.bp.107.041475. PMID: 18310585. Study covered in a systematic review.18310585
Catty SJ, Burns T, Comas A, . Day centres for severe mental illness. Cochrane Database Syst Rev. 2007 Jan 24(1):Cd001710. doi: 10.1002/14651858.CD001710.pub2. PMID: 17253463. Intervention not included in review.17253463
Cavallaro R, Anselmetti S, Poletti S, . Computer-aided neurocognitive remediation as an enhancing strategy for schizophrenia rehabilitation. Psychiatry Res. 2009 Oct 30;169(3):191–6. doi: 10.1016/j.psychres.2008.06.027. PMID: 19740550. Study covered in a systematic review.19740550
Cazorla P, Mackle M, Zhao J, . Safety and tolerability of switching to asenapine from other antipsychotic agents: Pooled results from two randomized multicenter trials in stable patients with persistent negative symptoms in schizophrenia. Neuropsychiatr Dis Treat. 2012;8:247–57. PMID: 22745558. Study design not included in review.22745558
Cella M, Bishara AJ, Medin E, . Identifying cognitive remediation change through computational modelling-effects on reinforcement learning in schizophrenia. Schizophr Bull. 2014 Nov;40(6):1422–32. doi: 10.1093/schbul/sbt152. PMID: 24214932. Study design not included in review.24214932
Cella M, Reeder C, Wykes T. It is all in the factors: effects of cognitive remediation on symptom dimensions. Schizophr Res. 2014 Jun;156(1):60–2. doi: 10.1016/j.schres.2014.03.032. PMID: 24768130. Outcome not included in review.24768130
Ceskova E, Prikryl R, Libiger J, . Gender differences in the treatment of first-episode schizophrenia: results from the European first episode schizophrenia trial. Schizophr Res. 2015 Dec;169(1–3):303–7. doi: 10.1016/j.schres.2015.10.013. PMID: 26545298. Study covered in a systematic review.26545298
Chabannes JP, Bazin N, Leguay D, . Two-year study of relapse prevention by a new education program in schizophrenic patients treated with the same antipsychotic drug. Eur Psychiatry. 2008 Jan;23(1):8–13. PMID: 17964764. Comparator not included in review.17964764
Chadwick P, Hughes S, Russell D, . Mindfulness groups for distressing voices and paranoia: a replication and randomized feasibility trial. Behav Cogn Psychother. 2009 Jul;37(4):403–12. doi: 10.1017/S1352465809990166. PMID: 19545481. Inadequate duration (<12 weeks).19545481
Chafetz L, White M, Collins-Bride G, . Clinical trial of wellness training: health promotion for severely mentally ill adults. J Nerv Ment Dis. 2008 Jun;196(6):475–83. doi: 10.1097/NMD.0b013e31817738de. PMID: 18552625. Intervention not included in review.18552625
Challis S, Nielssen O, Harris A, . Systematic meta-analysis of the risk factors for deliberate self-harm before and after treatment for first-episode psychosis. Acta Psychiatrica Scandinavica. 2013 Jun;127(6):442–54. doi: 10.1111/acps.12074. PMID: 23298325. Outcome not included in review.23298325
Chan GHK, Jim OTT, AuYang CWS, . Effects of extended case management on functioning in people with early psychosis-preliminary findings of the easy3 randomised controlled study. Schizophr Res. 2012;136(14). Not a study.
Chan JY, Hirai HW, Tsoi KK. Can computer-assisted cognitive remediation improve employment and productivity outcomes of patients with severe mental illness? A meta-analysis of prospective controlled trials. J Psychiatr Res. 2015 Sep;68:293–300. doi: 10.1016/j.jpsychires.2015.05.010. PMID: 26028551. Comparator not included in review.26028551
Chan SH, Lee SW, Chan IW. TRIP: a psycho-educational programme in Hong Kong for people with schizophrenia. Occup Ther Int. 2007;14(2):86–98. PMID: 17623381. Country not eligible.17623381
Chan SW, Yip B, Tso S, . Evaluation of a psychoeducation program for Chinese clients with schizophrenia and their family caregivers. Patient Educ Couns. 2009 Apr;75(1):67–76. PMID: 18963721. Study covered in a systematic review.18963721
Chandler D, Hu TW, Meisel J, . Mental health costs, other public costs, and family burden among mental health clients in capitated integrated service agencies. J Ment Health Adm. 1997 Spring;24(2):178–88. PMID: 9110521. Not a study.9110521
Chandler D, Meisel J, Hu T, . A capitated model for a cross-section of severely mentally ill clients: employment outcomes. Community Ment Health J. 1997 Dec;33(6):501–16. PMID: 9435997. Intervention not included in review.9435997
Chandler D, Meisel J, Hu TW, . Client outcomes in a three-year controlled study of an integrated service agency model. Psychiatr Serv. 1996 Dec;47(12):1337–43. PMID: 9117472. Study covered in a systematic review.9117472
Chanpattana W, Chakrabhand ML, Sackeim HA, . Continuation ECT in treatment-resistant schizophrenia: a controlled study. J ECT. 1999 Sep;15(3):178–92. PMID: 10492856. Intervention not included in review.10492856
Chen JJ, Chan HY, Chen CH, . Risperidone and olanzapine versus another first generation antipsychotic in patients with schizophrenia inadequately responsive to first generation antipsychotics. Pharmacopsychiatry. 2012 Mar;45(2):64–71. doi: 10.1055/s-0031-1291293. PMID: 22086749. Inadequate duration (<12 weeks).22086749
Chen L-f, Liu J, Zhang J, . Non-pharmacological interventions for caregivers of patients with schizophrenia: a meta-analysis. Psychiatry Res. 2015 Novdoi: 10.1016/j.psychres.2015.11.037. PMID: 26639649. Outcome not included in review.26639649
Chien WT, Chan S, Morrissey J, . Effectiveness of a mutual support group for families of patients with schizophrenia. J Adv Nurs. 2005 Sep;51(6):595–608. doi: 10.1111/j.1365-2648.2005.03545.x. PMID: 16129010. Country not eligible.16129010
Chien WT, Chan SW. One-year follow-up of a multiple-family-group intervention for Chinese families of patients with schizophrenia. Psychiatr Serv. 2004 Nov;55(11):1276–84. PMID: 15534017. Country not eligible.15534017
Chien WT, Chan SW, Thompson DR. Effects of a mutual support group for families of Chinese people with schizophrenia: 18-month follow-up. Br J Psychiatry. 2006 Jul;189:41–9. doi: 10.1192/bjp.bp.105.008375. PMID: 16816305. Country not eligible.16816305
Chien WT, Lee IY. The schizophrenia care management program for family caregivers of Chinese patients with schizophrenia. Psychiatr Serv. 2010 Mar;61(3):317–20. PMID: 20194413. Country not eligible.20194413
Chien WT, Lee IY. The mindfulness-based psychoeducation program for Chinese patients with schizophrenia. Psychiatr Serv. 2013 Apr 1;64(4):376–9. doi: 10.1176/appi.ps.002092012. PMID: 23412024. Country not eligible.23412024
Chien WT, Mui J, Gray R, . Adherence therapy versus routine psychiatric care for people with schizophrenia spectrum disorders: a randomised controlled trial. BMC Psychiatry. 2016;16(1)doi: 10.1186/s12888-016-0744-6. PMID: 26911397. Country not eligible.26911397
Chien WT, Mui JHC, Cheung EFC, . Effects of motivational interviewing-based adherence therapy for schizophrenia spectrum disorders: a randomized controlled trial. Trials. 2015;16(1)doi: 10.1186/s13063-015-0785-z. PMID: 26072311. Country not eligible.26072311
Chien WT, Thompson DR. An RCT with three-year follow-up of peer support groups for Chinese families of persons with schizophrenia. Psychiatr Serv. 2013 Oct;64(10):997–1005. doi: 10.1176/appi.ps.201200243. PMID: 23820670. Country not eligible.23820670
Chien WT, Thompson DR. Effects of a mindfulness-based psychoeducation programme for Chinese patients with schizophrenia: 2-year follow-up. Br J Psychiatry. 2014 Jul;205(1):52–9. doi: 10.1192/bjp.bp.113.134635. PMID: 24809397. Country not eligible.24809397
Chien WT, Thompson DR, Norman I. Evaluation of a peer-led mutual support group for Chinese families of people with schizophrenia. Am J Community Psychol. 2008 Sep;42(1–2):122–34. doi: 10.1007/s10464-008-9178-8. PMID: 18584319. Country not eligible.18584319
Chien WT, Wong KF. A family psychoeducation group program for chinese people with schizophrenia in Hong Kong. Psychiatr Serv. 2007 Jul;58(7):1003–6. PMID: 17602019. Country not eligible.17602019
Chien W-T, Chan SWC. One-year follow-up of a multiple-family-group intervention for Chinese families of patients with schizophrenia. Psychiatr Serv. 2004;55(11):1276–84. doi: 10.1176/appi.ps.55.11.1276. PMID: 15534017. Country not eligible.15534017
Chien W-T, Norman I. The effectiveness and active ingredients of mutual support groups for family caregivers of people with psychotic disorders: a literature review. Int J Nurs Stud. 2009 Dec;46(12):1604–23. doi: 10.1016/j.ijnurstu.2009.04.003. PMID: 19481205. Study design not included in review.19481205
Chien W-T, Norman I, Thompson DR. A randomized controlled trial of a mutual support group for family caregivers of patients with schizophrenia. Int J Nurs Stud. 2004;41(6):637–49. doi: 10.1016/j.ijnurstu.2004.01.010. PMID: 15240088. Study covered in a systematic review.15240088
Chilvers R, Macdonald GM, Hayes AA. Supported housing for people with severe mental disorders. Cochrane Database Syst Rev. 2006 Oct 18(4):Cd000453. doi: 10.1002/14651858.CD000453.pub2. PMID: 17054130. Not a study.17054130
Choi KH, Kwon JH. Social cognition enhancement training for schizophrenia: a preliminary randomized controlled trial. Community Ment Health J. 2006 Apr;42(2):177–87. PMID: 16732472. Outcome not included in review.16732472
Cipriani A, Accordini S, Nose M, . Aripiprazole versus haloperidol in combination with clozapine for treatment-resistant schizophrenia: a 12-month, randomized, naturalistic trial. J Clin Psychopharmacol. 2013 Aug;33(4):533–7. PMID: 23775051. Intervention not included in review.23775051
Citrome L, Weiden PJ, Alva G, . Switching to iloperidone: an omnibus of clinically relevant observations from a 12-week, open-label, randomized clinical trial in 500 persons with schizophrenia. Clin Schizophr Relat Psychoses. 2015 Jan;8(4):183–95. doi: 10.3371/CSRP.CIWE.103114. PMID: 25367165. Study design not included in review.25367165
Citrome L, Weiden PJ, McEvoy JP, . Effectiveness of lurasidone in schizophrenia or schizoaffective patients switched from other antipsychotics: a 6-month, open-label, extension study. CNS Spectr. 2014;19(4):330–9. PMID: 24330868. Study design not included in review.24330868
Ciudad A, Anand E, Berggren L, . Switching to olanzapine long-acting injection from either oral olanzapine or any other antipsychotic: comparative post hoc analyses. Neuropsychiatr Dis Treat. 2013;9:1737–50. PMID: 24235837. Study design not included in review.24235837
Clarke GN, Herinckx HA, Kinney RF, . Psychiatric hospitalizations, arrests, emergency room visits, and homelessness of clients with serious and persistent mental illness: findings from a randomized trial of two ACT programs vs. usual care. Ment Health Serv Res. 2000 Sep;2(3):155–64. PMID: 11256724. Study covered in a systematic review.11256724
Cohen LJ, Test MA, Brown RL. Suicide and schizophrenia: data from a prospective community treatment study. Am J Psychiatry. 1990 May;147(5):602–7. doi: 10.1176/ajp.147.5.602. PMID: 2327487. Study design not included in review.2327487
Cook JA, Copeland ME, Jonikas JA, . Results of a randomized controlled trial of mental illness self-management using wellness recovery action planning. Schizophr Bull. 2012 Jun;38(4):881–91. doi: 10.1093/schbul/sbr012. PMID: 21402724. Intervention not included in review.21402724
Correll CU, Cucchiaro J, Silva R, . Long-term safety and effectiveness of lurasidone in schizophrenia: a 22-month, open-label extension study. CNS Spectr. 2016 Oct;21(5):393–402. doi: 10.1017/s1092852915000917. PMID: 27048911. Comparator not included in review.27048911
Covell NH, McEvoy JP, Schooler NR, . Effectiveness of switching from long-acting injectable fluphenazine or haloperidol decanoate to long-acting injectable risperidone microspheres: an open-label, randomized controlled trial. J Clin Psychiatry. 2012 May;73(5):669–75. doi: 10.4088/JCP.11m07074. PMID: 22480442. Study design not included in review.22480442
Craig TK, Johnson S, McCrone P, . Integrated care for co-occurring disorders: psychiatric symptoms, social functioning, and service costs at 18 months. Psychiatr Serv. 2008 Mar;59(3):276–82. doi: 10.1176/appi.ps.59.3.276. PMID: 18308908. Study design not included in review.18308908
Cramer H, Lauche R, Klose P, . Yoga for schizophrenia: a systematic review and meta-analysis. BMC Psychiatry. 2013;13:32. doi: 10.1186/1471-244X-13-32. PMID: 23327116. Intervention not included in review.23327116
Crawford MJ, Killaspy H, Barnes TR, . Group art therapy as an adjunctive treatment for people with schizophrenia: multicentre pragmatic randomised trial. BMJ. 2012;344:e846. doi: 10.1136/bmj.e846. PMID: 22374932. Intervention not included in review.22374932
Crawford-Walker CJ, King A, Chan S. Distraction techniques for schizophrenia. Cochrane Database Syst Rev. 2009 (4)PMID: 15674963. Systematic review/meta-analysis used as a source document to identify individual studies.15674963
Crespo-Facorro B, de la Foz VO, Mata I, . Treatment of first-episode non-affective psychosis: a randomized comparison of aripiprazole, quetiapine and ziprasidone over 1 year. Psychopharmacology (Berl). 2014 Jan;231(2):357–66. PMID: 23958945. Study covered in a systematic review.23958945
Crespo-Facorro B, Perez-Iglesias R, Mata I, . Long-term (3-year) effectiveness of haloperidol, risperidone and olanzapine: results of a randomized, flexible-dose, open-label comparison in first-episode nonaffective psychosis. Psychopharmacology (Berl). 2012 Jan;219(1):225–33. PMID: 21735072. Study covered in a systematic review.21735072
Crespo-Facorro B, Perez-Iglesias R, Mata I, . Aripiprazole, ziprasidone, and quetiapine in the treatment of first-episode nonaffective psychosis: results of a 6-week, randomized, flexible-dose, open-label comparison. J Clin Psychopharmacol. 2013 Apr;33(2):215–20. doi: 10.1097/JCP.0b013e3182825c1e. PMID: 23422371. Inadequate duration (<12 weeks).23422371
Crowther R, Marshall M, Bond G, . Vocational rehabilitation for people with severe mental illness. Cochrane Database Syst Rev. 2001(2):Cd003080. doi: 10.1002/14651858.cd003080. PMID: 11406069. Intervention not included in review.11406069
Cuijpers P, Hollon SD, van Straten A, . Does cognitive behaviour therapy have an enduring effect that is superior to keeping patients on continuation pharmacotherapy? A meta-analysis. BMJ Open. 2013;3(4)doi: 10.1136/bmjopen-2012-002542. PMID: 23624992. Comparator not included in review.23624992
Cunningham Owens DG, Carroll A, Fattah S, . A randomized, controlled trial of a brief interventional package for schizophrenic out-patients. Acta Psychiatr Scand. 2001 May;103(5):362–9. PMID: 11380306. Interventions evaluated in a single study.11380306
Curtis JL, Millman EJ, Struening E, . Deaths among former psychiatric inpatients in an outreach case management program. Psychiatr Serv. 1996 Apr;47(4):398–402. doi: 10.1176/ps.47.4.398. PMID: 8689371. Study covered in a systematic review.8689371
Curtis JL, Millman EJ, Struening EL, . Does outreach case management improve patients’ quality of life? Psychiatr Serv. 1998 Mar;49(3):351–4. doi: 10.1176/ps.49.3.351. PMID: 9525795. Study covered in a systematic review.9525795
Cutler AJ, Kalali AH, Mattingly GW, . Long-term safety and tolerability of iloperidone: results from a 25-week, open-label extension trial. CNS Spectr. 2013 Feb;18(1):43–54. doi: 10.1017/S1092852912000764. PMID: 23312567. Study design not included in review.23312567
Dalum HS, Korsbek L, Mikkelsen JH, . Illness management and recovery (IMR) in Danish community mental health centres. Trials. 2011;12 (195)PMID: 21849024. Study design not included in review.21849024
d’Amato T, Bation R, Cochet A, . A randomized, controlled trial of computer-assisted cognitive remediation for schizophrenia. Schizophr Res. 2011 Feb;125(2–3):284–90. doi: 10.1016/j.schres.2010.10.023. PMID: 21094025. Intervention not included in review.21094025
Dang J, Zhang J, Guo Z, . A pilot study of iPad-assisted cognitive training for schizophrenia. Arch Psychiatr Nurs. 2014 Jun;28(3):197–9. PMID: 24856273. Outcome not included in review.24856273
Davidson L, Chinman M, Sells D, . Peer support among adults with serious mental illness: a report from the field. Schizophr Bull. 2006 Jul;32(3):443–50. PMID: 16461576. Not a study.16461576
Davis LW, Lysaker PH, Kristeller JL, . Effect of mindfulness on vocational rehabilitation outcomes in stable phase schizophrenia. Psychol Serv. 2015 Aug;12(3):303–12. doi: 10.1037/ser0000028. PMID: 25938855. Intervention not included in review.25938855
Davis MC, Green MF, Lee J, . Oxytocin-augmented social cognitive skills training in schizophrenia. Neuropsychopharmacology. 2014 Aug;39(9):2070–7. doi: 10.1038/npp.2014.68. PMID: 24637803. Intervention not included in review.24637803
Davis MC, Lee J, Horan WP, . Effects of single dose intranasal oxytocin on social cognition in schizophrenia. Schizophr Res. 2013 Jul;147(2–3):393–7. PMID: 23676253. Intervention not included in review.23676253
De Giacomo P, Pierri G, Santoni Rugiu A, . Schizophrenia: a study comparing a family therapy group following a paradoxical model plus psychodrugs and a group treated by the conventional clinical approach. Acta Psychiatr Scand. 1997 Mar;95(3):183–8. PMID: 9111850. Study covered in a systematic review.9111850
de Jesus DR, Gil A, Barbosa L, . A pilot double-blind sham-controlled trial of repetitive transcranial magnetic stimulation for patients with refractory schizophrenia treated with clozapine. Psychiatry Res. 2011 Jul 30;188(2):203–7. doi: 10.1016/j.psychres.2010.11.022. PMID: 21186062. Intervention not included in review.21186062
de Jesus Mari J, Streiner DL. An overview of family interventions and relapse on schizophrenia: meta-analysis of research findings. Psychol Med. 1994 Aug;24(3):565–78. doi: 10.1017/S0033291700027720. PMID: 7991739. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.7991739
De Silva MJ, Cooper S, Li HL, . Effect of psychosocial interventions on social functioning in depression and schizophrenia: meta-analysis. Br J Psychiatry. 2013 Apr;202(4):253–60. doi: 10.1192/bjp.bp.112.118018. PMID: 23549941. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23549941
de Weijer AD, Sommer IE, Lotte Meijering A, . High frequency rTMS; a more effective treatment for auditory verbal hallucinations? Psychiatry Res. 2014 Dec 30;224(3):204–10. doi: 10.1016/j.pscychresns.2014.10.007. PMID: 25453990. Inadequate duration (<12 weeks).25453990
Dean M, Weston AR, Osborn DP, . Activity groups for people with schizophrenia: a randomized controlled trial. J Ment Health. 2014 Aug;23(4):171–5. doi: 10.3109/09638237.2014.889285. PMID: 24660971. Interventions evaluated in a single study.24660971
Dekker J, Wijdenes W, Koning YA, . Assertive community treatment in Amsterdam. Community Ment Health J. 2002 Oct;38(5):425–34. PMID: 12236412. Intervention not included in review.12236412
Demily C, Cavezian C, Desmurget M, . The game of chess enhances cognitive abilities in schizophrenia. Schizophr Res. 2009 Jan;107(1):112–3. doi: 10.1016/j.schres.2008.09.024. PMID: 18995990. Intervention not included in review.18995990
Depp CA, Mausbach B, Granholm E, . Mobile interventions for severe mental illness: design and preliminary data from three approaches. J Nerv Ment Dis. 2010 Oct;198(10):715–21. doi: 10.1097/NMD.0b013e3181f49ea3. PMID: 20921861. Study design not included in review.20921861
D’Ercole A, Struening E, Curtis JL, . Effects of diagnosis, demographic characteristics, and case management on rehospitalization. Psychiatr Serv. 1997 May;48(5):682–8. PMID: 9144824. Outcome not included in review.9144824
Desamericq G, Schurhoff F, Meary A, . Long-term neurocognitive effects of antipsychotics in schizophrenia: a network meta-analysis. Eur J Clin Pharmacol. 2014 Feb;70(2):127–34. doi: 10.1007/s00228-013-1600-y. PMID: 24145817. Outcome not included in review.24145817
Dickerson FB, Lehman AF. Evidence-based psychotherapy for schizophrenia. J Nerv Ment Dis. 2006 Jan;194(1):3–9. PMID: 16462548. Not a study.16462548
Dickerson FB, Lehman AF. Evidence-based psychotherapy for schizophrenia: 2011 update. J Nerv Ment Dis. 2011 Aug;199(8):520–6. doi: 10.1097/NMD.0b013e318225ee78. PMID: 21814072. Not a study.21814072
Dickinson D, Gold JM. Less unique variance than meets the eye: overlap among traditional neuropsychological dimensions in schizophrenia. Schizophr Bull. 2008 May;34(3):423–34. PMID: 17702991. Outcome not included in review.17702991
Dickinson D, Tenhula W, Morris S, . A randomized, controlled trial of computer-assisted cognitive remediation for schizophrenia. Am J Psychiatry. 2010 Feb;167(2):170–80. doi: 10.1176/appi.ajp.2009.09020264. PMID: 20008941. Study covered in a systematic review.20008941
Dieterich M, Irving CB, Park B, . Intensive case management for severe mental illness. Cochrane Database Syst Rev. 2010 Oct 06(10):Cd007906. doi: 10.1002/14651858.CD007906.pub2. PMID: 20927766. Intervention not included in review.20927766
Dixon L, Adams C, Lucksted A. Update on family psychoeducation for schizophrenia. Schizophr Bull. 2000;26(1):5–20. PMID: 10755667. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.10755667
Dixon L, Lyles A, Scott J, . Services to families of adults with schizophrenia: from treatment recommendations to dissemination. Psychiatr Serv. 1999 Feb;50(2):233–8. PMID: 10030482. Outcome not included in review.10030482
Dixon L, Stewart B, Burland J, . Pilot study of the effectiveness of the family-to-family education program. Psychiatr Serv. 2001 Jul;52(7):965–7. doi: 10.1176/appi.ps.52.7.965. PMID: 11433116. Study design not included in review.11433116
Dixon LB, Dickerson F, Bellack AS, . The 2009 schizophrenia PORT psychosocial treatment recommendations and summary statements. Schizophr Bull. 2010 Jan;36(1):48–70. doi: 10.1093/schbul/sbp115. PMID: 19955389. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.19955389
Dixon LB, Goldman HH, Bennett ME, . Implementing coordinated specialty care for early psychosis: the RAISE Connection Program. Psychiatr Serv. 2015 Jul;66(7):691–8. doi: 10.1176/appi.ps.201400281. PMID: 25772764. Study design not included in review.25772764
Dixon LB, Lehman AF. Family interventions for schizophrenia. Schizophr Bull. 1995;21(4):631–43. PMID: 8749890. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.8749890
Doane JA, Falloon IR, Goldstein MJ, . Parental affective style and the treatment of schizophrenia. Predicting course of illness and social functioning. Arch Gen Psychiatry. 1985 Jan;42(1):34–42. PMID: 3966851. Study design not included in review.3966851
Doane JA, Goldstein MJ, Miklowitz DJ, . The impact of individual and family treatment on the affective climate of families of schizophrenics. Br J Psychiatry. 1986 Mar;148:279–87. doi: 10.1192/bjp.148.3.279. PMID: 3719220. Outcome not included in review.3719220
Dobson DJ, McDougall G, Busheikin J, . Effects of social skills training and social milieu treatment on symptoms of schizophrenia. Psychiatr Serv. 1995 Apr;46(4):376–80. PMID: 7788460. Inadequate duration (<12 weeks).7788460
Dold M, Fugger G, Aigner M, . Dose escalation of antipsychotic drugs in schizophrenia: a meta-analysis of randomized controlled trials. Schizophr Res. 2015 Aug;166(1–3):187–93. doi: 10.1016/j.schres.2015.04.024. PMID: 26008883. Study design not included in review.26008883
Dold M, Samara MT, Li C, . Haloperidol versus first-generation antipsychotics for the treatment of schizophrenia and other psychotic disorders. Cochrane Database Syst Rev. 2015 (1)PMID: 25592299. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.25592299
Dougall N, Maayan N, Soares-Weiser K, . Transcranial Magnetic Stimulation for Schizophrenia. Schizophr Bull. 2015 Nov;41(6):1220–2. doi: 10.1093/schbul/sbv121. PMID: 26392626. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.26392626
Drake R, Day C, Picucci R, . A naturalistic, randomized, controlled trial combining cognitive remediation with cognitive-behavioural therapy after first-episode non-affective psychosis. Psychol Med. 2014 Jul;44(9):1889–99. doi: 10.1017/S0033291713002559. PMID: 24172842. Outcome not included in review.24172842
Drake RE, Bond GR, Goldman HH, . Individual Placement And Support Services Boost Employment For People With Serious Mental Illnesses, But Funding Is Lacking. Health Aff (Millwood). 2016 Jun 01;35(6):1098–105. doi: 10.1377/hlthaff.2016.0001. PMID: 27269028. Not a study.27269028
Drake RE, Frey W, Bond GR, . Assisting Social Security Disability Insurance beneficiaries with schizophrenia, bipolar disorder, or major depression in returning to work. Am J Psychiatry. 2013 Dec;170(12):1433–41. doi: 10.1176/appi.ajp.2013.13020214. PMID: 23929355. Intervention not included in review.23929355
Drake RE, McHugo GJ, Bebout RR, . A randomized clinical trial of supported employment for inner-city patients with severe mental disorders. Arch Gen Psychiatry. 1999 Jul;56(7):627–33. PMID: 10401508. Study covered in a systematic review.10401508
Drake RE, McHugo GJ, Becker DR, . The New Hampshire study of supported employment for people with severe mental illness. J Consult Clin Psychol. 1996 Apr;64(2):391–9. PMID: 8871423. Study covered in a systematic review.8871423
D’Souza DC, Radhakrishnan R, Perry E, . Feasibility, safety, and efficacy of the combination of D-serine and computerized cognitive retraining in schizophrenia: an international collaborative pilot study. Neuropsychopharmacology. 2013 Feb;38(3):492–503. doi: 10.1038/npp.2012.208. PMID: 23093223. Intervention not included in review.23093223
Duckworth K, Halpern L. Peer support and peer-led family support for persons living with schizophrenia. Curr Opin Psychiatry. 2014 May;27(3):216–21. doi: 10.1097/YCO.0000000000000051. PMID: 24662961. Not a study.24662961
Duggan L, Fenton M, Rathbone J, . Olanzapine for schizophrenia. Cochrane Database Syst Rev. 2005 Apr 18(2):Cd001359. doi: 10.1002/14651858.CD001359.pub2. PMID: 15846619. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.15846619
Duncan E, Best C, Hagen S. Shared decision making interventions for people with mental health conditions. Cochrane Database Syst Rev. 2010 Jan 20(1):Cd007297. doi: 10.1002/14651858.CD007297.pub2. PMID: 20091628. Intervention not included in review.20091628
Dunn H, Morrison AP. Psychosis. Handbook of homework assignments in psychotherapy. New York, NY: Springer Science + Business Media; US; 2007:335–49. Study design not included in review.
Duraiswamy G, Thirthalli J, Nagendra HR, . Yoga therapy as an add-on treatment in the management of patients with schizophrenia--a randomized controlled trial. Acta Psychiatr Scand. 2007 Sep;116(3):226–32. PMID: 17655565. Intervention not included in review.17655565
Durgam S, Cutler AJ, Lu K, . Cariprazine in acute exacerbation of schizophrenia: a fixed-dose, phase 3, randomized, double-blind, placebo- and active-controlled trial. J Clin Psychiatry. 2015 Dec;76(12):e1574–82. doi: 10.4088/JCP.15m09997. PMID: 26717533. Inadequate duration (<12 weeks).26717533
Durham RC, Chambers JA, Power KG, . Long-term outcome of cognitive behaviour therapy clinical trials in central Scotland. Health Technol Assess. 2005 Nov;9(42):1–174. PMID: 16266559. Population ineligible for review.16266559
Durham RC, Guthrie M, Morton RV, . Tayside-Fife clinical trial of cognitive-behavioural therapy for medication-resistant psychotic symptoms. Results to 3-month follow-up. Br J Psychiatry. 2003 Apr;182:303–11. PMID: 12668405. Study covered in a systematic review.12668405
Dyck DG, Hendryx MS, Short RA, . Service use among patients with schizophrenia in psychoeducational multiple-family group treatment. Psychiatr Serv. 2002 Jun;53(6):749–54. PMID: 12045314. Study covered in a systematic review.12045314
Eack SM, Greenwald DP, Hogarty SS, . Cognitive enhancement therapy for early-course schizophrenia: effects of a two-year randomized controlled trial. Psychiatr Serv. 2009 Nov;60(11):1468–76. doi: 10.1176/appi.ps.60.11.1468. PMID: 19880464. Study covered in a systematic review.19880464
Eack SM, Greenwald DP, Hogarty SS, . One-year durability of the effects of cognitive enhancement therapy on functional outcome in early schizophrenia. Schizophr Res. 2010;120(1–3):210–6. PMID: 20472402. Comparator not included in review.20472402
Eack SM, Hogarty GE, Cho RY, . Neuroprotective effects of cognitive enhancement therapy against gray matter loss in early schizophrenia: results from a 2-year randomized controlled trial. Arch Gen Psychiatry. 2010 Jul;67(7):674–82. doi: 10.1001/archgenpsychiatry.2010.63. PMID: 20439824. Outcome not included in review.20439824
Eack SM, Hogarty GE, Greenwald DP, . Cognitive enhancement therapy improves emotional intelligence in early course schizophrenia: preliminary effects. Schizophr Res. 2007 Jan;89(1–3):308–11. PMID: 17055227. Outcome not included in review.17055227
Eack SM, Hogarty GE, Greenwald DP, . Effects of cognitive enhancement therapy on employment outcomes in early schizophrenia: results from a 2-year randomized trial. Res Soc Work Pract. 2011 Jan;21(1):32–42. doi: 10.1177/1049731509355812. PMID: 23885163. Study covered in a systematic review.23885163
Eack SM, Hogarty SS, Greenwald DP, . Cognitive enhancement therapy in substance misusing schizophrenia: results of an 18-month feasibility trial. Schizophr Res. 2015 Feb;161(2–3):478–83. doi: 10.1016/j.schres.2014.11.017. PMID: 25510926. Sample size too small (<50).25510926
Eack SM, Mesholam-Gately RI, Greenwald DP, . Negative symptom improvement during cognitive rehabilitation: results from a 2-year trial of cognitive enhancement therapy. Psychiatry Res. 2013 Aug 30;209(1):21–6. doi: 10.1016/j.psychres.2013.03.020. PMID: 23623449. Study covered in a systematic review.23623449
Eack SM, Pogue-Geile MF, Greenwald DP, . Mechanisms of functional improvement in a 2-year trial of cognitive enhancement therapy for early schizophrenia. Psychol Med. 2011 Jun;41(6):1253–61. doi: 10.1017/S0033291710001765. PMID: 20860867. Outcome not included in review.20860867
Echeburua E, Gomez M, Freixa M. Cognitive-behavioural treatment of pathological gambling in individuals with chronic schizophrenia: a pilot study. Behav Res Ther. 2011 Nov;49(11):808–14. doi: 10.1016/j.brat.2011.08.009. PMID: 21920501. Outcome not included in review.21920501
Ecker J, Aubry T, Wasylenki D, . Predicting alcohol use and drug use among consumers of community mental health programs. J Dual Diagn. 2012 Jul;8(3):188–99. doi: 10.1080/15504263.2012.697861. Study design not included in review.
Eckman TA, Wirshing WC, Marder SR, . Technique for training schizophrenic patients in illness self-management: a controlled trial. Am J Psychiatry. 1992 Nov;149(11):1549–55. PMID: 1384364. Comparator not included in review.1384364
Edwards CJ, Cella M, Tarrier N, . Investigating the empirical support for therapeutic targets proposed by the temporal experience of pleasure model in schizophrenia: a systematic review. Schizophr Res. 2015 Oct;168(1–2):120–44. doi: 10.1016/j.schres.2015.08.013. PMID: 26342966. Outcome not included in review.26342966
El-Sayeh HG, Morganti C. Aripiprazole for schizophrenia. Cochrane Database Syst Rev. 2006 Apr 19(2):Cd004578. doi: 10.1002/14651858.CD004578.pub3. PMID: 16625607. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.16625607
Emmerson LC, Granholm E, Link PC, . Insight and treatment outcome with cognitive-behavioral social skills training for older people with schizophrenia. J Rehabil Res Dev. 2009;46(8):1053–8. PMID: 20157862. Not a study.20157862
Engh JA, Andersen E, Holmen TL, . Effects of high-intensity aerobic exercise on psychotic symptoms and neurocognition in outpatients with schizophrenia: study protocol for a randomized controlled trial. Trials. 2015;16 (1)PMID: 26646670. Intervention not included in review.26646670
England M. Efficacy of cognitive nursing intervention for voice hearing. Perspect Psychiatr Care. 2007 Apr;43(2):69–76. PMID: 17388849. Study covered in a systematic review.17388849
England M. Significance of cognitive intervention for voice hearers. Perspect Psychiatr Care. 2008 Jan;44(1):40–7. doi: 10.1111/j.1744-6163.2008.00146.x. PMID: 18177277. Study covered in a systematic review.18177277
Erawati E, Keliat BA, Helena N, . The influence of metacognitive training on delusion severity and metacognitive ability in schizophrenia. J Psychiatr Ment Health Nurs. 2014;21(9):841–7. doi: 10.1111/jpm.12130. PMID: 24548341. Intervention not included in review.24548341
Essali A, Tarboush M, Awad M. Specialist interventions for homeless people with severe mental illness (Protocol). Cochrane Database Syst Rev. 2012 Dec 12(12):Cd010170. doi: 10.1002/14651858.CD010170. Not a study.
Essock SM, Kontos N. Implementing assertive community treatment teams. Psychiatr Serv. 1995 Jul;46(7):679–83. PMID: 7552558. Comparator not included in review.7552558
Essock SM, Mueser KT, Drake RE, . Comparison of ACT and standard case management for delivering integrated treatment for co-occurring disorders. Psychiatr Serv. 2006 Feb;57(2):185–96. PMID: 16452695. Study covered in a systematic review.16452695
Evins AE, Cather C, Culhane MA, . A 12-week double-blind, placebo-controlled study of bupropion sr added to high-dose dual nicotine replacement therapy for smoking cessation or reduction in schizophrenia. J Clin Psychopharmacol. 2007 Aug;27(4):380–6. PMID: 17632223. Outcome not included in review.17632223
Evins AE, Cather C, Deckersbach T, . A double-blind placebo-controlled trial of bupropion sustained-release for smoking cessation in schizophrenia. J Clin Psychopharmacol. 2005 Jun;25(3):218–25. PMID: 15876899. Outcome not included in review.15876899
Evins AE, Cather C, Rigotti NA, . Two-year follow-up of a smoking cessation trial in patients with schizophrenia: increased rates of smoking cessation and reduction. J Clin Psychiatry. 2004 Mar;65(3):307–11; quiz 452–3. PMID: 15096068. Intervention not included in review.15096068
Evins AE, Mays VK, Rigotti NA, . A pilot trial of bupropion added to cognitive behavioral therapy for smoking cessation in schizophrenia. Nicotine Tob Res. 2001 Nov;3(4):397–403. PMID: 11694208. Intervention not included in review.11694208
Falloon IR, Boyd JL, McGill CW, . Family management in the prevention of exacerbations of schizophrenia: a controlled study. N Engl J Med. 1982 Jun 17;306(24):1437–40. PMID: 6123079. Study covered in a systematic review.6123079
Falloon IR, Boyd JL, McGill CW, . Family management in the prevention of morbidity of schizophrenia. Clinical outcome of a two-year longitudinal study. Arch Gen Psychiatry. 1985 Sep;42(9):887–96. PMID: 2864032. Study covered in a systematic review.2864032
Falloon IR, Lindley P, McDonald R, . Social skills training of out-patient groups. A controlled study of rehearsal and homework. Br J Psychiatry. 1977;131:599–609. PMID: 597688. Intervention not included in review.597688
Falloon IR, McGill CW, Boyd JL, . Family management in the prevention of morbidity of schizophrenia: social outcome of a two-year longitudinal study. Psychol Med. 1987 Feb;17(1):59–66. PMID: 3575578. Study covered in a systematic review.3575578
Falloon IR, Pederson J. Family management in the prevention of morbidity of schizophrenia: the adjustment of the family unit. Br J Psychiatry. 1985 Aug;147:156–63. doi: 10.1192/bjp.147.2.156. PMID: 4041688. Study covered in a systematic review.4041688
Fan X, Copeland PM, Liu EY, . No effect of single-dose intranasal insulin treatment on verbal memory and sustained attention in patients with schizophrenia. J Clin Psychopharmacol. 2011 Apr;31(2):231–4. PMID: 21346605. Intervention not included in review.21346605
Fan X, Liu E, Freudenreich O, . No effect of adjunctive, repeated-dose intranasal insulin treatment on psychopathology and cognition in patients with schizophrenia. J Clin Psychopharmacol. 2013 Apr;33(2):226–30. PMID: 23422397. Intervention not included in review.23422397
Fardig R, Lewander T, Melin L, . A randomized controlled trial of the illness management and recovery program for persons with schizophrenia. Psychiatr Serv. 2011 Jun;62(6):606–12. PMID: 21632728. Sample size too small (<50).21632728
Farhall J, Freeman NC, Shawyer F, . An effectiveness trial of cognitive behaviour therapy in a representative sample of outpatients with psychosis. Br J Clin Psychol. 2009 Mar;48(Pt 1):47–62. doi: 10.1348/014466608x360727. PMID: 18851771. Study covered in a systematic review.18851771
Farreny A, Aguado J, Ochoa S, . The role of negative symptoms in the context of cognitive remediation for schizophrenia. Schizophr Res. 2013 Oct;150(1):58–63. doi: 10.1016/j.schres.2013.08.008. PMID: 23993864. Outcome not included in review.23993864
Faulkner G, Cohn T, Remington G. Interventions to reduce weight gain in schizophrenia. Cochrane Database Syst Rev. 2007 Jan 24(1):Cd005148. doi: 10.1002/14651858.CD005148.pub2. PMID: 17253540. Intervention not included in review.17253540
Faulkner G, Duncan MJ, Hahn M, . Behavioural interventions for reducing weight gain in schizophrenia. Cochrane Database Syst Rev. 2013(10). Study design not included in review.
Favrod J, Rexhaj S, Bardy S, . Sustained antipsychotic effect of metacognitive training in psychosis: a randomized-controlled study. Eur Psychiatry. 2014 Jun;29(5):275–81. doi: 10.1016/j.eurpsy.2013.08.003. PMID: 24176646. Outcome not included in review.24176646
Feldmann R, Hornung W, Prein B, . Timing of psychoeducational psychotherapeutic interventions in schizophrenic patients. Eur Arch Psychiatry Clin Neurosci. 2002;252(3):115–9. doi: 10.1007/s00406-002-0369-2. PMID: 12192468. Outcome not included in review.12192468
Feldmann R, Hornung WP, Buchkremer G, . The influence of familial loading on the course of schizophrenic symptoms and the success of psychoeducational therapy. Psychopathology. 2001 Jul–Aug;34(4):192–7. PMID: 11549929. Not a study.11549929
Fenton FR, Tessier L, Struening EL. A comparative trial of home and hospital psychiatric care. One-year follow-up. Arch Gen Psychiatry. 1979 Sep;36(10):1073–9. PMID: 475542. Comparator not included in review.475542
Fenton FR, Tessier L, Struening EL, . A two-year follow-up of a comparative trial of the cost-effectiveness of home and hospital psychiatric treatment. Can J Psychiatry. 1984 Apr;29(3):205–11. PMID: 6442211. Outcome not included in review.6442211
Fenton WS. Evolving perspectives on individual psychotherapy for schizophrenia. Schizophr Bull. 2000;26(1):47–72. PMID: 10755669. Not a study.10755669
Fenton WS, Dickerson F, Boronow J, . A placebo-controlled trial of omega-3 fatty acid (ethyl eicosapentaenoic acid) supplementation for residual symptoms and cognitive impairment in schizophrenia. Am J Psychiatry. 2001 Dec;158(12):2071–4. PMID: 11729030. Intervention not included in review.11729030
Fernandes BS, Massuda R, Torres M, . Improvement of schizophrenia with electroconvulsive therapy and serum brain-derived neurotrophic factor levels: lack of association in a pilot study. Psychiatry Clin Neurosci. 2010 Dec;64(6):663–5. doi: 10.1111/j.1440-1819.2010.02153.x. PMID: 21105955. Intervention not included in review.21105955
Fernández ÓV, Giráldez SL, Sáiz AG, . Integrated psychological treatment for schizophrenic patients. Psicothema. 1998;10(2):459–74. Intervention not included in review.
Fernandez-Gonzalo S, Turon M, Jodar M, . A new computerized cognitive and social cognition training specifically designed for patients with schizophrenia/schizoaffective disorder in early stages of illness: a pilot study. Psychiatry Res. 2015;228(3):501–9. PMID: 26163731. Sample size too small (<50).26163731
Ferreira CD, de Souza MGD, Fernandez-Calvo B, . Neurocognitive functions in schizophrenia: a systematic review of the effects of typical and atypical antipsychotic drugs. Psychol Neurosci. 2016 Mar;9(1):12–31. doi: 10.1037/pne0000045. Outcome not included in review.
Fervaha G, Agid O, Takeuchi H, . Life satisfaction among individuals with schizophrenia in the Clinical Antipsychotic Trial of Intervention Effectiveness (CATIE) study. Am J Psychiatry. 2013 Sep;170(9):1061–2. doi: 10.1176/appi.ajp.2013.13010060. PMID: 24030617. Not a study.24030617
Fervaha G, Agid O, Takeuchi H, . Clinical determinants of life satisfaction in chronic schizophrenia: data from the CATIE study. Schizophr Res. 2013 Dec;151(1–3):203–8. PMID: 24183751. Outcome not included in review.24183751
Field CD, Galletly C, Anderson D, . Computer-aided cognitive rehabilitation: possible application to the attentional deficit of schizophrenia, a report of negative results. Percept Mot Skills. 1997 Dec;85(3 Pt 1):995–1002. PMID: 9399309. Inadequate duration (<12 weeks).9399309
Fiorillo A, Bassi M, de Girolamo G, . The impact of a psychoeducational intervention on family members’ views about schizophrenia: results from the OASIS Italian multi-centre study. Int J Soc Psychiatry. 2011 Nov;57(6):596–603. doi: 10.1177/0020764010376607. PMID: 20650976. Outcome not included in review.20650976
Firth J, Cotter J, Elliott R, . A systematic review and meta-analysis of exercise interventions in schizophrenia patients. Psychol Med. 2015 May;45(7):1343–61. doi: 10.1017/S0033291714003110. PMID: 25650668. Intervention not included in review.25650668
Fisher M, Holland C, Merzenich MM, . Using neuroplasticity-based auditory training to improve verbal memory in schizophrenia. Am J Psychiatry. 2009 Jul;166(7):805–11. PMID: 19448187. Outcome not included in review.19448187
Fisher M, Holland C, Subramaniam K, . Neuroplasticity-based cognitive training in schizophrenia: an interim report on the effects 6 months later. Schizophr Bull. 2010 Jul;36(4):869–79. PMID: 19269924. Study covered in a systematic review.19269924
Fisher M, Loewy R, Carter C, . Neuroplasticity-based auditory training via laptop computer improves cognition in young individuals with recent onset schizophrenia. Schizophr Bull. 2015 Jan;41(1):250–8. doi: 10.1093/schbul/sbt232. PMID: 24444862. Inadequate duration (<12 weeks).24444862
Fisher M, Mellon SH, Wolkowitz O, . Neuroscience-informed auditory training in schizophrenia: a final report of the effects on cognition and serum brain-derived neurotrophic factor. Schizophr Res Cogn. 2016;3:1–7. PMID: 26705516. Outcome not included in review.26705516
Fiszdon JM, Bryson GJ, Wexler BE, . Durability of cognitive remediation training in schizophrenia: performance on two memory tasks at 6-month and 12-month follow-up. Psychiatry Res. 2004 Jan 30;125(1):1–7. PMID: 14967547. Study covered in a systematic review.14967547
Fiszdon JM, Choi J, Bryson GJ, . Impact of intellectual status on response to cognitive task training in patients with schizophrenia. Schizophr Res. 2006 Oct;87(1–3):261–9. PMID: 16737798. Study design not included in review.16737798
Fiszdon JM, Choi J, Goulet J, . Temporal relationship between change in cognition and change in functioning in schizophrenia. Schizophr Res. 2008 Oct;105(1–3):105–13. doi: 10.1016/j.schres.2008.06.010. PMID: 18657398. Study design not included in review.18657398
Fiszdon JM, Johannesen JK. Comparison of computational methods for the evaluation of learning potential in schizophrenia. J Int Neuropsychol Soc. 2010 Jul;16(4):613–20. doi: 10.1017/S1355617710000317. PMID: 20374673. Study design not included in review.20374673
Fiszdon JM, Kurtz MM, Choi J, . Motivational interviewing to increase cognitive rehabilitation adherence in schizophrenia. Schizophr Bull. 2016 Mar;42(2):327–34. doi: 10.1093/schbul/sbv143. PMID: 26420905. Outcome not included in review.26420905
Fiszdon JM, Whelahan H, Bryson GJ, . Cognitive training of verbal memory using a dichotic listening paradigm: impact on symptoms and cognition. Acta Psychiatr Scand. 2005 Sep;112(3):187–93. PMID: 16095473. Study covered in a systematic review.16095473
Fitzgerald PB, Benitez J, Daskalakis JZ, . A double-blind sham-controlled trial of repetitive transcranial magnetic stimulation in the treatment of refractory auditory hallucinations. J Clin Psychopharmacol. 2005 Aug;25(4):358–62. PMID: 16012279. Intervention not included in review.16012279
Fitzgerald PB, Herring S, Hoy K, . A study of the effectiveness of bilateral transcranial magnetic stimulation in the treatment of the negative symptoms of schizophrenia. Brain Stimul. 2008 Jan;1(1):27–32. doi: 10.1016/j.brs.2007.08.001. PMID: 20633367. Intervention not included in review.20633367
Fitzgerald PB, McQueen S, Daskalakis ZJ, . A negative pilot study of daily bimodal transcranial direct current stimulation in schizophrenia. Brain Stimul. 2014 Nov–Dec;7(6):813–6. doi: 10.1016/j.brs.2014.08.002. PMID: 25442152. Intervention not included in review.25442152
Ford R, Beadsmoore A, Ryan P, . Providing the safety net: case management for people with a serious mental illness. J Ment Health. 1995. Study covered in a systematic review.
Ford R, Ryan P, Beadsmoore A, . Intensive case management for people with serious mental illness- Site 2: Clinical and social outcome. J Ment Health. 1997 1997/01/01;6(2):181–90. doi: 10.1080/09638239718941. Study covered in a systematic review.
Forsberg KA, Bjorkman T, Sandman PO, . Physical health--a cluster randomized controlled lifestyle intervention among persons with a psychiatric disability and their staff. Nord J Psychiatry. 2008;62(6):486–95. doi: 10.1080/08039480801985179. PMID: 18843564. Intervention not included in review.18843564
Foruzandeh N, Parvin N. Occupational therapy for inpatients with chronic schizophrenia: a pilot randomized controlled trial. Jpn J Nurs Sci. 2013 Jun;10(1):136–41. doi: 10.1111/j.1742-7924.2012.00211.x. PMID: 23735098. Setting ineligible for review (i.e., inpatient only).23735098
Fowler D, Hodgekins J, Painter M, . Cognitive behaviour therapy for improving social recovery in psychosis: a report from the ISREP MRC Trial Platform Study (Improving Social Recovery in Early Psychosis). Psychol Med. 2009 Oct;39(10):1627–36. doi: 10.1017/s0033291709005467. PMID: 19335932. Outcome not included in review.19335932
Foxx RM, McMorrow MJ, Bittle RG, . Teaching social skills to psychiatric inpatients. Behav Res Ther. 1985;23(5):531–7. PMID: 4051925. Setting ineligible for review (i.e., inpatient only).4051925
Franck N, Duboc C, Sundby C, . Specific vs general cognitive remediation for executive functioning in schizophrenia: a multicenter randomized trial. Schizophr Res. 2013 Jun;147(1):68–74. doi: 10.1016/j.schres.2013.03.009. PMID: 23583327. Comparator not included in review.23583327
Fredrick MM, Mintz J, Roberts DL, . Is cognitive adaptation training (CAT) compensatory, restorative, or both? Schizophr Res. 2015 Aug;166(1–3):290–6. doi: 10.1016/j.schres.2015.06.003. PMID: 26126419. Outcome not included in review.26126419
Freeman D, Dunn G, Startup H, . The effects of reducing worry in patients with persecutory delusions: study protocol for a randomized controlled trial. Trials. 2012;13:223. doi: 10.1186/1745-6215-13-223. PMID: 23171601. Not a study.23171601
Freeman D, Garety P, Fowler D, . The London-East Anglia randomized controlled trial of cognitive-behaviour therapy for psychosis. IV: self-esteem and persecutory delusions. Br J Clin Psychol. 1998 Nov;37(Pt 4):415–30. PMID: 9856295. Study design not included in review.9856295
Freeman D, Pugh K, Dunn G, . An early Phase II randomised controlled trial testing the effect on persecutory delusions of using CBT to reduce negative cognitions about the self: the potential benefits of enhancing self confidence. Schizophr Res. 2014 Dec;160(1–3):186–92. doi: 10.1016/j.schres.2014.10.038. PMID: 25468186. Outcome not included in review.25468186
Freeman D, Startup H, Myers E, . The effects of using cognitive behavioural therapy to improve sleep for patients with delusions and hallucinations (the BEST study): study protocol for a randomized controlled trial. Trials. 2013;14:214. doi: 10.1186/1745-6215-14-214. PMID: 23845104. Not a study.23845104
Freeman D, Waite F, Startup H, . Efficacy of cognitive behavioural therapy for sleep improvement in patients with persistent delusions and hallucinations (BEST): a prospective, assessor-blind, randomised controlled pilot trial. Lancet Psychiatry. 2015;2(11):975–83. PMID: 26363701. Sample size too small (<50).26363701
Freitas C, Fregni F, Pascual-Leone A. Meta-analysis of the effects of repetitive transcranial magnetic stimulation (rTMS) on negative and positive symptoms in schizophrenia. Schizophr Res. 2009 Mar;108(1–3):11–24. doi: 10.1016/j.schres.2008.11.027. PMID: 19138833. Intervention not included in review.19138833
Fritze J, Forthner B, Schmitt B, . Cognitive training adjunctive to pharmacotherapy in schizophrenia and depression: a pilot study on the lateralization hypothesis of schizophrenia and depression and on cognitive therapy as adjunctive to pharmacotherapy. Neuropsychobiology. 1988;19(1):45–50. PMID: 3185895. Outcome not included in review.3185895
Fung KM, Tsang HW, Cheung WM. Randomized controlled trial of the self-stigma reduction program among individuals with schizophrenia. Psychiatry Res. 2011 Sep 30;189(2):208–14. doi: 10.1016/j.psychres.2011.02.013. PMID: 21377738. Interventions evaluated in a single study.21377738
Fusar-Poli P, Kempton MJ, Rosenheck RA. Efficacy and safety of second-generation long-acting injections in schizophrenia: a meta-analysis of randomized-controlled trials. Int Clin Psychopharmacol. 2013 Mar;28(2):57–66. doi: 10.1097/YIC.0b013e32835b091f. PMID: 23165366. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23165366
Fusar-Poli P, Papanastasiou E, Stahl D, . Treatments of negative symptoms in schizophrenia: meta-analysis of 168 randomized placebo-controlled trials. Schizophr Bull. 2015 Jul;41(4):892–9. doi: 10.1093/schbul/sbu170. PMID: 25528757. Comparator not included in review.25528757
Gaebel W, Riesbeck M, Wolwer W, . Rates and predictors of remission in first-episode schizophrenia within 1year of antipsychotic maintenance treatment. Results of a randomized controlled trial within the German research network on schizophrenia. Schizophr Res. 2014;152(2–3):478–86. PMID: 23643327. Outcome not included in review.23643327
Gaebel W, Schreiner A, Bergmans P, . Relapse prevention in schizophrenia and schizoaffective disorder with risperidone long-acting injectable vs quetiapine: results of a long-term, open-label, randomized clinical trial. Neuropsychopharmacology. 2010 Nov;35(12):2367–77. doi: 10.1038/npp.2010.111. PMID: 20686456. Study covered in a systematic review.20686456
Galderisi S, Mucci A, Bitter I, . Persistent negative symptoms in first episode patients with schizophrenia: results from the European First Episode Schizophrenia Trial. Eur Neuropsychopharmacol. 2013 Mar;23(3):196–204. doi: 10.1016/j.euroneuro.2012.04.019. PMID: 22647933. Study design not included in review.22647933
Galderisi S, Piegari G, Mucci A, . Social skills and neurocognitive individualized training in schizophrenia: comparison with structured leisure activities. Eur Arch Psychiatry Clin Neurosci. 2010 Jun;260(4):305–15. doi: 10.1007/s00406-009-0078-1. PMID: 19826855. Comparator not included in review.19826855
Gallagher AG, Dinan TG, Baker LV. The effects of varying information content and speaking aloud on auditory hallucinations. Br J Med Psychol. 1995 Jun;68(Pt 2):143–55. PMID: 7547611. Study design not included in review.7547611
Garcia S, Fuentes I, Ruiz JC, . Application of the IPT in a Spanish sample: evaluation of the “social perception subprogramme”. Intern Jour Psych Psychol Ther. 2003 Dec;3(2):299–310. Study design not included in review.
Garety P, Kuipers L, Fowler D, . Cognitive behavioural therapy for drug-resistant psychosis. Br J Med Psychol. 1994 Sep;67(3):259–71. doi: 10.1111/j.2044-8341.1994.tb01795.x. PMID: 7803318. Study design not included in review.7803318
Garrido G, Barrios M, Penades R, . Computer-assisted cognitive remediation therapy: cognition, self-esteem and quality of life in schizophrenia. Schizophr Res. 2013 Nov;150(2–3):563–9. doi: 10.1016/j.schres.2013.08.025. PMID: 24035402. Comparator not included in review.24035402
Gater R, Goldberg D, Jackson G, . The care of patients with chronic schizophrenia: a comparison between two services. Psychol Med. 1997 Nov;27(6):1325–36. PMID: 9403904. Outcome not included in review.9403904
Gaudiano BA. Is symptomatic improvement in clinical trials of cognitive-behavioral therapy for psychosis clinically significant? J Psychiatr Pract. 2006 Jan;12(1):11–23. PMID: 16432441. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.16432441
Gaughran F, Stahl D, Ismail K, . Improving physical health and reducing substance use in psychosis - randomised control trial (IMPACT RCT): study protocol for a cluster randomised controlled trial. BMC Psychiatry. 2013;13 PMID: 24131496. Not a study.24131496
Gaynes BN, Brown C, Lux LJ, . Management Strategies To Reduce Psychiatric Readmissions. Rockville (MD): Agency for Healthcare Research and Quality (US); 2015. Intervention not included in review.
Gearing RE, Alonzo D, Marinelli C. Maternal schizophrenia: psychosocial treatment for mothers and their children. Clin Schizophr Relat Psychoses. 2012 Apr;6(1):27–33. doi: 10.3371/CSRP.6.1.4. PMID: 22453867. Outcome not included in review.22453867
Gelkopf M, Gonen B, Kurs R, . The effect of humorous movies on inpatients with chronic schizophrenia. J Nerv Ment Dis. 2006 Nov;194(11):880–3. PMID: 17102716. Setting ineligible for review (i.e., inpatient only).17102716
Gelkopf M, Noam S, Rudinski D, . Nonmedication smoking reduction program for inpatients with chronic schizophrenia: a randomized control design study. J Nerv Ment Dis. 2012 Feb;200(2):142–6. doi: 10.1097/NMD.0b013e3182438e92. PMID: 22297311. Intervention not included in review.22297311
Gentile S. Adverse effects associated with second-generation antipsychotic long-acting injection treatment: a comprehensive systematic review. Pharmacotherapy. 2013 Oct;33(10):1087–106. doi: 10.1002/phar.1313. PMID: 23776129. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23776129
George TP, Ziedonis DM, Feingold A, . Nicotine transdermal patch and atypical antipsychotic medications for smoking cessation in schizophrenia. Am J Psychiatry. 2000 Nov;157(11):1835–42. PMID: 11058482. Intervention not included in review.11058482
Georgiev A, Probst M, De Hert M, . Acute effects of progressive muscle relaxation on state anxiety and subjective well-being in chronic Bulgarian patients with schizophrenia. Psychiatr Danub. 2012 Dec;24(4):367–72. PMID: 23132187. Inadequate duration (<12 weeks).23132187
Ghadiri Vasfi M, Moradi-Lakeh M, Esmaeili N, . Efficacy of aftercare services for people with severe mental disorders in Iran: a randomized controlled trial. Psychiatr Serv. 2015 Apr 1;66(4):373–80. doi: 10.1176/appi.ps.201400111. PMID: 25828982. Intervention not included in review.25828982
Gharaeipour M, Scott BJ. Effects of cognitive remediation on neurocognitive functions and psychiatric symptoms in schizophrenia inpatients. Schizophr Res. 2012 Dec;142(1–3):165–70. doi: 10.1016/j.schres.2012.09.018. PMID: 23102691. Setting ineligible for review (i.e., inpatient only).23102691
Gibson CM, Penn DL, Smedley KL, . A pilot six-week randomized controlled trial of oxytocin on social cognition and social skills in schizophrenia. Schizophr Res. 2014 Jul;156(2–3):261–5. PMID: 24799299. Intervention not included in review.24799299
Gil Sanz D, Diego Lorenzo M, Bengochea Seco R, . Efficacy of a social cognition training program for schizophrenic patients: a pilot study. Span J Psychol. 2009 May;12(1):184–91. PMID: 19476231. Study design not included in review.19476231
Gingerich SL, Bellack AS. Research-based family interventions for the treatment of schizophrenia. Res Soc Work Pract. 1996 Jan;6(1):122–6. doi: 10.1177/104973159600600112. Not a study.
Girgis RR, Merrill DB, Vorel SR, . Aripiprazole versus haloperidol treatment in early-stage schizophrenia. J Psychiatr Res. 2011 Jun;45(6):756–62. doi: 10.1016/j.jpsychires.2010.09.003. PMID: 20937506. Study covered in a systematic review.20937506
Giron M, Fernandez-Yanez A, Mana-Alvarenga S, . Efficacy and effectiveness of individual family intervention on social and clinical functioning and family burden in severe schizophrenia: a 2-year randomized controlled study. Psychol Med. 2010 Jan;40(1):73–84. doi: 10.1017/S0033291709006126. PMID: 19490746. Sample size too small (<50).19490746
Giron M, Nova-Fernandez F, Mana-Alvarenga S, . How does family intervention improve the outcome of people with schizophrenia? Soc Psychiatry Psychiatr Epidemiol. 2015 Mar;50(3):379–87. doi: 10.1007/s00127-014-0942-9. PMID: 25087012. Outcome not included in review.25087012
Gleeson JF, Alvarez-Jimenez M, Cotton SM, . A systematic review of relapse measurement in randomized controlled trials of relapse prevention in first-episode psychosis. Schizophr Res. 2010 Jun;119(1–3):79–88. doi: 10.1016/j.schres.2010.02.1073. PMID: 20347266. Systematic review/meta-analysis used as a source document to identify individual studies.20347266
Gleeson JF, Cotton SM, Alvarez-Jimenez M, . Family outcomes from a randomized control trial of relapse prevention therapy in first-episode psychosis. J Clin Psychiatry. 2010 Apr;71(4):475–83. doi: 10.4088/JCP.08m04672yel. PMID: 20021994. Intervention not included in review.20021994
Glick ID, Clarkin JF, Haas GL, . Clinical significance of inpatient family intervention: conclusions from a clinical trial. Hosp Community Psychiatry. 1993 Sep;44(9):869–73. PMID: 8225301. Setting ineligible for review (i.e., inpatient only).8225301
Glick ID, Clarkin JF, Haas GL, . A randomized clinical trial of inpatient family intervention: VI. Mediating variables and outcome. Fam Process. 1991 Mar;30(1):85–99. doi: 10.1111/j.1545-5300.1991.00085.x. PMID: 2044754. Setting ineligible for review (i.e., inpatient only).2044754
Glick ID, Correll CU, Altamura AC, . Mid-term and long-term efficacy and effectiveness of antipsychotic medications for schizophrenia: a data-driven, personalized clinical approach. J Clin Psychiatry. 2011 Dec;72(12):1616–27. doi: 10.4088/JCP.11r06927. PMID: 22244023. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.22244023
Glick ID, Fleming L, DeChillo N, . A controlled study of transitional day care for non-chronically-ill patients. Am J Psychiatry. 1986 Dec;143(12):1551–6. PMID: 3789208. Intervention not included in review.3789208
Glick ID, Hargreaves WA, Drues J, . Short vs long hospitalization. A controlled study: III. Inpatient results for nonschizophrenics. Arch Gen Psychiatry. 1976 Jan;33(1):78–83. PMID: 813604. Setting ineligible for review (i.e., inpatient only).813604
Glick ID, Hargreaves WA, Goldfield MD. Short vs long hospitalization. A prospective controlled study. I. The preliminary results of a one-year follow-up schizophrenics. Arch Gen Psychiatry. 1974 Mar;30(3):363–9. PMID: 4813139. Intervention not included in review.4813139
Glick ID, Hargreaves WA, Raskin M, . Short versus long hospitalization: a prospective controlled study. II. Results for schizophrenic inpatients. Am J Psychiatry. 1975 Apr;132(4):385–90. PMID: 1119589. Intervention not included in review.1119589
Glick ID, Spencer JH, Clarkin JF, . A randomized clinical trial of inpatient family intervention: IV. Followup results for subjects with schizophrenia. Schizophr Res. 1990 May–Jun;3(3):187–200. doi: 10.1016/0920-9964%2890%2990036-7. PMID: 2278982. Setting ineligible for review (i.e., inpatient only).2278982
Glynn SM, Cohen AN, Niv N. New challenges in family interventions for schizophrenia. Expert Rev Neurother. 2007 Jan;7(1):33–43. PMID: 17187495. Not a study.17187495
Glynn SM, Marder SR, Liberman RP, . Supplementing clinic-based skills training with manual-based community support sessions: effects on social adjustment of patients with schizophrenia. Am J Psychiatry. 2002 May;159(5):829–37. PMID: 11986138. Comparator not included in review.11986138
Gohar SM, Hamdi E, El Ray LA, . Adapting and evaluating a social cognitive remediation program for schizophrenia in Arabic. Schizophr Res. 2013 Aug;148(1–3):12–7. doi: 10.1016/j.schres.2013.05.008. PMID: 23756297. Country not eligible.23756297
Gold C, Heldal TO, Dahle T, . Music therapy for schizophrenia or schizophrenia-like illnesses. Cochrane Database Syst Rev. 2005 Apr 18(2):Cd004025. doi: 10.1002/14651858.CD004025.pub2. PMID: 15846692. Intervention not included in review.15846692
Gold PB, Meisler N, Santos AB, . Randomized trial of supported employment integrated with assertive community treatment for rural adults with severe mental illness. Schizophr Bull. 2006 Apr;32(2):378–95. PMID: 16177278. Study covered in a systematic review.16177278
Goldberg D. Cost-effectiveness in the treatment of patients with schizophrenia. Acta Psychiatr Scand. 1994;89(382, Suppl):89–92. doi: 10.1111/j.1600-0447.1994.tb05873.x. PMID: 8092005. Outcome not included in review.8092005
Goldberg SC, Schooler NR, Hogarty GE, . Prediction of relapse in schizophrenic outpatients treated by drug and sociotherapy. Arch Gen Psychiatry. 1977 Feb;34(2):171–84. PMID: 843177. Study design not included in review.843177
Goldsmith LP, Lewis SW, Dunn G, . Psychological treatments for early psychosis can be beneficial or harmful, depending on the therapeutic alliance: an instrumental variable analysis. Psychol Med. 2015 Aug;45(11):2365–73. doi: 10.1017/S003329171500032X. PMID: 25805118. Study design not included in review.25805118
Goldstein MJ. Psychosocial treatment of schizophrenia. Schizophrenia: Scientific progress. New York, NY: Oxford University Press; US; 1989:318–24. Not a study.
Goldstein MJ, Rodnick EH, Evans JR, . Drug and family therapy in the aftercare of acute schizophrenics. Arch Gen Psychiatry. 1978 Oct;35(10):1169–77. doi: 10.1001/archpsyc.1978.01770340019001. PMID: 211983. Study covered in a systematic review.211983
Gomar JJ, Valls E, Radua J, . A multisite, randomized controlled clinical trial of computerized cognitive remediation therapy for schizophrenia. Schizophr Bull. 2015 Nov;41(6):1387–96. doi: 10.1093/schbul/sbv059. PMID: 26006264. Outcome not included in review.26006264
Gong W, Xu D, Zhou L, . Village doctor-assisted case management of rural patients with schizophrenia: protocol for a cluster randomized control trial. Implement Sci. 2014;9:13. doi: 10.1186/1748-5908-9-13. PMID: 24433461. Not a study.24433461
Gorczynski P, Faulkner G. Exercise therapy for schizophrenia. Cochrane Database Syst Rev. 2010 May 12(5):Cd004412. doi: 10.1002/14651858.CD004412.pub2. PMID: 20464730. Intervention not included in review.20464730
Gottlieb JD, Cather C, Shanahan M, . D-cycloserine facilitation of cognitive behavioral therapy for delusions in schizophrenia. Schizophr Res. 2011 Sep;131(1–3):69–74. doi: 10.1016/j.schres.2011.05.029. PMID: 21723096. Intervention not included in review.21723096
Gould RA, Mueser KT, Bolton E, . Cognitive therapy for psychosis in schizophrenia: an effect size analysis. Schizophrenia Research. 2001 Mar 30;48(2–3):335–42. PMID: 11295385. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.11295385
Goyal N, Nizamie SH, Desarkar P. Efficacy of adjuvant high frequency repetitive transcranial magnetic stimulation on negative and positive symptoms of schizophrenia: preliminary results of a double-blind sham-controlled study. J Neuropsychiatry Clin Neurosci. 2007;19(4):464–7. PMID: 18070852. Intervention not included in review.18070852
Graeber DA, Moyers TB, Griffith G, . A pilot study comparing motivational interviewing and an educational intervention in patients with schizophrenia and alcohol use disorders. Community Ment Health J. 2003 Jun;39(3):189–202. PMID: 12836801. Study covered in a systematic review.12836801
Graham HL, Copello A, Griffith E, . Pilot randomised trial of a brief intervention for comorbid substance misuse in psychiatric in-patient settings. Acta Psychiatr Scand. 2016;133(4):298–309. PMID: 26590876. Setting ineligible for review (i.e., inpatient only).26590876
Granholm E, Ben-Zeev D, Link PC. Social disinterest attitudes and group cognitive-behavioral social skills training for functional disability in schizophrenia. Schizophr Bull. 2009 Sep;35(5):874–83. doi: 10.1093/schbul/sbp072. PMID: 19628761. Comparator not included in review.19628761
Granholm E, Holden J, Link PC, . Randomized clinical trial of cognitive behavioral social skills training for schizophrenia: improvement in functioning and experiential negative symptoms. J Consult Clin Psychol. 2014 Dec;82(6):1173–85. doi: 10.1037/a0037098. PMID: 24911420. Comparator not included in review.24911420
Granholm E, Holden J, Link PC, . Randomized controlled trial of cognitive behavioral social skills training for older consumers with schizophrenia: defeatist performance attitudes and functional outcome. Am J Geriatr Psychiatry. 2013 Mar;21(3):251–62. doi: 10.1016/j.jagp.2012.10.014. PMID: 23395192. Comparator not included in review.23395192
Granholm E, Holden JL, Sommerfeld D, . Enhancing assertive community treatment with cognitive behavioral social skills training for schizophrenia: study protocol for a randomized controlled trial. Trials. 2015;16(1):438. PMID: 26424639. Not a study.26424639
Granholm E, McQuaid JR, Auslander LA, . Group cognitive-behavioral social skills training for older outpatients with chronic schizophrenia. J Cogn Psychother. 2004 Fal;18(3):265–79. doi: 10.1891/jcop.18.3.265.65652. Study design not included in review.
Granholm E, McQuaid JR, Link PC, . Neuropsychological predictors of functional outcome in cognitive behavioral social skills training for older people with schizophrenia. Schizophr Res. 2008 Mar;100(1–3):133–43. doi: 10.1016/j.schres.2007.11.032. PMID: 18222648. Outcome not included in review.18222648
Granholm E, McQuaid JR, McClure FS, . Randomized controlled trial of cognitive behavioral social skills training for older people with schizophrenia: 12-month follow-up. J Clin Psychiatry. 2007 May;68(5):730–7. PMID: 17503982. Study covered in a systematic review.17503982
Granholm E, McQuaid JR, McClure FS, . A randomized controlled pilot study of cognitive behavioral social skills training for older patients with schizophrenia. Schizophr Res. 2002 Jan 1;53(1–2):167–9. PMID: 11728848. Not a study.11728848
Grawe RW, Falloon IR, Widen JH, . Two years of continued early treatment for recent-onset schizophrenia: a randomised controlled study. Acta Psychiatr Scand. 2006 Nov;114(5):328–36. PMID: 17022792. Study covered in a systematic review.17022792
Gray R, Leese M, Bindman J, . Adherence therapy for people with schizophrenia. European multicentre randomised controlled trial. Br J Psychiatry. 2006;189:508–14. PMID: 17139034. Intervention not included in review.17139034
Greenwood K, Hung CF, Tropeano M, . No association between the Catechol-O-Methyltransferase (COMT) val158met polymorphism and cognitive improvement following cognitive remediation therapy (CRT) in schizophrenia.[Erratum appears in Neurosci Lett. 2011 Jul 15;499(1):57]. Neurosci Lett. 2011 Jun 1;496(2):65–9. doi: 10.1016/j.neulet.2011.03.075. PMID: 21458532. Study design not included in review.21458532
Greig TC, Zito W, Wexler BE, . Improved cognitive function in schizophrenia after one year of cognitive training and vocational services. Schizophr Res. 2007 Nov;96(1–3):156–61. PMID: 17669629. Outcome not included in review.17669629
Grinspoon L, Ewalt JR, Shader R. Long-term treatment of chronic schizophrenia. A preliminary report. Int J Psychiatry. 1967 Aug;4(2):116–28. PMID: 4862724. Study design not included in review.4862724
Gromer J. Need-adapted and open-dialogue treatments: empirically supported psychosocial interventions for schizophrenia and other psychotic disorders. Ethical Hum Psychol Psychiatry. 2012;14(3):162–77. doi: 10.1891/1559-4343.14.3.162. Not a study.
Grunder G, Heinze M, Cordes J, . Effects of first-generation antipsychotics versus second-generation antipsychotics on quality of life in schizophrenia: A double-blind, randomised study. Lancet Psychiatry. 2016 Aug;3(8):717–29. doi: 10.1016/S2215-0366%2816%2900085-7. PMID: 27265548. Study design not included in review.27265548
Grynszpan O, Perbal S, Pelissolo A, . Efficacy and specificity of computer-assisted cognitive remediation in schizophrenia: a meta-analytical study. Psychol Med. 2011 Jan;41(1):163–73. doi: 10.1017/S0033291710000607. PMID: 20380784. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.20380784
Guastella AJ, Ward PB, Hickie IB, . A single dose of oxytocin nasal spray improves higher-order social cognition in schizophrenia. Schizophr Res. 2015;168(3):628–33. PMID: 26150070. Intervention not included in review.26150070
Gudeman JE, Dickey B, Rood L, . Alternative to the back ward: the quarterway house. Hosp Community Psychiatry. 1981 May;32(5):330–4. PMID: 7239459. Intervention not included in review.7239459
Gumley AI, MacBeth A, Reilly JD, . Fear of recurrence: results of a randomized trial of relapse detection in schizophrenia. Br J Clin Psychol. 2015 Mar;54(1):49–62. doi: 10.1111/bjc.12060. PMID: 25040487. Intervention not included in review.25040487
Gunderson JG, Frank AF. Effects of psychotherapy in schizophrenia. Yale J Biol Med. 1985 Jul–Aug;58(4):373–81. PMID: 4049918. Intervention not included in review.4049918
Gunderson JG, Frank AF, Katz HM, . Effects of psychotherapy in schizophrenia: II. Comparative outcome of two forms of treatment. Schizophr Bull. 1984;10(4):564–98. PMID: 6151246. Intervention not included in review.6151246
Haas GL, Glick ID, Clarkin JF, . Gender and schizophrenia outcome: a clinical trial of an inpatient family intervention. Schizophr Bull. 1990;16(2):277–92. PMID: 2197716. Setting ineligible for review (i.e., inpatient only).2197716
Haas GL, Glick ID, Clarkin JF, . Inpatient family intervention: a randomized clinical trial: II. Results at hospital discharge. Arch Gen Psychiatry. 1988 Mar;45(3):217–24. doi: 10.1001/archpsyc.1988.01800270025003. PMID: 3277578. Setting ineligible for review (i.e., inpatient only).3277578
Habib N, Dawood S, Kingdon D, . Preliminary evaluation of culturally adapted CBT for psychosis (CA-CBTp): findings from developing culturally-sensitive CBT project (DCCP). Behav Cogn Psychother. 2015 Mar;43(2):200–8. doi: 10.1017/S1352465813000829. PMID: 24382109. Country not eligible.24382109
Hadas-Lidor N, Katz N, Tyano S, . Effectiveness of dynamic cognitive intervention in rehabilitation of clients with schizophrenia. Clin Rehabil. 2001 Aug;15(4):349–59. PMID: 11518436. Study covered in a systematic review.11518436
Haddock G, Barrowclough C, Tarrier N, . Cognitive-behavioural therapy and motivational intervention for schizophrenia and substance misuse. 18-month outcomes of a randomised controlled trial. Br J Psychiatry. 2003 Nov;183:418–26. PMID: 14594917. Study covered in a systematic review.14594917
Haddock G, Slade PD, Bentall RP, . A comparison of the long-term effectiveness of distraction and focusing in the treatment of auditory hallucinations. Br J Med Psychol. 1998 Sep;71(3):339–49. doi: 10.1111/j.2044-8341.1998.tb00996.x. PMID: 9733427. Outcome not included in review.9733427
Halperin S, Nathan P, Drummond P, . A cognitive-behavioural, group-based intervention for social anxiety in schizophrenia. Aust N Z J Psychiatry. 2000 Oct;34(5):809–13. PMID: 11037367. Inadequate duration (<12 weeks).11037367
Hamann J, Cohen R, Leucht S, . Shared decision making and long-term outcome in schizophrenia treatment. J Clin Psychiatry. 2007;68:992–7. PMID: 17685733. Intervention not included in review.17685733
Hamann J, Mendel R, Meier A, . “How to speak to your psychiatrist”: shared decision-making training for inpatients with schizophrenia. Psychiatr Serv. 2011 Oct;62(10):1218–21. PMID: 21969650. Intervention not included in review.21969650
Hamilton AB, Cohen AN, Glover DL, . Implementation of evidence-based employment services in specialty mental health. Health Serv Res. 2013 Dec;48(6 Pt 2):2224–44. doi: 10.1111/1475-6773.12115. PMID: 24138608. Study design not included in review.24138608
Hansen JP, Ostergaard B, Nordentoft M, . Cognitive adaptation training combined with assertive community treatment: a randomised longitudinal trial. Schizophr Res. 2012 Mar;135(1–3):105–11. doi: 10.1016/j.schres.2011.12.014. PMID: 22264599. Comparator not included in review.22264599
Hansen JP, Ostergaard B, Nordentoft M, . The feasibility of cognitive adaptation training for outpatients with schizophrenia in integrated treatment. Community Ment Health J. 2013 Dec;49(6):630–5. doi: 10.1007/s10597-012-9557-3. PMID: 23064969. Comparator not included in review.23064969
Hansson L, Svensson B, Bjorkman T, . What works for whom in a computer-mediated communication intervention in community psychiatry? Moderators of outcome in a cluster randomized trial. Acta Psychiatr Scand. 2008 Nov;118(5):404–9. doi: 10.1111/j.1600-0447.2008.01258.x. PMID: 18759805. Outcome not included in review.18759805
Harder S, Koester A, Valbak K, . Five-year follow-up of supportive psychodynamic psychotherapy in first-episode psychosis: long-term outcome in social functioning. Psychiatry. 2014;77(2):155–68. doi: 10.1521/psyc.2014.77.2.155. PMID: 24865198. Study design not included in review.24865198
Harvey PD, Ogasa M, Cucchiaro J, . Performance and interview-based assessments of cognitive change in a randomized, double-blind comparison of lurasidone vs. ziprasidone. Schizophr Res. 2011 Apr;127(1–3):188–94. doi: 10.1016/j.schres.2011.01.004. PMID: 21277745. Inadequate duration (<12 weeks).21277745
Harvey PD, Siu CO, Ogasa M, . Effect of lurasidone dose on cognition in patients with schizophrenia: post-hoc analysis of a long-term, double-blind continuation study. Schizophr Res. 2015 Aug;166(1–3):334–8. doi: 10.1016/j.schres.2015.06.008. PMID: 26117157. Study design not included in review.26117157
Hasan A, Guse B, Cordes J, . Cognitive Effects of High-Frequency rTMS in Schizophrenia Patients With Predominant Negative Symptoms: Results From a Multicenter Randomized Sham-Controlled Trial. Schizophrenia Bulletin. 2016 May;42(3):608–18. doi: 10.1093/schbul/sbv142. PMID: 26433217. Inadequate duration (<12 weeks).26433217
Hasan AA, Callaghan P, Lymn JS. Evaluation of the impact of a psycho-educational intervention on knowledge levels and psychological outcomes for people diagnosed with schizophrenia and their caregivers in Jordan: a randomized controlled trial. BMC Psychiatry. 2014;14:17. doi: 10.1186/1471-244X-14-17. PMID: 24450608. Country not eligible.24450608
Hasan AA, Callaghan P, Lymn JS. Evaluation of the impact of a psycho-educational intervention for people diagnosed with schizophrenia and their primary caregivers in Jordan: a randomized controlled trial. BMC Psychiatry. 2015;15:72. doi: 10.1186/s12888-015-0444-7. PMID: 25885432. Country not eligible.25885432
Hatta K, Otachi T, Fujita K, . Antipsychotic switching versus augmentation among early non-responders to risperidone or olanzapine in acute-phase schizophrenia. Schizophr Res. 2014 Sep;158(1–3):213–22. doi: 10.1016/j.schres.2014.07.015. PMID: 25086659. Population ineligible for review.25086659
Hay A, Byers A, Sereno M, . Asenapine versus placebo for schizophrenia. Cochrane Database Syst Rev. 2015 Nov 24(11):Cd011458. doi: 10.1002/14651858.CD011458.pub2. PMID: 26599405. Comparator not included in review.26599405
Hayes RL, Halford WK, Varghese FN. Generalization of the effects of activity therapy and social skills training on the social behavior of low functioning schizophrenic patients. Occup Ther Ment Health. 1991;11(4):3–20. Setting ineligible for review (i.e., inpatient only).
Hayes RL, McGrath JJ. Cognitive rehabilitation for people with schizophrenia and related conditions. Cochrane Database Syst Rev. 2000(3):Cd000968. doi: 10.1002/14651858.cd000968. PMID: 10908479. Intervention not included in review.10908479
Hazel NA, McDonell MG, Short RA, . Impact of multiple-family groups for outpatients with schizophrenia on caregivers’ distress and resources. Psychiatr Serv. 2004 Jan;55(1):35–41. PMID: 14699198. Outcome not included in review.14699198
He Y, Li C. Morita therapy for schizophrenia. Cochrane Database Syst Rev. 2012 (9)PMID: 17253588. Intervention not included in review.17253588
Hegde S, Rao SL, Raguram A, . Addition of home-based cognitive retraining to treatment as usual in first episode schizophrenia patients: a randomized controlled study. Indian J Psychiatry. 2012;54(1):15–22. PMID: 22556432. Sample size too small (<50).22556432
Heggelund J, Morken G, Helgerud J, . Therapeutic effects of maximal strength training on walking efficiency in patients with schizophrenia - a pilot study. BMC Res Notes. 2012;5:344. doi: 10.1186/1756-0500-5-344. PMID: 22759719. Intervention not included in review.22759719
Held T, Falloon IR. Family therapy of schizophrenia. Keio J Med. 1999 Sep;48(3):151–4. PMID: 10535277. Study design not included in review.10535277
Helgason C, Sarris J. Mind-body medicine for schizophrenia and psychotic disorders: a review of the evidence. Clin Schizophr Relat Psychoses. 2013 Oct;7(3):138–48. doi: 10.3371/CSRP.HESA.020813. PMID: 23428783. Interventions evaluated in a single study.23428783
Herinckx HA, Kinney RF, Clarke GN, . Assertive community treatment versus usual care in engaging and retaining clients with severe mental illness. Psychiatr Serv. 1997 Oct;48(10):1297–306. doi: 10.1176/ps.48.10.1297. PMID: 9323749. Study covered in a systematic review.9323749
Herman D, Opler L, Felix A, . A critical time intervention with mentally ill homeless men: impact on psychiatric symptoms. J Nerv Ment Dis. 2000 Mar;188(3):135–40. PMID: 10749277. Interventions evaluated in a single study.10749277
Herz MI. Psychosocial treatment. Psychiatr Ann. 1996 Aug;26(8):531–5. Study design not included in review.
Herz MI, Lamberti JS, Mintz J, . A program for relapse prevention in schizophrenia: a controlled study. Arch Gen Psychiatry. 2000 Mar;57(3):277–83. PMID: 10711914. Interventions evaluated in a single study.10711914
Hjorthoj C, Fohlmann A, Nordentoft M. Reprint of “treatment of cannabis use disorders in people with schizophrenia spectrum disorders - a systematic review”. Addict Behav. 2009 Oct;34(10):846–51. doi: 10.1016/j.addbeh.2009.02.003. PMID: 19604646. Study design not included in review.19604646
Hjorthoj C, Fohlmann A, Nordentoft M. Treatment of cannabis use disorders in people with schizophrenia spectrum disorders-a systematic review. Addict Behav. 2009 Jun–Jul;34(6–7):520–5. doi: 10.1016/j.addbeh.2009.02.001. PMID: 19268481. Study design not included in review.19268481
Hjorthoj CR, Fohlmann A, Larsen AM, . Specialized psychosocial treatment plus treatment as usual (TAU) versus TAU for patients with cannabis use disorder and psychosis: the CapOpus randomized trial. Psychol Med. 2013 Jul;43(7):1499–510. doi: 10.1017/S0033291712002255. PMID: 23040144. Intervention not included in review.23040144
Hjorthoj CR, Orlovska S, Fohlmann A, . Psychiatric treatment following participation in the CapOpus randomized trial for patients with comorbid cannabis use disorder and psychosis. Schizophr Res. 2013 Dec;151(1–3):191–6. PMID: 24189290. Study design not included in review.24189290
Ho JS, Moore RC, Davine T, . Direct and mediated effects of cognitive function with multidimensional outcome measures in schizophrenia: the role of functional capacity. J Clin Exp Neuropsychol. 2013;35(8):882–95. doi: 10.1080/13803395.2013.828021. PMID: 23984631. Study design not included in review.23984631
Hodge MA, Siciliano D, Withey P, . A randomized controlled trial of cognitive remediation in schizophrenia. Schizophr Bull. 2010 Mar;36(2):419–27. doi: 10.1093/schbul/sbn102. PMID: 18718884. Study covered in a systematic review.18718884
Hoffman RE, Boutros NN, Hu S, . Transcranial magnetic stimulation and auditory hallucinations in schizophrenia. Lancet. 2000 Mar 25;355(9209):1073–5. PMID: 10744097. Study design not included in review.10744097
Hoffman RE, Hawkins KA, Gueorguieva R, . Transcranial magnetic stimulation of left temporoparietal cortex and medication-resistant auditory hallucinations. Arch Gen Psychiatry. 2003 Jan;60(1):49–56. PMID: 12511172. Intervention not included in review.12511172
Hoffmann H, Jackel D, Glauser S, . Long-term effectiveness of supported employment: 5-year follow-up of a randomized controlled trial. Am J Psychiatry. 2014 Nov 1;171(11):1183–90. PMID: 25124692. Population ineligible for review.25124692
Hogan M. Updated schizophrenia PORT treatment recommendations: a commentary. Schizophr Bull. 2010;36(1):104–6. Not a study.19892820
Hogarty GE, Anderson CM. Medication, family psychoeducation, and social skills training: first year relapse results of a controlled study. Psychopharmacol Bull. 1986;22(3):860–2. PMID: 2879309. Intervention not included in review.2879309
Hogarty GE, Anderson CM, Reiss DJ, . Family psychoeducation, social skills training, and maintenance chemotherapy in the aftercare treatment of schizophrenia: I. One-year effects of a controlled study on relapse and expressed emotion. Arch Gen Psychiatry. 1986 Jul;43(7):633–42. doi: 10.1001/archpsyc.1986.01800070019003. PMID: 2872870. Comparator not included in review.2872870
Hogarty GE, Anderson CM, Reiss DJ, . Family psychoeducation, social skills training, and maintenance chemotherapy in the aftercare treatment of schizophrenia: II. Two-year effects of a controlled study on relapse and adjustment. Arch Gen Psychiatry. 1991 Apr;48(4):340–7. doi: 10.1001/archpsyc.1991.01810280056008. PMID: 1672589. Intervention not included in review.1672589
Hogarty GE, Flesher S, Ulrich R, . Cognitive enhancement therapy for schizophrenia: effects of a 2-year randomized trial on cognition and behavior. Arch Gen Psychiatry. 2004 Sep;61(9):866–76. PMID: 15351765. Study covered in a systematic review.15351765
Hogarty GE, Goldberg SC. Drug and sociotherapy in the aftercare of schizophrenic patients. One-year relapse rates. Arch Gen Psychiatry. 1973 Jan;28(1):54–64. PMID: 4345664. Interventions evaluated in a single study.4345664
Hogarty GE, Goldberg SC, Schooler NR. Drug and sociotherapy in the aftercare of schizophrenic patients. III. adjustment of nonrelapsed patients. Arch Gen Psychiatry. 1974 Nov;31(5):609–18. PMID: 4374156. Interventions evaluated in a single study.4374156
Hogarty GE, Goldberg SC, Schooler NR, . Drug and sociotherapy in the aftercare of schizophrenic patients. II. two-year relapse rates. Arch Gen Psychiatry. 1974 Nov;31(5):603–8. PMID: 4374155. Interventions evaluated in a single study.4374155
Hogarty GE, Greenwald D, Ulrich RF, . Three-year trials of personal therapy among schizophrenic patients living with or independent of family, II: effects on adjustment of patients. Am J Psychiatry. 1997 Nov;154(11):1514–24. PMID: 9356558. Comparator not included in review.9356558
Hogarty GE, Greenwald DP, Eack SM. Durability and mechanism of effects of cognitive enhancement therapy. Psychiatr Serv. 2006 Dec;57(12):1751–7. PMID: 17158490. Study covered in a systematic review.17158490
Hogarty GE, Kornblith SJ, Greenwald D, . Three-year trials of personal therapy among schizophrenic patients living with or independent of family, I: description of study and effects on relapse rates. Am J Psychiatry. 1997 Nov;154(11):1504–13. PMID: 9356557. Comparator not included in review.9356557
Holloway F, Carson J. Intensive case management for the severely mentally ill. Controlled trial. Br J Psychiatry. 1998 Jan;172:19–22. PMID: 9534826. Study covered in a systematic review.9534826
Holzer L, Urben S, Passini CM, . A randomized controlled trial of the effectiveness of computer-assisted cognitive remediation (CACR) in adolescents with psychosis or at high risk of psychosis. Behav Cogn Psychother. 2014 Jul;42(4):421–34. doi: 10.1017/s1352465813000313. PMID: 23631951. Population ineligible for review.23631951
Horan WP, Kern RS, Shokat-Fadai K, . Social cognitive skills training in schizophrenia: an initial efficacy study of stabilized outpatients. Schizophr Res. 2009 Jan;107(1):47–54. doi: 10.1016/j.schres.2008.09.006. PMID: 18930378. Inadequate duration (<12 weeks).18930378
Horan WP, Kern RS, Tripp C, . Efficacy and specificity of social cognitive skills training for outpatients with psychotic disorders. J Psychiatr Res. 2011 Aug;45(8):1113–22. doi: 10.1016/j.jpsychires.2011.01.015. PMID: 21377168. Study design not included in review.21377168
Hornung W, Kieserg A, Feldmann R, . Psychoeducational training for schizophrenic patients: background, procedure and empirical findings. Patient Educ Couns. 1996 Dec;29(3):257–68. doi: 10.1016/S0738-3991%2896%2900918-4. PMID: 9006241. Study covered in a systematic review.9006241
Hornung WP, Feldmann R, Klingberg S, . Long-term effects of a psychoeducational psychotherapeutic intervention for schizophrenic outpatients and their key-persons--results of a five-year follow-up. Eur Arch Psychiatry Clin Neurosci. 1999;249(3):162–7. PMID: 10433131. Intervention not included in review.10433131
Hosaini H, Akbari M, Mohamadi J. Effects of cognitive-behavioral therapy on positive symptoms of schizophrenia. J Mazandaran Univ of Med Sci. 2013;23(107):28–37. Not English language.
Hovington CL, McGirr A, Lepage M, . Repetitive transcranial magnetic stimulation (rTMS) for treating major depression and schizophrenia: a systematic review of recent meta-analyses. Ann Med. 2013 Jun;45(4):308–21. doi: 10.3109/07853890.2013.783993. PMID: 23687987. Intervention not included in review.23687987
Howard LM, Heslin M, Leese M, . Supported employment: randomised controlled trial. Br J Psychiatry. 2010 May;196(5):404–11. doi: 10.1192/bjp.bp.108.061465. PMID: 20435968. Study covered in a systematic review.20435968
Hu S, Yao M, Peterson BS, . A randomized, 12-week study of the effects of extended-release paliperidone (paliperidone ER) and olanzapine on metabolic profile, weight, insulin resistance, and beta-cell function in schizophrenic patients. Psychopharmacology (Berl). 2013 Nov;230(1):3–13. doi: 10.1007/s00213-013-3073-1. PMID: 23559220. Setting ineligible for review (i.e., inpatient only).23559220
Hui CL, Chang WC, Chan SK, . Early intervention and evaluation for adult-onset psychosis: the JCEP study rationale and design. Early Interv Psychiatry. 2014 Aug;8(3):261–8. doi: 10.1111/eip.12034. PMID: 23445124. Not a study.23445124
Hui CL, Wong GH, Tang JY, . Predicting 1-year risk for relapse in patients who have discontinued or continued quetiapine after remission from first-episode psychosis. Schizophr Res. 2013 Oct;150(1):297–302. PMID: 23993865 Intervention not included in review.23993865
Hutton P, Wood L, Taylor PJ, . Cognitive behavioural therapy for psychosis: rationale and protocol for a systematic review and meta-analysis. Psychosis. 2014 Jul;6(3):220–30. doi: 10.1080/17522439.2013.825005. Not a study.
Iancu SC, Hoogendoorn AW, Zweekhorst MB, . Farm-based interventions for people with mental disorders: a systematic review of literature. Disabil Rehabil. 2015;37(5):379–88. doi: 10.3109/09638288.2014.932441. PMID: 24963943. Intervention not included in review.24963943
Ishigooka J, Nakagome K, Ohmori T, . Japan useful medication program for schizophrenia (JUMPs)-long-term study on discontinuation rate, resolution and remission, and improvement in social functioning rate associated with atypical antipsychotic medications in patients with schizophrenia. BMC Psychiatry. 2013;13:243. doi: 10.1186/1471-244X-13-243. PMID: 24090047. Not a study.24090047
Issakidis C, Sanderson K, Teesson M, . Intensive case management in Australia: a randomized controlled trial. Acta Psychiatr Scand. 1999 May;99(5):360–7. doi: 10.1111/j.1600-0447.1999.tb07242.x. PMID: 10353452. Comparator not included in review.10353452
Jenner JA, Nienhuis FJ, van de Willige G, . “Hitting” voices of schizophrenia patients may lastingly reduce persistent auditory hallucinations and their burden: 18-month outcome of a randomized controlled trial. Can J Psychiatry. 2006 Mar;51(3):169–77. PMID: 16618008. Interventions evaluated in a single study.16618008
Jenner JA, Nienhuis FJ, Wiersma D, . Hallucination focused integrative treatment: a randomized controlled trial. Schizophr Bull. 2004;30(1):133–45. PMID: 15176768. Interventions evaluated in a single study.15176768
Jeppesen P, Petersen L, Thorup A, . Integrated treatment of first-episode psychosis: effect of treatment on family burden: OPUS trial. Br J Psychiatry Suppl. 2005 Aug;48:s85–90. PMID: 16055815. Outcome not included in review.16055815
Jerrell JM. Toward managed care for persons with severe mental illness: implications from a cost-effectiveness study. Health Aff (Millwood). 1995 Fall;14(3):197–207. PMID: 7498892. Study design not included in review.7498892
Jiang Y, Ni W. Health care utilization and treatment persistence associated with oral paliperidone and lurasidone in schizophrenia treatment. J Manag Care Spec Pharm. 2015 Sep;21(9):780–92. doi: 10.18553/jmcp.2015.21.9.780. PMID: 26308225. Study design not included in review.26308225
Jin H, Shih PA, Golshan S, . Comparison of longer-term safety and effectiveness of 4 atypical antipsychotics in patients over age 40: a trial using equipoise-stratified randomization. J Clin Psychiatry. 2013 Jan;74(1):10–8. doi: 10.4088/JCP.12m08001. PMID: 23218100. Population ineligible for review.23218100
Johnson DP, Penn DL, Bauer DJ, . Predictors of the therapeutic alliance in group therapy for individuals with treatment-resistant auditory hallucinations. Br J Clin Psychol. 2008 Jun;47(Pt 2):171–83. PMID: 17900393. Study design not included in review.17900393
Jones C, Campbell C, Cormac I, . Cognitive behaviour therapy versus standard care for schizophrenia (Protocol). Cochrane Database Syst Rev. 2009(4):Cd007964. doi: 10.1002/14651858.CD007964. Study design not included in review.
Jones C, Cormac I, Silveira da Mota Neto JI, . Cognitive behaviour therapy for schizophrenia. Cochrane Database Syst Rev. 2004 Oct 18(4):Cd000524. doi: 10.1002/14651858.CD000524.pub2. PMID: 15495000. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.15495000
Jorgensen P, Nordentoft M, Abel MB, . Early detection and assertive community treatment of young psychotics: the Opus Study Rationale and design of the trial. Soc Psychiatry Psychiatr Epidemiol. 2000 Jul;35(7):283–7. PMID: 11016522. Study covered in a systematic review.11016522
Jorgensen R, Licht RW, Lysaker PH, . Effects on cognitive and clinical insight with the use of guided self-determination in outpatients with schizophrenia: a randomized open trial. Eur Psychiatry. 2015 Jul;30(5):655–63. doi: 10.1016/j.eurpsy.2014.12.007. PMID: 25601635. Interventions evaluated in a single study.25601635
Juretic TG, Ruzic K, Letica-Crepulja M, . Effects of Psychosocial Day Care Programme on Quality of Life in Patients Affected with Schizophrenia - a Prospective Study. Psychiatria Danubina. 2016 Jun;28(2):111–7. PMID: 27287784. Intervention not included in review.27287784
Kahn RS. Effectiveness of antipsychotic drugs in first-episode schizophrenia and schizophreniform disorder: an open randomized clinical trial. World Psychiatry. 2009;8(Suppl 1):44–5. Study covered in a systematic review.
Kaiser W, Priebe S. The impact of the interviewer-interviewee relationship on subjective quality of life ratings in schizophrenia patients. Int J Soc Psychiatry. 1999;45(4):292–301. PMID: 10689613. Study design not included in review.10689613
Kang R, Wu Y, Li Z, . Effect of Community-Based Social Skills Training and Tai-Chi Exercise on Outcomes in Patients with Chronic Schizophrenia: A Randomized, One-Year Study. Psychopathology. 2016;49(5):345–55. doi: 10.1159/000448195. PMID: 27584836. Country not eligible.27584836
Kantrowitz JT, Sharif Z, Medalia A, . A multicenter, rater-blinded, randomized controlled study of auditory processing-focused cognitive remediation combined with open-label lurasidone in patients with schizophrenia and schizoaffective disorder. J Clin Psychiatry. 2016 Jun;77(6):799–806. doi: 10.4088/JCP.15m09998. PMID: 27035157. Intervention not included in review.27035157
Kaplan K, Salzer MS, Solomon P, . Internet peer support for individuals with psychiatric disabilities: a randomized controlled trial. Soc Sci Med. 2011 Jan;72(1):54–62. doi: 10.1016/j.socscimed.2010.09.037. PMID: 21112682. Interventions evaluated in a single study.21112682
Kaplan K, Solomon P, Salzer MS, . Assessing an internet-based parenting intervention for mothers with a serious mental illness: a randomized controlled trial. Psychiatr Rehabil J. 2014 Sep;37(3):222–31. doi: 10.1037/prj0000080. PMID: 24978623. Outcome not included in review.24978623
Kasckow J, Felmet K, Appelt C, . Telepsychiatry in the assessment and treatment of schizophrenia. Clin Schizophr Relat Psychoses. 2014 Apr;8(1):21–7A. doi: 10.3371/CSRP.KAFE.021513. PMID: 23428781. Intervention not included in review.23428781
Kasper S, Montagnani G, Trespi G, . Treatment of depressive symptoms in patients with schizophrenia: a randomized, open-label, parallel-group, flexible-dose subgroup analysis of patients treated with extended-release quetiapine fumarate or risperidone. Int Clin Psychopharmacol. 2015 Jan;30(1):14–22. doi: 10.1097/YIC.0000000000000053. PMID: 25356632. Outcome not included in review.25356632
Kastner D, Buchtemann D, Warnke I, . Clinical and functional outcome of assertive outreach for patients with schizophrenic disorder: results of a quasi-experimental controlled trial. Eur Psychiatry. 2015 Sep;30(6):736–42. doi: 10.1016/j.eurpsy.2015.04.003. PMID: 26003931. Study design not included in review.26003931
Kawanishi C, Aruga T, Ishizuka N, . Assertive case management versus enhanced usual care for people with mental health problems who had attempted suicide and were admitted to hospital emergency departments in Japan (ACTION-J): a multicentre, randomised controlled trial. Lancet Psychiatry. 2014;1(3):193–201. PMID: 26360731. Population ineligible for review.26360731
Keefe R, Hufford M, Davis V, . Who responds best to cognitive enhancement in schizophrenia? Age and diurnal variation effects. Schizophr bull. 2013;39(21). Not a study.
Keefe RS, Fox KH, Harvey PD, . Characteristics of the MATRICS Consensus Cognitive Battery in a 29-site antipsychotic schizophrenia clinical trial. Schizophr Res. 2011 Feb;125(2–3):161–8. doi: 10.1016/j.schres.2010.09.015. PMID: 21075600. Intervention not included in review.21075600
Keefe RS, Seidman LJ, Christensen BK, . Comparative effect of atypical and conventional antipsychotic drugs on neurocognition in first-episode psychosis: a randomized, double-blind trial of olanzapine versus low doses of haloperidol. Am J Psychiatry. 2004 Jun;161(6):985–95. PMID: 15169686. Study covered in a systematic review.15169686
Keefe RS, Sweeney JA, Gu H, . Effects of olanzapine, quetiapine, and risperidone on neurocognitive function in early psychosis: a randomized, double-blind 52-week comparison. Am J Psychiatry. 2007 Jul;164(7):1061–71. PMID: 17606658. Study covered in a systematic review.17606658
Keefe RS, Vinogradov S, Medalia A, . Feasibility and pilot efficacy results from the multisite cognitive remediation in the schizophrenia trials network (CRSTN) randomized controlled trial. J Clin Psychiatry. 2012 Jul;73(7):1016–22. doi: 10.4088/JCP.11m07100. PMID: 22687548. Sample size too small (<50).22687548
Keith SJ, Bellack A, Frances A, . The influence of diagnosis and family treatment on acute treatment response and short term outcome in schizophrenia. Treatment strategies in schizophrenia collaborative study group. Psychopharmacol Bull. 1989;25(3):336–9. PMID: 2697007. Study design not included in review.2697007
Kelly DL, Conley RR. A randomized double-blind 12-week study of quetiapine, risperidone or fluphenazine on sexual functioning in people with schizophrenia. Psychoneuroendocrinology. 2006 Apr;31(3):340–6. PMID: 16198059. Study covered in a systematic review.16198059
Kern RS, Green MF, Cornblatt BA, . The neurocognitive effects of aripiprazole: an open-label comparison with olanzapine. Psychopharmacology. 2006 Aug;187(3):312–20. PMID: 16810506. Outcome not included in review.16810506
Kern RS, Green MF, Mintz J, . Does ‘errorless learning’ compensate for neurocognitive impairments in the work rehabilitation of persons with schizophrenia? Psychol Med. 2003 Apr;33(3):433–42. PMID: 12701664. Comparator not included in review.12701664
Kern RS, Liberman RP, Becker DR, . Errorless learning for training individuals with schizophrenia at a community mental health setting providing work experience. Schizophr Bull. 2009;35(4):807–15. PMID: 18326529. Sample size too small (<50).18326529
Kern RS, Liberman RP, Kopelowicz A, . Applications of errorless learning for improving work performance in persons with schizophrenia. Am J Psychiatry. 2002 Nov;159(11):1921–6. PMID: 12411229. Outcome not included in review.12411229
Kerwin R, Millet B, Herman E, . A multicentre, randomized, naturalistic, open-label study between aripiprazole and standard of care in the management of community-treated schizophrenic patients Schizophrenia Trial of Aripiprazole: (STAR) study. Eur Psychiatry. 2007 Oct;22(7):433–43. PMID: 17555947. Study covered in a systematic review.17555947
Khaleghparast S, Ghanbari B, Kahani S, . The effectiveness of discharge planning on the knowledge, clinical symptoms and hospitalisation frequency of persons with schizophrenia: a longitudinal study in two hospitals in Tehran, Iran. J Clin Nurs. 2014 Aug;23(15–16):2215–22. doi: 10.1111/jocn.12499. PMID: 24329909. Study design not included in review.24329909
Kho KH, Blansjaar BA, de Vries S, . Electroconvulsive therapy for the treatment of clozapine nonresponders suffering from schizophrenia--an open label study. Eur Arch Psychiatry Clin Neurosci. 2004 Dec;254(6):372–9. PMID: 15538604. Study design not included in review.15538604
Khoury B, Lecomte T, Gaudiano BA, . Mindfulness interventions for psychosis: a meta-analysis. Schizophr Res. 2013 Oct;150(1):176–84. doi: 10.1016/j.schres.2013.07.055. PMID: 23954146. Systematic review/meta-analysis used as a source document to identify individual studies.23954146
Khushu A, Powney MJ. Haloperidol for long-term aggression in psychosis. Cochrane Database of Systematic Reviews. 2016 11 27;11:CD009830. doi: 10.1002/14651858.CD009830.pub2. PMID: 27889922. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.27889922
Kidd SA, Herman Y, Barbic S, . Testing a modification of cognitive adaptation training: streamlining the model for broader implementation. Schizophr Res. 2014 Jun;156(1):46–50. doi: 10.1016/j.schres.2014.03.026. PMID: 24794880. Study design not included in review.24794880
Kidd SA, Kaur J, Virdee G, . Cognitive remediation for individuals with psychosis in a supported education setting: a randomized controlled trial. Schizophr Res. 2014 Aug;157(1–3):90–8. doi: 10.1016/j.schres.2014.05.007. PMID: 24893903. Study covered in a systematic review.24893903
Killackey E, Jackson HJ, McGorry PD. Vocational intervention in first-episode psychosis: individual placement and support v. treatment as usual. Br J Psychiatry. 2008 Aug;193(2):114–20. PMID: 18669993. Study covered in a systematic review.18669993
Kim SH, Han DH, Joo SY, . The effect of dopamine partial agonists on the nicotine dependency in patients with schizophrenia. Hum Psychopharmacol. 2010 Mar;25(2):187–90. doi: 10.1002/hup.1089. PMID: 20033907. Outcome not included in review.20033907
Kin Wong K, Chiu R, Tang B, . A randomized controlled trial of a supported employment program for persons with long-term mental illness in Hong Kong. Psychiatr Serv. 2008 Jan;59(1):84–90. doi: 10.1176/ps.2008.59.1.84. PMID: 18182544. Study covered in a systematic review.18182544
Kinon BJ, Kollack-Walker S, Jeste D, . Incidence of tardive dyskinesia in older adult patients treated with olanzapine or conventional antipsychotics. J Geriatr Psychiatry Neurol. 2015 Mar;28(1):67–79. doi: 10.1177/0891988714541867. PMID: 25009161. Population ineligible for review.25009161
Kinon BJ, Noordsy DL, Liu-Seifert H, . Randomized, double-blind 6-month comparison of olanzapine and quetiapine in patients with schizophrenia or schizoaffective disorder with prominent negative symptoms and poor functioning. J Clin Psychopharmacol. 2006 Oct;26(5):453–61. PMID: 16974184. Study covered in a systematic review.16974184
Kishimoto T, Robenzadeh A, Leucht C, . Long-acting injectable vs oral antipsychotics for relapse prevention in schizophrenia: a meta-analysis of randomized trials. Schizophr Bull. 2014 Jan;40(1):192–213. doi: 10.1093/schbul/sbs150. PMID: 23256986. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23256986
Klieser E, Strauss WH, Lemmer W. The tolerability and efficacy of the atypical neuroleptic remoxipride compared with clozapine and haloperidol in acute schizophrenia. Acta psychiatrica Scandinavica. Supplementum. 1994;380:68–73. PMID: 8048341. Study covered in a systematic review.8048341
Klingberg S, Herrlich J, Wiedemann G, . Adverse effects of cognitive behavioral therapy and cognitive remediation in schizophrenia: results of the treatment of negative symptoms study. J Nerv Ment Dis. 2012 Jul;200(7):569–76. doi: 10.1097/NMD.0b013e31825bfa1d. PMID: 22759932. Comparator not included in review.22759932
Klingberg S, Wittorf A, Fischer A, . Evaluation of a cognitive behaviourally oriented service for relapse prevention in schizophrenia. Acta Psychiatr Scand. 2010 May;121(5):340–50. doi: 10.1111/j.1600-0447.2009.01479.x. PMID: 19895624. Setting ineligible for review (i.e., inpatient only).19895624
Klingberg S, Wittorf A, Herrlich J, . Cognitive behavioural treatment of negative symptoms in schizophrenia patients: study design of the TONES study, feasibility and safety of treatment. Eur Arch Psychiatry Clin Neurosci. 2009 Nov;259 Suppl 2:S149–54. doi: 10.1007/s00406-009-0047-8. PMID: 19876673. Study covered in a systematic review.19876673
Klingberg S, Wolwer W, Engel C, . Negative symptoms of schizophrenia as primary target of cognitive behavioral therapy: results of the randomized clinical TONES study. Schizophr Bull. 2011 Sep;37 Suppl 2:S98–110. doi: 10.1093/schbul/sbr073. PMID: 21860053. Study covered in a systematic review.21860053
Kluwe-Schiavon B, Sanvicente-Vieira B, Kristensen CH, . Executive functions rehabilitation for schizophrenia: a critical systematic review. J Psychiatr Res. 2013 Jan;47(1):91–104. doi: 10.1016/j.jpsychires.2012.10.001. PMID: 23122645. Outcome not included in review.23122645
Knapp MR, Marks IM, Wolstenholme J, . Home-based versus hospital-based care for serious mental illness: controlled cost-effectiveness study over four years. Br J Psychiatry. 1998 Jun;172(6):506–12. doi: 10.1192/bjp.172.6.506. PMID: 9828991. Comparator not included in review.9828991
Komatsu H, Sekine Y, Okamura N, . Effectiveness of information technology aided relapse prevention programme in schizophrenia excluding the effect of user adherence: a randomized controlled trial. Schizophr Res. 2013 Oct;150(1):240–4. doi: 10.1016/j.schres.2013.08.007. PMID: 23998952. Intervention not included in review.23998952
Koolaee AK, Etemadi A. The outcome of family interventions for the mothers of schizophrenia patients in Iran. Int J Soc Psychiatry. 2010 Nov;56(6):634–46. doi: 10.1177/0020764009344144. PMID: 19734180. Country not eligible.19734180
Kopelowicz A. Adapting social skills training for Latinos with schizophrenia. Int Rev Psychiatry. 1998 Feb;10(1):47–50. doi: 10.1080/09540269875087. Not a study.
Kopelowicz A, Zarate R, Gonzalez Smith V, . Disease management in Latinos with schizophrenia: a family-assisted, skills training approach. Schizophr Bull. 2003;29(2):211–27. PMID: 14552498. Study covered in a systematic review.14552498
Krabbendam L, Aleman A. Cognitive rehabilitation in schizophrenia: a quantitative analysis of controlled studies. Psychopharmacology (Berl). 2003 Sep;169(3–4):376–82. PMID: 12545330. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.12545330
Krakowski M, Czobor P. Cholesterol and cognition in schizophrenia: a double-blind study of patients randomized to clozapine, olanzapine and haloperidol. Schizophr Res. 2011 Aug;130(1–3):27–33. PMID: 21549568. Outcome not included in review.21549568
Krakowski MI, Czobor P, Nolan KA. Atypical antipsychotics, neurocognitive deficits, and aggression in schizophrenic patients. J Clin Psychopharmacol. 2008 Oct;28(5):485–93. PMID: 18794642. Outcome not included in review.18794642
Krakvik B, Grawe RW, Hagen R, . Cognitive behaviour therapy for psychotic symptoms: a randomized controlled effectiveness trial. Behav Cogn Psychother. 2013 Oct;41(5):511–24. doi: 10.1017/S1352465813000258. PMID: 23635846. Study covered in a systematic review.23635846
Kreyenbuhl J, Buchanan RW, Dickerson FB, . The Schizophrenia Patient Outcomes Research Team (PORT): updated treatment recommendations 2009. Schizophr Res. 2010 Jan;36(1):94–103. doi: 10.1093/schbul/sbp130. PMID: 19955388. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.19955388
Kuipers E, Holloway F, Rabe-Hesketh S, . An RCT of early intervention in psychosis: Croydon Outreach and Assertive Support Team (COAST). Soc Psychiatry Psychiatr Epidemiol. 2004 May;39(5):358–63. doi: 10.1007/s00127-004-0754-4. PMID: 15133591. Interventions evaluated in a single study.15133591
Kumar A, Narayan M, Raja H, . Asenapine versus typical antipsychotics for schizophrenia (Protocol). Cochrane Database Syst Rev. 2012(11):Cd010230. doi: 10.1002/14651858.CD010230. Not a study.
Kuokkanen R, Lappalainen R, Repo-Tiihonen E, . Metacognitive group training for forensic and dangerous non-forensic patients with schizophrenia: a randomised controlled feasibility trial. Crim Behav Ment Health. 2014 Dec;24(5):345–57. doi: 10.1002/cbm.1905. PMID: 24619628. Intervention not included in review.24619628
Kurtz MM, Mueser KT. A meta-analysis of controlled research on social skills training for schizophrenia. J Consult Clin Psychol. 2008 Jun;76(3):491–504. doi: 10.1037/0022-006X.76.3.491. PMID: 18540742. Systematic review/meta-analysis used as a source document to identify individual studies.18540742
Kurtz MM, Mueser KT, Thime WR, . Social skills training and computer-assisted cognitive remediation in schizophrenia. Schizophr Res. 2015 Mar;162(1–3):35–41. doi: 10.1016/j.schres.2015.01.020. PMID: 25640526. Comparator not included in review.25640526
Kurtz MM, Richardson CL. Social cognitive training for schizophrenia: a meta-analytic investigation of controlled research. Schizophr Bull. 2012 Sep;38(5):1092–104. doi: 10.1093/schbul/sbr036. PMID: 21525166. Study design not included in review.21525166
Kurtz MM, Seltzer JC, Fujimoto M, . Predictors of change in life skills in schizophrenia after cognitive remediation. Schizophr Res. 2009 Feb;107(2–3):267–74. doi: 10.1016/j.schres.2008.10.014. PMID: 19006657. Study design not included in review.19006657
Kurtz MM, Seltzer JC, Shagan DS, . Computer-assisted cognitive remediation in schizophrenia: what is the active ingredient? Schizophr Res. 2007 Jan;89(1–3):251–60. PMID: 17070671. Outcome not included in review.17070671
Lally J, Tully J, Robertson D, . Augmentation of clozapine with electroconvulsive therapy in treatment resistant schizophrenia: A systematic review and meta-analysis. Schizophr Res. 2016 Mar;171(1–3):215–24. doi: 10.1016/j.schres.2016.01.024. PMID: 26827129. Intervention not included in review.26827129
Lam KCK, Ho CPS, Wa JC, . Metacognitive training (MCT) for schizophrenia improves cognitive insight: a randomized controlled trial in a Chinese sample with schizophrenia spectrum disorders. Behav Res Ther. 2015;64:38–42. PMID: 25513971. Intervention not included in review.25513971
Lambert M, Bock T, Schottle D, . Assertive community treatment as part of integrated care versus standard care: a 12-month trial in patients with first- and multiple-episode schizophrenia spectrum disorders treated with quetiapine immediate release (ACCESS trial). J Clin Psychiatry. 2010 Oct;71(10):1313–23. doi: 10.4088/JCP.09m05113yel. PMID: 20361911. Study design not included in review.20361911
Laties AM, Flach AJ, Baldycheva I, . Cataractogenic potential of quetiapine versus risperidone in the long-term treatment of patients with schizophrenia or schizoaffective disorder: a randomized, open-label, ophthalmologist-masked, flexible-dose, non-inferiority trial. J Psychopharmacol. 2015 Jan;29(1):69–79. doi: 10.1177/0269881114553253. PMID: 25315830. Outcome not included in review.25315830
Latimer EA, Lecomte T, Becker DR, . Generalisability of the individual placement and support model of supported employment: results of a Canadian randomised controlled trial. Br J Psychiatry. 2006 Jul;189:65–73. doi: 10.1192/bjp.bp.105.012641. PMID: 16816308. Study covered in a systematic review.16816308
Lawrence R, Bradshaw T, Mairs H. Group cognitive behavioural therapy for schizophrenia: a systematic review of the literature. J Psychiatr Ment Health Nurs. 2006 Dec;13(6):673–81. PMID: 17087669. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.17087669
Lecardeur L, Stip E, Giguere M, . Effects of cognitive remediation therapies on psychotic symptoms and cognitive complaints in patients with schizophrenia and related disorders: a randomized study. Schizophr Res. 2009 Jun;111(1–3):153–8. doi: 10.1016/j.schres.2009.03.029. PMID: 19395240. Study covered in a systematic review.19395240
Lecomte T, Cyr M, Lesage AD, . Efficacy of a self-esteem module in the empowerment of individuals with schizophrenia. J Nerv Ment Dis. 1999 Jul;187(7):406–13. PMID: 10426460. Interventions evaluated in a single study.10426460
Lecomte T, Leclerc C, Wykes T. Group CBT for early psychosis--are there still benefits one year later? Int J Group Psychother. 2012 Apr;62(2):309–21. doi: 10.1521/ijgp.2012.62.2.309. PMID: 22468576. Study covered in a systematic review.22468576
Lee MS, Shin BC, Ronan P, . Acupuncture for schizophrenia: a systematic review and meta-analysis. Int J Clin Pract. 2009 Nov;63(11):1622–33. doi: 10.1111/j.1742-1241.2009.02167.x. PMID: 19832819. Intervention not included in review.19832819
Lee RS, Redoblado-Hodge MA, Naismith SL, . Cognitive remediation improves memory and psychosocial functioning in first-episode psychiatric out-patients. Psychol Med. 2013 Jun;43(6):1161–73. doi: 10.1017/s0033291712002127. PMID: 23237010. Study covered in a systematic review.23237010
Lee SH, Choi TK, Suh S, . Effectiveness of a psychosocial intervention for relapse prevention in patients with schizophrenia receiving risperidone via long-acting injection. Psychiatry Res. 2010 Feb 28;175(3):195–9. doi: 10.1016/j.psychres.2008.06.043. PMID: 20022120. Study design not included in review.20022120
Lee WK. Effectiveness of computerized cognitive rehabilitation training on symptomatological, neuropsychological and work function in patients with schizophrenia. Asia Pac Psychiatry. 2013 Jun;5(2):90–100. doi: 10.1111/appy.12070. PMID: 23857809. Setting ineligible for review (i.e., inpatient only).23857809
Leff J, Berkowitz R, Shavit N, . A trial of family therapy v. a relatives group for schizophrenia. Br J Psychiatry. 1989;154:58–66. PMID: 2673479. Study covered in a systematic review.2673479
Leff J, Berkowitz R, Shavit N, . A trial of family therapy versus a relatives’ group for schizophrenia. Two-year follow-up. Br J Psychiatry. 1990;157(OCT.):571–7. PMID: 2131140. Study covered in a systematic review.2131140
Leff J, Kuipers L, Berkowitz R, . A controlled trial of social intervention in the families of schizophrenic patients. Br J Psychiatry. 1982 Aug;141:121–34. doi: 10.1192/bjp.141.2.121. PMID: 7116051. Study covered in a systematic review.7116051
Leff JP, Kuipers L, Berkowitz R, . A controlled trial of social intervention in the families of schizophrenic patients: two year follow-up. Br J Psychiatry. 1985 Jun;146:594–600. doi: 10.1192/bjp.146.6.594. PMID: 3893605. Study covered in a systematic review.3893605
Lehman AF, Dixon LB, DeForge BR, . Assertive community treatment for homeless persons with schizophrenia and other chronic mental disorders. Schizophr Res. 1995 4//;15(1–2):218–9. doi: 10.1016/0920-9964(95)95671-U. Not a study.7756198
Lehman AF, Dixon LB, Kernan E, . A randomized trial of assertive community treatment for homeless persons with severe mental illness. Arch Gen Psychiatry. 1997 Nov;54(11):1038–43. PMID: 9366661. Study covered in a systematic review.9366661
Lehman AF, Goldberg R, Dixon LB, . Improving employment outcomes for persons with severe mental illnesses. Archives of General Psychiatry. 2002 Feb;59(2):165–72. PMID: 11825138. Study covered in a systematic review.11825138
Lenior ME, Dingemans PM, Linszen DH, . Social functioning and the course of early-onset schizophrenia: five-year follow-up of a psychosocial intervention. Br J Psychiatry. 2001;179:53–8. PMID: 11435269. Study covered in a systematic review.11435269
Lester H, Allan T, Wilson S, . A cluster randomised controlled trial of patient-held medical records for people with schizophrenia receiving shared care. Br J Gen Pract. 2003 Mar;53(488):197–203. PMID: 14694695. Interventions evaluated in a single study.14694695
Leucht S, Cipriani A, Spineli L, . Comparative efficacy and tolerability of 15 antipsychotic drugs in schizophrenia: a multiple-treatments meta-analysis. Lancet. 2013 Sep 14;382(9896):951–62. doi: 10.1016/S0140-6736(13)60733-3. PMID: 23810019. Study covered in a systematic review.23810019
Levitt AJ, Mueser KT, Degenova J, . Randomized controlled trial of illness management and recovery in multiple-unit supportive housing. Psychiatr Serv. 2009 Dec;60(12):1629–36. doi: 10.1176/ps.2009.60.12.1629. PMID: 19952153. Population ineligible for review.19952153
Li F, Wang M. A behavioral training programme for chronic schizophrenic patients: a three-month randomised controlled trial in Beijing. Br J Psychiatry. 1994 Aug;165(Suppl 24):32–7. PMID: 7946229. Setting ineligible for review (i.e., inpatient only).7946229
Li Z, Arthur D. Family education for people with schizophrenia in Beijing, China: randomised controlled trial. Br J Psychiatry. 2005;187:339–45. PMID: 16199793. Country not eligible.16199793
Li ZJ, Guo ZH, Wang N, . Cognitive-behavioural therapy for patients with schizophrenia: a multicentre randomized controlled trial in Beijing, China. Psychol Med. 2015 Jul;45(9):1893–905. doi: 10.1017/S0033291714002992. PMID: 25532460. Country not eligible.25532460
Liberman RP, Wallace CJ, Blackwell G, . Skills training versus psychosocial occupational therapy for persons with persistent schizophrenia. Am J Psychiatry. 1998 Aug;155(8):1087–91. PMID: 9699698. Comparator not included in review.9699698
Lieberman JA, Tollefson G, Tohen M, . Comparative efficacy and safety of atypical and conventional antipsychotic drugs in first-episode psychosis: a randomized, double-blind trial of olanzapine versus haloperidol. Am J Psychiatry. 2003 Aug;160(8):1396–404. PMID: 12900300. Study covered in a systematic review.12900300
Lieberman JA, Tollefson GD, Charles C, . Antipsychotic drug effects on brain morphology in first-episode psychosis. Arch Gen Psychiatry. 2005 Apr;62(4):361–70. PMID: 15809403. Outcome not included in review.15809403
Lincoln T. A comment on Lynch, et al. (2009): cognitive behavioural therapy for major psychiatric disorder: does it really work? A meta-analytical review of well-controlled trials. Psychol Med. 2010 May;40(5):877–80. doi: 10.1017/S0033291709991838. PMID: 19917145. Not a study.19917145
Lincoln TM, Wilhelm K, Nestoriuc Y. Effectiveness of psychoeducation for relapse, symptoms, knowledge, adherence and functioning in psychotic disorders: a metaanalysis (provisional abstract). Schizophr Res. 2007;96:232–45. doi: 10.1016/j.schres.2007.07.022. PMID: 17826034. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.17826034
Lindberg D. A controlled study of 5 years’ treatment with psychotherapy in combination with depot neuroleptics in schizophrenia. II. Personality changes measured by ten selected Rorschach variables. Acta Psychiatr Scand Suppl. 1981;289:56–66. PMID: 6110316. Outcome not included in review.6110316
Lindenmayer JP, McGurk SR, Khan A, . Improving social cognition in schizophrenia: a pilot intervention combining computerized social cognition training with cognitive remediation. Schizophr Bull. 2013 May;39(3):507–17. doi: 10.1093/schbul/sbs120. PMID: 23125396. Comparator not included in review.23125396
Lindenmayer JP, McGurk SR, Mueser KT, . A randomized controlled trial of cognitive remediation among inpatients with persistent mental illness. Psychiatr Serv. 2008 Mar;59(3):241–7. doi: 10.1176/appi.ps.59.3.241. PMID: 18308903. Setting ineligible for review (i.e., inpatient only).18308903
Lindenmayer J-P, Khan A, Lachman H, . COMT genotype and response to cognitive remediation in schizophrenia. Schizophr Res. 2015 Oct;168(1–2):279–84. doi: 10.1016/j.schres.2015.07.037. PMID: 26255563. Outcome not included in review.26255563
Ling Young S, Taylor M, Lawrie SM. “First do no harm.” A systematic review of the prevalence and management of antipsychotic adverse effects. J Psychopharmacol. 2015 Apr;29(4):353–62. doi: 10.1177/0269881114562090. PMID: 25516373. Study design not included in review.25516373
Linszen D, Dingemans P, Van der Does JW, . Treatment, expressed emotion and relapse in recent onset schizophrenic disorders. Psychol Med. 1996 Mar;26(2):333–42. PMID: 8685289. Setting ineligible for review (i.e., inpatient only).8685289
Liu CC, Demjaha A. Antipsychotic interventions in prodromal psychosis: safety issues. CNS Drugs. 2013 Mar;27(3):197–205. doi: 10.1007/s40263-013-0046-1. PMID: 23436256. Not a study.23436256
Liu Y, Bo L, Sampson S, . Horticultural therapy for schizophrenia. Cochrane Database Syst Rev. 2014 May 19(5):Cd009413. doi: 10.1002/14651858.CD009413.pub2. PMID: 24842458. Inadequate duration (<12 weeks).24842458
Liu-Seifert H, Ascher-Svanum H, Osuntokun O, . Change in level of productivity in the treatment of schizophrenia with olanzapine or other antipsychotics. BMC Psychiatry. 2011;11 PMID: 21586165. Study design not included in review.21586165
Ljubin T, Milas DZ, Mimica N, . A preliminary study of the comparative effects of olanzapine and fluphenazine on cognition in schizophrenic patients. Hum Psychopharmacol. 2000;15(7):513–9. PMID: 12404620. Study covered in a systematic review.12404620
Lloyd-Evans B, Mayo-Wilson E, Harrison B, . A systematic review and meta-analysis of randomised controlled trials of peer support for people with severe mental illness. BMC Psychiatry. 2014 Feb;14doi: 10.1186/1471-244X-14-39. PMID: 24528545. Intervention not included in review.24443820
Loebel A, Cucchiaro J, Sarma K, . Efficacy and safety of lurasidone 80 mg/day and 160 mg/day in the treatment of schizophrenia: a randomized, double-blind, placebo- and active-controlled trial. Schizophr Res. 2013 Apr;145(1–3):101–9. doi: 10.1016/j.schres.2013.01.009. PMID: 23415311. Inadequate duration (<12 weeks).23415311
Loebel A, Silva R, Goldman R, . Lurasidone dose escalation in early nonresponding patients with schizophrenia: A randomized, placebo-controlled study. J Clin Psychiatry. 2016 Dec;77(12):1672–80. doi: 10.4088/JCP.16m10698. PMID: 27454547. Inadequate duration (<12 weeks).27454547
Loebel AD, Siu CO, Cucchiaro JB, . Daytime sleepiness associated with lurasidone and quetiapine XR: results from a randomized double-blind, placebo-controlled trial in patients with schizophrenia. CNS Spectr. 2014 Apr;19(2):197–205. PMID: 24330860. Study covered in a systematic review.24330860
Loh SY, Abdullah A, Abu Bakar AK, . Structured walking and chronic institutionalized schizophrenia inmates: a pilot RCT study on quality of life. Glob J Health Sci. 2016 Jan;8(1):238–48. doi: 10.5539/gjhs.v8n1p238. PMID: 26234968. Intervention not included in review.26234968
Lu H, Li Y, Li F, . Randomized controlled trial on adjunctive cognitive remediation therapy for chronically hospitalized patients with schizophrenia. Shanghai Arch Psychiatry. 2012 Jun;24(3):149–54. PMID: 25324619. Setting ineligible for review (i.e., inpatient only).25324619
Lu SF, Lo CH, Sung HC, . Effects of group music intervention on psychiatric symptoms and depression in patient with schizophrenia. Complement Ther Med. 2013 Dec;21(6):682–8. doi: 10.1016/j.ctim.2013.09.002. PMID: 24280478. Intervention not included in review.24280478
Lysaker PH, Bond G, Davis LW, . Enhanced cognitive-behavioral therapy for vocational rehabilitation in schizophrenia: effects on hope and work. J Rehabil Res Dev. 2005 Sep–Oct;42(5):673–82. PMID: 16586193. Study covered in a systematic review.16586193
Lysaker PH, Davis LW, Beattie N. Effects of cognitive behavioral therapy and vocational rehabilitation on metacognition and coping in schizophrenia. J Contemp Psychother. 2006;36(1):25–30. Outcome not included in review.
Macias C, Rodican CF, Hargreaves WA, . Supported employment outcomes of a randomized controlled trial of ACT and clubhouse models. Psychiatric services (Washington, D.C.). 2006 Oct;57(10):1406–15. PMID: CN-00572777 UPDATE. Study covered in a systematic review.
Macpherson R, Edwards TR, Chilvers R, . Twenty-four hour care for schizophrenia. Cochrane Database Syst Rev. 2009 Apr 15(2):Cd004409. doi: 10.1002/14651858.CD004409.pub2. PMID: 19370601. Comparator not included in review.19370601
Magliano L, Fiorillo A, Malangone C, . Patient functioning and family burden in a controlled, real-world trial of family psychoeducation for schizophrenia. Psychiatr Serv. 2006 Dec;57(12):1784–91. PMID: 17158495. Study covered in a systematic review.17158495
Mairs H, Bradshaw T. Life skills training in schizophrenia. Br J Occup Ther. 2004 May;67(5):217–24. doi: 10.1177/030802260406700505. Study design not included in review.
Mairs H, Lovell K, Campbell M, . Development and pilot investigation of behavioral activation for negative symptoms. Behav Modif. 2011 Sep;35(5):486–506. doi: 10.1177/0145445511411706. PMID: 21746764. Study design not included in review.21746764
Mak GKL, Li FWS, Lee PWH. A pilot study on psychological interventions with Chinese young adults with schizophrenia. Hong Kong J Psychiatr. 2007;17(1):17–23. Country not eligible.
Malakouti SK, Nojomi M, Panaghi L, . Case-management for patients with schizophrenia in Iran: a comparative study of the clinical outcomes of mental health workers and consumers’ family members as case managers. Community Ment Health J. 2009 Dec;45(6):447–52. doi: 10.1007/s10597-009-9197-4. PMID: 19415489. Study design not included in review.19415489
Malm U, Ivarsson B, Allebeck P, . Integrated care in schizophrenia: a 2-year randomized controlled study of two community-based treatment programs. Acta Psychiatr Scand. 2003 Jun;107(6):415–23. PMID: 12752017. Comparator not included in review.12752017
Malm UI, Ivarsson BA, Allebeck P. Durability of the efficacy of integrated care in schizophrenia: a five-year randomized controlled study. Psychiatr Serv. 2014 Aug 1;65(8):1054–7. doi: 10.1176/appi.ps.201300164. PMID: 24932858. Comparator not included in review.24932858
Malmberg L, Fenton M, Rathbone J. Individual psychodynamic psychotherapy and psychoanalysis for schizophrenia and severe mental illness. Cochrane Database Syst Rev. 2012 (2)PMID: 11686988. Intervention not included in review.11686988
Man DW, Law KM, Chung RC. Cognitive training for Hong Kong Chinese with schizophrenia in vocational rehabilitation. Hong Kong Med J. 2012 Dec;18 Suppl 6:18–22. PMID: 23249847. Comparator not included in review.23249847
Marder SR, Glynn SM, Wirshing WC, . Maintenance treatment of schizophrenia with risperidone or haloperidol: 2-year outcomes. Am J Psychiatry. 2003 Aug;160(8):1405–12. PMID: 12900301. Study covered in a systematic review.12900301
Marder SR, Wirshing WC, Mintz J, . Two-year outcome of social skills training and group psychotherapy for outpatients with schizophrenia. Am J Psychiatry. 1996 Dec;153(12):1585–92. PMID: 8942455. Comparator not included in review.8942455
Marshall M, Rathbone J. Early intervention for psychosis. Cochrane Database Syst Rev. 2011 Jun 15(6):Cd004718. doi: 10.1002/14651858.CD004718.pub3. PMID: 21678345. Systematic review/meta-analysis used as a source document to identify individual studies.21678345
Marshall T, Goldberg RW, Braude L, . Supported employment: assessing the evidence. Psychiatr Serv. 2014 Jan 01;65(1):16–23. doi: 10.1176/appi.ps.201300262. PMID: 24247197. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.24247197
Martin G, Costello H, Leese M, . An exploratory study of assertive community treatment for people with intellectual disability and psychiatric disorders: conceptual, clinical, and service issues. J Intellect Disabil Res. 2005 Jul;49(Pt 7):516–24. PMID: 15966959. Population ineligible for review.15966959
Martin-Carrasco M, Fernandez-Catalina P, Dominguez-Panchon AI, . A randomized trial to assess the efficacy of a psychoeducational intervention on caregiver burden in schizophrenia. Eur Psychiatry. 2016 Mar;33:9–17. doi: 10.1016/j.eurpsy.2016.01.003. PMID: 26852375. Outcome not included in review.26852375
Maslenikov NV, Mosolov SN, Smirnov NA, . Repetitive transcranial magnetic stimulation (rTMS) effects on depression, negative symptoms and cognition in schizophrenia. Brain Stimul. 2015 START: 2015 Mar 2 CONFERENCE END: 2015 Mar 4, 1st International Brain Stimulation Conference Singapore Singapore;8(2):333. Not a study.
Mastroeni A, Bellotti C, Pellegrini E, . Clinical and social outcomes five years after closing a mental hospital: a trial of cognitive behavioural interventions. Clin Pract Epidemiol Ment Health. 2005;1 (25)PMID: 16305738. Setting ineligible for review (i.e., inpatient only).16305738
Matheson SL, Green MJ, Loo C, . Quality assessment and comparison of evidence for electroconvulsive therapy and repetitive transcranial magnetic stimulation for schizophrenia: a systematic meta-review. Schizophr Res. 2010 May;118(1–3):201–10. doi: 10.1016/j.schres.2010.01.002. PMID: 20117918. Intervention not included in review.20117918
Matsuda Y, Sato S, Iwata K, . Effects of risperidone and aripiprazole on neurocognitive rehabilitation for schizophrenia. Psychiatry Clin Neurosci. 2014 Jun;68(6):425–31. PMID: 24506576. Outcome not included in review.24506576
Mausbach BT, Cardenas V, McKibbin CL, . Reducing emergency medical service use in patients with chronic psychotic disorders: results from the FAST intervention study. Behav Res Ther. 2008 Jan;46(1):145–53. PMID: 17997395. Outcome not included in review.17997395
Mavreas VG, Tomaras V, Karydi V, . Expressed emotion in families of chronic schizophrenics and its association with clinical measures. Soc Psychiatry Psychiatr Epidemiol. 1992 Jan;27(1):4–9. PMID: 1557681. Study design not included in review.1557681
May PR, Tuma AH, Dixon WJ, . Schizophrenia. A follow-up study of the results of five forms of treatment. Arch Gen Psychiatry. 1981 Jul;38(7):776–84. PMID: 6113821. Intervention not included in review.6113821
McCann E. Brief cognitive-behavioural therapy reduces hospital readmission but does not reduce overall symptoms of schizophrenia. Evid Based Ment Health. 2007;10(2):55. PMID: 17459986. Interventions evaluated in a single study.17459986
McCay E, Beanlands H, Leszcz M, . A group intervention to promote healthy self-concepts and guide recovery in first episode schizophrenia: a pilot study. Psychiatr Rehabil J. 2006;30(2):105–11. PMID: 17076053. Study design not included in review.17076053
McCay E, Beanlands H, Zipursky R, . A randomised controlled trial of a group intervention to reduce engulfment and self-stigmatisation in first episode schizophrenia. AeJAMH. 2007 Nov;6(3):1–9. doi: 10.5172/jamh.6.3.212. Outcome not included in review.
McCreadie RG, Wiles D, Grant S, . The Scottish first episode schizophrenia study. VII. Two-year follow-up. Scottish Schizophrenia Research Group. Acta Psychiatr Scand. 1989 Dec;80(6):597–602. PMID: 2694767. Study design not included in review.2694767
McCrone P, Beecham J, Knapp M. Community psychiatric nurse teams: cost-effectiveness of intensive support versus generic care. Br J Psychiatry. 1994 Aug;165(2):218–21. PMID: 7953035. Study design not included in review.7953035
McDonell MG, Short RA, Hazel NA, . Multiple-family group treatment of outpatients with schizophrenia: impact on service utilization. Fam Process. 2006 Sep;45(3):359–73. PMID: 16984076. Outcome not included in review.16984076
McEvoy JP, Byerly M, Hamer RM, . “Effectiveness of paliperidone palmitate vs haloperidol decanoate for maintenance treatment of schizophrenia: a randomized clinical trial”: Erratum. JAMA. 2014 Oct;312(14):1473. Not a study.
McFarlane WR, Dixon L, Lukens E, . Family psychoeducation and schizophrenia: A review of the literature. J Marital Fam Ther. 2003 Apr;29(2):223–45. doi: 10.1111/j.1752-0606.2003.tb01202.x. PMID: 12728780. Not a study.12728780
McFarlane WR, Dushay RA, Deakins SM, . Employment outcomes in family-aided assertive community treatment. Am J Orthopsychiatry. 2000 Apr;70(2):203–14. PMID: 10826032. Not a study.10826032
McFarlane WR, Dushay RA, Stastny P, . A comparison of two levels of family-aided assertive community treatment. Psychiatr Serv. 1996 Jul;47(7):744–50. PMID: 8807689. Comparator not included in review.8807689
McFarlane WR, Link B, Dushay R, . Psychoeducational multiple family groups: four-year relapse outcome in schizophrenia. Fam Process. 1995 Jun;34(2):127–44. PMID: 7589414. Study covered in a systematic review.7589414
McFarlane WR, Lukens E, Link B, . Multiple-family groups and psychoeducation in the treatment of schizophrenia. Arch Gen Psychiatry. 1995 Aug;52(8):679–87. PMID: 7632121. Comparator not included in review.7632121
McGrew JH, Johannesen JK, Griss ME, . Performance-based funding of supported employment for persons with severe mental illness: vocational rehabilitation and employment staff perspectives. J Behav Health Serv Res. 2007;34(1):1–16. doi: 10.1007/s11414-006-9045-z. PMID: 17180719. Outcome not included in review.17180719
McGurk SR, Mueser KT. Cognitive functioning, symptoms, and work in supported employment: a review and heuristic model. Schizophr Res. 2004 10/1/;70(2–3):147–73. doi: 10.1016/j.schres.2004.01.009. PMID: 15329293. Not a study.15329293
McGurk SR, Mueser KT, DeRosa TJ, . Work, recovery, and comorbidity in schizophrenia: a randomized controlled trial of cognitive remediation. Schizophr Bull. 2009 Mar;35(2):319–35. doi: 10.1093/schbul/sbn182. PMID: 19269925. Study covered in a systematic review.19269925
McGurk SR, Mueser KT, Feldman K, . Cognitive training for supported employment: 2–3 year outcomes of a randomized controlled trial. Am J Psychiatry. 2007 Mar;164(3):437–41. PMID: 17329468. Study covered in a systematic review.17329468
McGurk SR, Mueser KT, Pascaris A. Cognitive training and supported employment for persons with severe mental illness: one-year results from a randomized controlled trial. Schizophr Bull. 2005 Oct;31(4):898–909. PMID: 16079391. Study covered in a systematic review.16079391
McGurk SR, Mueser KT, Xie H, . Cognitive enhancement treatment for people with mental illness who do not respond to supported employment: a randomized controlled trial. Am J Psychiatry. 2015 Sep 1;172(9):852–61. doi: 10.1176/appi.ajp.2015.14030374. PMID: 25998278. Population ineligible for review.25998278
McGurk SR, Twamley EW, Sitzer DI, . A meta-analysis of cognitive remediation in schizophrenia. Am J Psychiatry. 2007 Dec;164(12):1791–802. PMID: 18056233. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.18056233
McHugo GJ, Bebout RR, Harris M, . A randomized controlled trial of integrated versus parallel housing services for homeless adults with severe mental illness. Schizophr Bull. 2004;30(4):969–82. PMID: 15957201. Interventions evaluated in a single study.15957201
McHugo GJ, Drake RE, Teague GB, . Fidelity to assertive community treatment and client outcomes in the New Hampshire dual disorders study. Psychiatr Serv. 1999 Jun;50(6):818–24. PMID: 10375153. Study covered in a systematic review.10375153
McIntosh AM, Conlon L, Lawrie SM, . Compliance therapy for schizophrenia. Cochrane Database Syst Rev. 2009 Jul 19(3):Cd003442. doi: 10.1002/14651858.CD003442.pub2. PMID: 16856009. Intervention not included in review.16856009
McMonagle T, Sultana A. Token economy for schizophrenia. Cochrane Database Syst Rev. 2000(4):Cd001473. doi: 10.1002/14651858.cd001473. PMID: 10908499. Intervention not included in review.10908499
McWilliams S, Hill S, Mannion N, . Schizophrenia: a five-year follow-up of patient outcome following psycho-education for caregivers. Eur Psychiatry. 2012 Jan;27(1):56–61. doi: 10.1016/j.eurpsy.2010.08.012. PMID: 21982177. Study design not included in review.21982177
Medalia A, Richardson R. What predicts a good response to cognitive remediation interventions? Schizophr Bull. 2005 Oct;31(4):942–53. doi: 10.1093/schbul/sbi045. PMID: 16120830. Study design not included in review.16120830
Meltzer H, Lindenmayer J, Kwentus J, . A six month randomized controlled trial of long acting injectable risperidone 50 and 100mg in treatment resistant schizophrenia. Schizophr Res. 2014 Apr;154(1–3):14–22. doi: 10.1016/j.schres.2014.02.015. PMID: 24630262. Comparator not included in review.24630262
Meltzer HY, Bobo WV, Lee MA, . A randomized trial comparing clozapine and typical neuroleptic drugs in non-treatment-resistant schizophrenia. Psychiatry Res. 2010 May 30;177(3):286–93. PMID: 20378185. Study covered in a systematic review.20378185
Meltzer HY, Cucchiaro J, Silva R, . Lurasidone in the treatment of schizophrenia: a randomized, double-blind, placebo- and olanzapine-controlled study. Am J Psychiatry. 2011 Sep;168(9):957–67. doi: 10.1176/appi.ajp.2011.10060907. PMID: 21676992. Inadequate duration (<12 weeks).21676992
Mendella PD, Burton CZ, Tasca GA, . Compensatory cognitive training for people with first-episode schizophrenia: results from a pilot randomized controlled trial. Schizophr Res. 2015 Mar;162(1–3):108–11. doi: 10.1016/j.schres.2015.01.016. PMID: 25631454. Sample size too small (<50).25631454
Mercer G, Finlayson A, Johnstone EC, . A study of enhanced management in patients with treatment-resistant schizophrenia. J Psychopharmacol. 1997;11(4):349–56. PMID: 9443524. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.9443524
Merinder LB, Viuff AG, Laugesen HD, . Patient and relative education in community psychiatry: a randomized controlled trial regarding its effectiveness. Soc Psychiatry Psychiatr Epidemiol. 1999 Jun;34(6):287–94. PMID: 10422481. Study covered in a systematic review.10422481
Meyer JM, Mao Y, Pikalov A, . Weight change during long-term treatment with lurasidone: pooled analysis of studies in patients with schizophrenia. Int Clin Psychopharmacol. 2015 Nov;30(6):342–50. doi: 10.1097/yic.0000000000000091. PMID: 26196189. Outcome not included in review.26196189
Mintz J, O’B’rien CP, Luborsky L. Predicting the outcome of psychotherapy for schizophrenics. Relative contributions of patient, therapist, and treatment characteristics. Arch Gen Psychiatry. 1976 Oct;33(10):1183–6. PMID: 9919. Outcome not included in review.9919
Misawa F, Kishimoto T, Hagi K, . Safety and tolerability of long-acting injectable versus oral antipsychotics: A meta-analysis of randomized controlled studies comparing the same antipsychotics. Schizophrenia Research. 2016 Oct;176(2–3):220–30. doi: 10.1016/j.schres.2016.07.018. PMID: 27499361. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.27499361
Misiak B, Frydecka D, Laczmanski L, . Effects of second-generation antipsychotics on selected markers of one-carbon metabolism and metabolic syndrome components in first-episode schizophrenia patients. Eur J Clin Pharmacol. 2014;70(12):1433–41. PMID: 25291992. Study design not included in review.25291992
Mohamed S, Rosenheck RA, Lin H, . Randomized trial of the effect of four second-generation antipsychotics and one first-generation antipsychotic on cigarette smoking, alcohol, and drug use in chronic schizophrenia. J Nerv Ment Dis. 2015 Jul;203(7):486–92. doi: 10.1097/NMD.0000000000000317. PMID: 26075840. Outcome not included in review.26075840
Mojtabai R, Nicholson RA, Carpenter BN. Role of psychosocial treatments in management of schizophrenia: a meta-analytic review of controlled outcome studies. Schizophr Bull. 1998;24(4):569–87. PMID: 9853790. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.9853790
Montag C, Haase L, Seidel D, . A pilot RCT of psychodynamic group art therapy for patients in acute psychotic episodes: feasibility, impact on symptoms and mentalising capacity. PLoS ONE. 2014;9(11):e112348. doi: 10.1371/journal.pone.0112348. PMID: 25393414. Outcome not included in review.25393414
Montero I, Asencio A, Hernandez I, . Two strategies for family intervention in schizophrenia: a randomized trial in a Mediterranean environment. Schizophr Bull. 2001;27(4):661–70. PMID: 11824492. Comparator not included in review.11824492
Montero I, Asencio AP, Ruiz I, . Family interventions in schizophrenia: an analysis of non-adherence. Acta Psychiatr Scand. 1999 Aug;100(2):136–41. PMID: 10480199. Outcome not included in review.10480199
Montero I, Hernandez I, Asencio A, . Do all people with schizophrenia receive the same benefit from different family intervention programs? Psychiatry Res. 2005 Feb 28;133(2–3):187–95. PMID: 15740994. Intervention not included in review.15740994
Montero I, Masanet MJ, Bellver F, . The long-term outcome of 2 family intervention strategies in schizophrenia. Compr Psychiatry. 2006 Sep–Oct;47(5):362–7. PMID: 16905398. Comparator not included in review.16905398
Moritz S, Andreou C, Schneider BC, . Sowing the seeds of doubt: a narrative review on metacognitive training in schizophrenia. Clin Psychol Rev. 2014 Jun;34(4):358–66. doi: 10.1016/j.cpr.2014.04.004. PMID: 24866025. Not a study.24866025
Moritz S, Cludius B, Hottenrott B, . Mindfulness and relaxation treatment reduce depressive symptoms in individuals with psychosis. Eur Psychiatry. 2015 Sep;30(6):709–14. doi: 10.1016/j.eurpsy.2015.05.002. PMID: 26163302. Comparator not included in review.26163302
Moritz S, Kerstan A, Veckenstedt R, . Further evidence for the efficacy of a metacognitive group training in schizophrenia. Behav Res Ther. 2011 Mar;49(3):151–7. doi: 10.1016/j.brat.2010.11.010. PMID: 21276962. Inadequate duration (<12 weeks).21276962
Moritz S, Veckenstedt R, Andreou C, . Sustained and “sleeper” effects of group metacognitive training for schizophrenia: a randomized clinical trial. JAMA Psychiatry. 2014 Oct;71(10):1103–11. doi: 10.1001/jamapsychiatry.2014.1038. PMID: 25103718. Intervention not included in review.25103718
Moritz S, Veckenstedt R, Bohn F, . Complementary group metacognitive training (MCT) reduces delusional ideation in schizophrenia. Schizophr Res. 2013 Dec;151(1–3):61–9. doi: 10.1016/j.schres.2013.10.007. PMID: 24183707. Intervention not included in review.24183707
Morken G, Grawe RW, Widen JH. Effects of integrated treatment on antipsychotic medication adherence in a randomized trial in recent-onset schizophrenia. J Clin Psychiatry. 2007 Apr;68(4):566–71. PMID: 17474812. Outcome not included in review.17474812
Morrison A, Hutton P, Wardle M, . Cognitive therapy for people with a schizophrenia spectrum diagnosis not taking antipsychotic medication: an exploratory trial. Psychol Med. 2012 May;42(5):1049–56. doi: 10.1017/S0033291711001899. PMID: 21914252. Study design not included in review.21914252
Morrison A, Renton J, Williams S, . Delivering cognitive therapy to people with psychosis in a community mental health setting: an effectiveness study. Acta Psychiatr Scand. 2004 Jul;110(1):36–44. doi: 10.1111/j.1600-0447.2004.00299.x. PMID: 15180778. Study design not included in review.15180778
Morrison AP, Turkington D, Pyle M, . Cognitive therapy for people with schizophrenia spectrum disorders not taking antipsychotic drugs: a single-blind randomised controlled trial. Lancet. 2014 Apr 19;383(9926):1395–403. doi: 10.1016/S0140-6736(13)62246-1. PMID: 24508320. Comparator not included in review.24508320
Morriss R, Vinjamuri I, Faizal MA, . Training to recognise the early signs of recurrence in schizophrenia. Cochrane Database Syst Rev. 2013 Feb 28(2):Cd005147. doi: 10.1002/14651858.CD005147.pub2. PMID: 23450559. Intervention not included in review.23450559
Mossler K, Chen X, Heldal TO, . Music therapy for people with schizophrenia and schizophrenia-like disorders. Cochrane Database Syst Rev. 2011 Dec 07(12):Cd004025. doi: 10.1002/14651858.CD004025.pub3. PMID: 22161383. Intervention not included in review.22161383
Mota NE, Lima MS, Soares BG. Amisulpride for schizophrenia. Cochrane Database Syst Rev. 2002(2):Cd001357. doi: 10.1002/14651858.cd001357. PMID: 12076408. Intervention not included in review.12076408
Mowbray CT, Bybee D, Collins ME. Follow-up client satisfaction in a supported education program. Psychiatr Rehabil J. 2001 Winter;24(3):237–47. PMID: 11315210. Study design not included in review.11315210
Mueller DR, Schmidt SJ, Roder V. Integrated psychological therapy: effectiveness in schizophrenia inpatient settings related to patients’ age. Am J Geriatr Psychiatry. 2013 Mar;21(3):231–41. doi: 10.1016/j.jagp.2012.12.011. PMID: 23395190. Setting ineligible for review (i.e., inpatient only).23395190
Mueser KT, Berenbaum H. Psychodynamic treatment of schizophrenia: is there a future? Psychol Med. 1990 May;20(2):253–62. PMID: 2192381. Not a study.2192381
Mueser KT, Corrigan PW, Hilton DW, . Illness management and recovery: a review of the research. Psychiatr Serv. 2002;53(10):1272–84. doi: 10.1176/appi.ps.53.10.1272. PMID: 12364675. Not a study.12364675
Mueser KT, Deavers F, Penn DL, . Psychosocial treatments for schizophrenia. Annu Rev Clin Psychol. 2013;9:465–97. doi: 10.1146/annurev-clinpsy-050212-185620. PMID: 23330939. Not a study.23330939
Mueser KT, Drake RE, Sigmon SC, . Psychosocial interventions for adults with severe mental illnesses and co-occurring substance use disorders. J Dual Diagn. 2005 2005/04/05;1(2):57–82. doi: 10.1300/J374v01n02_05. Not a study.
Mueser KT, Glynn SM. Have the potential benefits of CBT for severe mental disorders been undersold? World Psychiatry. 2014 Oct;13(3):253–6. doi: 10.1002/wps.20160. PMID: 25273293. Not a study.25273293
Mueser KT, Glynn SM, Cather C, . A randomized controlled trial of family intervention for co-occurring substance use and severe psychiatric disorders. Schizophr Bull. 2013 May;39(3):658–72. doi: 10.1093/schbul/sbr203. PMID: 22282453. Comparator not included in review.22282453
Mueser KT, Glynn SM, Cather C, . Family intervention for co-occurring substance use and severe psychiatric disorders: participant characteristics and correlates of initial engagement and more extended exposure in a randomized controlled trial. Addict Behav. 2009 Oct;34(10):867–77. doi: 10.1016/j.addbeh.2009.03.025. PMID: 19375870. Outcome not included in review.19375870
Mueser KT, Penn DL, Addington J, . The NAVIGATE program for first-episode psychosis: rationale, overview, and description of psychosocial components. Psychiatr Serv. 2015 Jul;66(7):680–90. doi: 10.1176/appi.ps.201400413. PMID: 25772766. Study design not included in review.25772766
Mueser KT, Sengupta A, Schooler NR, . Family treatment and medication dosage reduction in schizophrenia: effects on patient social functioning, family attitudes, and burden. J Consult Clin Psychol. 2001 Feb;69(1):3–12. PMID: 11302274. Not a study.11302274
Muijen M, Cooney M, Strathdee G, . Community psychiatric nurse teams: intensive support versus generic care. Br J Psychiatry. 1994 Aug;165(2):211–7. PMID: 7953034. Outcome not included in review.7953034
Murphy SM, Irving CB, Adams CE, . Crisis intervention for people with severe mental illnesses. Cochrane Database Syst Rev. 2015 Dec 03(12):Cd001087. doi: 10.1002/14651858.CD001087.pub5. PMID: 26633650. Intervention not included in review.26633650
Murray RM, Van Os J. Predictors of outcome in schizophrenia. J Clin Psychopharmacol. 1998 Apr;18(2 Suppl 1):2S–4S. PMID: 9555609. Study design not included in review.9555609
Naeem F, Asmer SM, Khoury B, . Acceptance and commitment therapy for schizophrenia and related disorders. Cochrane Database Syst Rev. 2015(6):Cd011734. doi: 10.1002/14651858.CD011734. Not a study.
Naeem F, Farooq S, Kingdon D. Cognitive behavioural therapy (brief versus standard duration) for schizophrenia. Cochrane Database Syst Rev. 2015 Oct 21;10:Cd010646. doi: 10.1002/14651858.CD010646.pub3. PMID: 26488686. Comparator not included in review.26488686
Naeem F, Xiang S, Munshi TA, . Self-help and guided self-help interventions for schizophrenia and related disorders. Cochrane Database Syst Rev. 2015(5):Cd011698. doi: 10.1002/14651858.CD011698. Not a study.
Nakajima S, Takeuchi H, Fervaha G, . Comparative efficacy between clozapine and other atypical antipsychotics on depressive symptoms in patients with schizophrenia: analysis of the CATIE phase 2E data. Schizophr Res. 2015 Feb;161(2–3):429–33. PMID: 25556080. Outcome not included in review.25556080
Nakamura M, Ogasa M, Guarino J, . Lurasidone in the treatment of acute schizophrenia: a double-blind, placebo-controlled trial. J Clin Psychiatry. 2009 Jun;70(6):829–36. doi: 10.4088/JCP.08m04905. PMID: 19497249. Comparator not included in review.19497249
Nasrallah HA, Cucchiaro JB, Mao Y, . Lurasidone for the treatment of depressive symptoms in schizophrenia: analysis of 4 pooled, 6-week, placebo-controlled studies. CNS Spectr. 2015 Apr;20(2):140–7. doi: 10.1017/s1092852914000285. PMID: 24955752. Inadequate duration (<12 weeks).24955752
Nasrallah HA, Silva R, Phillips D, . Lurasidone for the treatment of acutely psychotic patients with schizophrenia: a 6-week, randomized, placebo-controlled study. J Psychiatr Res. 2013 May;47(5):670–7. Comparator not included in review.23421963
Newton-Howes G, Wood R. Cognitive behavioural therapy and the psychopathology of schizophrenia: systematic review and meta-analysis. Psychol Psychother. 2013 Jun;86(2):127–38. doi: 10.1111/j.2044-8341.2011.02048.x. PMID: 23674464. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23674464
Nielssen OB, Malhi GS, McGorry PD, . Overview of violence to self and others during the first episode of psychosis. J Clin Psychiatry. 2012 May;73(5):e580–7. doi: 10.4088/JCP.11r07036. PMID: 22697204. Study design not included in review.22697204
Nishio M, Ito J, Oshima I, . Preliminary outcome study on assertive community treatment in Japan. Psychiatry Clin Neurosci. 2012 Aug;66(5):383–9. doi: 10.1111/j.1440-1819.2012.02348.x. PMID: 22834656. Study design not included in review.22834656
Nordentoft M, Jeppesen P, Abel M, . OPUS study: suicidal behaviour, suicidal ideation and hopelessness among patients with first-episode psychosis. One-year follow-up of a randomised controlled trial. Br J Psychiatry Suppl. 2002 Sep;43:s98–106. PMID: 12271808. Study covered in a systematic review.12271808
Nordentoft M, Ohlenschlaeger J, Thorup A, . Deinstitutionalization revisited: a 5-year follow-up of a randomized clinical trial of hospital-based rehabilitation versus specialized assertive intervention (OPUS) versus standard treatment for patients with first-episode schizophrenia spectrum disorders. Psychol Med. 2010 Oct;40(10):1619–26. doi: 10.1017/S0033291709992182. PMID: 20059798. Intervention not included in review.20059798
Norman RM, Malla AK, McLean TS, . An evaluation of a stress management program for individuals with schizophrenia. Schizophr Res. 2002 Dec 1;58(2–3):293–303. PMID: 12409170. Interventions evaluated in a single study.12409170
Novakovic V, Adel T, Peselow E, . Long-acting injectable antipsychotics and the development of postinjection delirium/sedation syndrome (PDSS). Clin Neuropharmacol. 2013 Mar–Apr;36(2):59–62. doi: 10.1097/WNF.0b013e3182854f70. PMID: 23503549. Study design not included in review.23503549
O’Brien CP, Hamm KB, Ray BA, . Group vs individual psychotherapy with schizophrenics. A controlled outcome study. Arch Gen Psychiatry. 1972 Oct;27(4):474–8. PMID: 4342116. Intervention not included in review.4342116
Ogasa M, Kimura T, Nakamura M, . Lurasidone in the treatment of schizophrenia: a 6-week, placebo-controlled study. Psychopharmacology. 2013 Feb;225(3):519–30. PMID: CN-00864694 UPDATE. Comparator not included in review.22903391
Ohlenschlaeger J, Nordentoft M, Thorup A, . Effect of integrated treatment on the use of coercive measures in first-episode schizophrenia-spectrum disorder. A randomized clinical trial. Int J Law Psychiatry. 2008 Jan–Feb;31(1):72–6. doi: 10.1016/j.ijlp.2007.11.003. PMID: 18191455. Outcome not included in review.18191455
Ohlenschlaeger J, Thorup A, Petersen L, . Intensive treatment models and coercion. Nord J Psychiatry. 2007;61(5):369–78. PMID: 17990199. Intervention not included in review.17990199
Ojeda N, Pena J, Sanchez P, . Efficiency of cognitive rehabilitation with REHACOP in chronic treatment resistant Hispanic patients. NeuroRehabilitation. 2012;30(1):65–74. PMID: 22349843. Comparator not included in review.22349843
Oka K, Maeda M, Hirano T, . Multicenter study on the effects of day care therapy on schizophrenia: a comparison of day care patients with outpatients. Psychiatry Clin Neurosci. 1999 Aug;53(4):505–10. PMID: 10498233. Intervention not included in review.10498233
Okpokoro U, Adams CE, Sampson S. Family intervention (brief) for schizophrenia. Cochrane Database Syst Rev. 2014;3:CD009802. doi: 10.1002/14651858.CD009802.pub2. PMID: 24595545. Inadequate duration (<12 weeks).24595545
Olbrich R, Mussgay L. Reduction of schizophrenic deficits by cognitive training: an evaluative study. Eur Arch Psychiatry Neurol Sci. 1990;239(6):366–9. PMID: 2144236. Outcome not included in review.2144236
O’Reilly K, Donohoe G, O’Sullivan D, . Study protocol: a randomised controlled trial of cognitive remediation for a national cohort of forensic mental health patients with schizophrenia or schizoaffective disorder. BMC Psychiatry. 2016 Dec;16:5. PMID: 26759167. Not a study.26759167
Orfanos S, Banks C, Priebe S. Are group psychotherapeutic treatments effective for patients with schizophrenia? A systematic review and meta-analysis. Psychother Psychosom. 2015;84(4):241–9. doi: 10.1159/000377705. PMID: 26022543. Intervention not included in review.26022543
Ostergaard Christensen T, Vesterager L, Krarup G, . Cognitive remediation combined with an early intervention service in first episode psychosis. Acta Psychiatr Scand. 2014 Oct;130(4):300–10. doi: 10.1111/acps.12287. PMID: 24833315. Comparator not included in review.24833315
Pagsberg A, Jeppesen P, Klauber D, . Quetiapine versus aripiprazole in children and adolescents with psychosis-protocol for the randomised, blinded clinical Tolerability and Efficacy of Antipsychotics (TEA) trial. BMC Psychiatry. 2014 Jul;14:199. PMID: 25015535. Not a study.25015535
Palma-Sevillano C, Canete-Crespillo J, Farriols-Hernando N, . Randomised controlled trial of cognitive-motivational therapy program for the initial phase of schizophrenia: a 6-month assessment. Eur J Psychiat. 2011 Apr–Jun;25(2):68–80. Sample size too small (<50).
Pandina G, Lane Rd, Gopal S, . A double-blind study of paliperidone palmitate and risperidone long-acting injectable in adults with schizophrenia. Prog Neuropsychopharmacol Biol Psychiatry. 2011 Jan 15;35(1):218–26. doi: 10.1016/j.pnpbp.2010.11.008. PMID: 21092748. Study covered in a systematic review.21092748
Parabiaghi A, D’Avanzo B, Tettamanti M, . The GiSAS study: rationale and design of a pragmatic randomized controlled trial on aripiprazole, olanzapine and haloperidol in the long-term treatment of schizophrenia. Contemp Clin Trials. 2011 Sep;32(5):675–84. PMID: 21554991. Study covered in a systematic review.21554991
Patterson TL, Bucardo J, McKibbin CL, . Development and pilot testing of a new psychosocial intervention for older Latinos with chronic psychosis. Schizophr Bull. 2005 Oct;31(4):922–30. doi: 10.1093/schbul/sbi036. PMID: 16037481. Interventions evaluated in a single study.16037481
Patterson TL, Mausbach BT, McKibbin C, . Functional Adaptation Skills Training (FAST): a randomized trial of a psychosocial intervention for middle-aged and older patients with chronic psychotic disorders. Schizophr Res. 2006 Sep;86(1–3):291–9. doi: 10.1016/j.schres.2006.05.017. PMID: 16814526. Study covered in a systematic review.16814526
Patterson TL, McKibbin C, Taylor M, . Functional adaptation skills training (FAST): a pilot psychosocial intervention study in middle-aged and older patients with chronic psychotic disorders. Am J Geriatr Psychiatry. 2003 Jan–Feb;11(1):17–23. PMID: 12527536. Sample size too small (<50).12527536
Pawelczyk T, Grancow-Grabka M, Kotlicka-Antczak M, . A randomized controlled study of the efficacy of six-month supplementation with concentrated fish oil rich in omega-3 polyunsaturated fatty acids in first episode schizophrenia. J Psychiatr Res. 2016;73:34–44. PMID: 26679763. Intervention not included in review.26679763
Peluso MJ, Lewis SW, Barnes TRE, . Extrapyramidal motor side-effects of first- and second-generation antipsychotic drugs. Br J Psychiatry. 2012;200(5):387–92. PMID: 22442101. Comparator not included in review.22442101
Penades R, Catalan R, Salamero M, . Cognitive remediation therapy for outpatients with chronic schizophrenia: a controlled and randomized study. Schizophr Res. 2006 Oct;87(1–3):323–31. PMID: 16750611. Comparator not included in review.16750611
Penn DL, Meyer PS, Evans E, . A randomized controlled trial of group cognitive-behavioral therapy vs. enhanced supportive therapy for auditory hallucinations. Schizophr Res. 2009 Apr;109(1–3):52–9. doi: 10.1016/j.schres.2008.12.009. PMID: 19176275. Study covered in a systematic review.19176275
Penn DL, Uzenoff SR, Perkins D, . A pilot investigation of the Graduated Recovery Intervention Program (GRIP) for first episode psychosis.[Erratum appears in Schizophr Res. 2012 Oct;141(1):106–7]. Schizophr Res. 2011 Feb;125(2–3):247–56. doi: 10.1016/j.schres.2010.08.006. PMID: 20817484. Interventions evaluated in a single study.20817484
Penttila M, Jaaskelainen E, Hirvonen N, . Duration of untreated psychosis as predictor of long-term outcome in schizophrenia: systematic review and meta-analysis. Br J Psychiatry. 2014 Aug;205(2):88–94. doi: 10.1192/bjp.bp.113.127753. PMID: 25252316. Outcome not included in review.25252316
Peters E, Landau S, McCrone P, . A randomised controlled trial of cognitive behaviour therapy for psychosis in a routine clinical service. Acta Psychiatr Scand. 2010 Oct;122(4):302–18. doi: 10.1111/j.1600-0447.2010.01572.x. PMID: 20491720. Study covered in a systematic review.20491720
Petersen L, Jeppesen P, Thorup A, . Substance abuse and first-episode schizophrenia-spectrum disorders. The Danish OPUS trial. Early Interv Psychiatry. 2007 Feb;1(1):88–96. doi: 10.1111/j.1751-7893.2007.00015.x. PMID: 21352112. Study covered in a systematic review.21352112
Petretto DR, Preti A, Zuddas C, . Study on psychoeducation enhancing results of adherence in patients with schizophrenia (SPERA-S): study protocol for a randomized controlled trial. Trials. 2013;14:323. doi: 10.1186/1745-6215-14-323. PMID: 24099414. Intervention not included in review.24099414
Petrides G, Malur C, Braga RJ, . Electroconvulsive therapy augmentation in clozapine-resistant schizophrenia: a prospective, randomized study. Am J Psychiatry. 2015 Jan;172(1):52–8. doi: 10.1176/appi.ajp.2014.13060787. PMID: 25157964. Intervention not included in review.25157964
Phutane VH, Thirthalli J, Muralidharan K, . Double-blind randomized controlled study showing symptomatic and cognitive superiority of bifrontal over bitemporal electrode placement during electroconvulsive therapy for schizophrenia. Brain Stimul. 2013 Mar;6(2):210–7. PMID: 22560048. Intervention not included in review.22560048
Pickett-Schenk SA, Bennett C, Cook JA, . Changes in caregiving satisfaction and information needs among relatives of adults with mental illness: results of a randomized evaluation of a family-led education intervention. Am J Orthopsychiatry. 2006 Oct;76(4):545–53. doi: 10.1037/0002-9432.76.4.545. PMID: 17209722. Outcome not included in review.17209722
Pickett-Schenk SA, Cook JA, Steigman P, . Psychological well-being and relationship outcomes in a randomized study of family-led education. Arch Gen Psychiatry. 2006 Sep;63(9):1043–50. doi: 10.1001/archpsyc.63.9.1043. PMID: 16953007. Intervention not included in review.16953007
Pickett-Schenk SA, Lippincott RC, Bennett C, . Improving knowledge about mental illness through family-led education: the journey of hope. Psychiatr Serv. 2008 Jan;59(1):49–56. doi: 10.1176/ps.2008.59.1.49. PMID: 18182539. Outcome not included in review.18182539
Pilling S, Bebbington P, Kuipers E, . Psychological treatments in schizophrenia: I. Meta-analysis of family intervention and cognitive behaviour therapy. Psychol Med. 2002 Jul;32(5):763–82. PMID: 12171372. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.12171372
Pinninti NR, Rissmiller DJ, Steer RA. Cognitive-behavioral therapy as an adjunct to second-generation antipsychotics in the treatment of schizophrenia. Psychiatr Serv. 2010 Sep;61(9):940–3. doi: 10.1176/appi.ps.61.9.940. PMID: 20810596. Study covered in a systematic review.20810596
Pinto A, La Pia S, Mennella R, . Cognitive-behavioral therapy and clozapine for clients with treatment-refractory schizophrenia. Psychiatr Serv. 1999 Jul;50(7):901–4. PMID: 10402608. Study covered in a systematic review.10402608
Pitkanen A, Valimaki M, Kuosmanen L, . Patient education methods to support quality of life and functional ability among patients with schizophrenia: a randomised clinical trial. Qual Life Res. 2012 Mar;21(2):247–56. PMID: 21655934. Setting ineligible for review (i.e., inpatient only).21655934
Pitschel-Walz G, Bauml J, Bender W, . Psychoeducation and compliance in the treatment of schizophrenia: results of the Munich Psychosis Information Project Study. J Clin Psychiatry. 2006 Mar;67(3):443–52. PMID: 16649832. Outcome not included in review.16649832
Pitschel-Walz G, Leucht S, Bauml J, . The effect of family interventions on relapse and rehospitalization in schizophrenia--a meta-analysis. Schizophr Bull. 2001;27(1):73–92. PMID: 11215551. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.11215551
Poletti S, Anselmetti S, Bechi M, . Computer-aided neurocognitive remediation in schizophrenia: durability of rehabilitation outcomes in a follow-up study. Neuropsychol Rehabil. 2010 Oct;20(5):659–74. doi: 10.1080/09602011003683158. PMID: 20661811. Interventions evaluated in a single study.20661811
Pompili M, Lester D, Dominici G, . Indications for electroconvulsive treatment in schizophrenia: a systematic review. Schizophr Res. 2013 May;146(1–3):1–9. doi: 10.1016/j.schres.2013.02.005. PMID: 23499244. Intervention not included in review.23499244
Pontes LMM, Martins CB, Napolitano IC, . Cognitive training for schizophrenia in developing countries: a pilot trial in Brazil. Schizophr Res Treatment. 2013 PMID: 24288608. Country not eligible.24288608
Posner CM, Wilson KG, Kral MJ, . Family psychoeducational support groups in schizophrenia. Am J Orthopsychiatry. 1992 Apr;62(2):206–18. PMID: 1580340. Study covered in a systematic review.1580340
Potkin SG, Kimura T, Guarino J. A 6-week, double-blind, placebo- and haloperidol-controlled, phase II study of lurasidone in patients with acute schizophrenia. Ther Adv Psychopharmacol. 2015;5(6):322–31. PMID: 26834965. Inadequate duration (<12 weeks).26834965
Potkin SG, Phiri P, Szegedi A, . Long-term effects of asenapine or olanzapine in patients with persistent negative symptoms of schizophrenia: a pooled analysis. Schizophr Res. 2013 Nov;150(2–3):442–9. doi: 10.1016/j.schres.2013.08.024. PMID: 24075603. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.24075603
Potkin SG, Preskorn S, Hochfeld M, . A thorough QTc study of 3 doses of iloperidone including metabolic inhibition via CYP2D6 and/or CYP3A4 and a comparison to quetiapine and ziprasidone. J Clin Psychopharmacol. 2013 Feb;33(1):3–10. PMID: 23277250. Study design not included in review.23277250
Potkin SG, Raoufinia A, Mallikaarjun S, . Safety and tolerability of once monthly aripiprazole treatment initiation in adults with schizophrenia stabilized on selected atypical oral antipsychotics other than aripiprazole. Curr Med Res Opin. 2013 Oct;29(10):1241–51. doi: 10.1185/03007995.2013.821973. PMID: 23822566. Study design not included in review.23822566
Poulet E, Haesebaert F, Saoud M, . Treatment of shizophrenic patients and rTMS. Psychiatr Danub. 2010 Nov;22 Suppl 1:S143–6. PMID: 21057425. Intervention not included in review.21057425
Power P, Iacoponi E, Reynolds N, . The Lambeth Early Onset Crisis Assessment Team Study: general practitioner education and access to an early detection team in first-episode psychosis. Br J Psychiatry. 2007 Dec;51:s133–9. doi: 10.1192/bjp.191.51.s133. PMID: 18055931. Intervention not included in review.18055931
Pratt SI, Mueser KT, Bartels SJ, . The impact of skills training on cognitive functioning in older people with serious mental illness. Am J Geriatr Psychiatry. 2013 Mar;21(3):242–50. doi: 10.1097/JGP.0b013e31826682dd. PMID: 23395191. Not a study.23395191
Premkumar P, Peters ER, Fannon D, . Coping styles predict responsiveness to cognitive behaviour therapy in psychosis. Psychiatry Res. 2011 May 30;187(3):354–62. doi: 10.1016/j.psychres.2010.12.029. PMID: 21262541. Study design not included in review.21262541
Priebe S. Social outcomes in schizophrenia. Br J Psychiatry. 2007 Aug;50:s15–20. PMID: 18019039. Not a study.18019039
Priebe S, Broker M. Prediction of hospitalizations by schizophrenia patients’ assessment of treatment: an expanded study. J Psychiatr Res. 1999 Mar–Apr;33(2):113–9. doi: 10.1016/S0022-3956%2898%2900037-5. PMID: 10221743. Outcome not included in review.10221743
Priebe S, Gruyters T. A pilot trial of treatment changes according to schizophrenic patients’ wishes. J Nerv Ment Dis. 1999 Jul;187(7):441–3. PMID: 10426465. Intervention not included in review.10426465
Priebe S, Kelley L, Omer S, . The effectiveness of a patient-centred assessment with a solution-focused approach (DIALOG+) for patients with psychosis: a pragmatic cluster-randomised controlled trial in community care. Psychother Psychosom. 2015;84(5):304–13. doi: 10.1159/000430991. PMID: 26278784. Interventions evaluated in a single study.26278784
Priebe S, McCabe R, Bullenkamp J, . Structured patient-clinician communication and 1-year outcome in community mental healthcare: cluster randomised controlled trial. Br J Psychiatry. 2007 Nov;191:420–6. PMID: 17978322. Interventions evaluated in a single study.17978322
Priebe S, Savill M, Reininghaus U, . Effectiveness and cost-effectiveness of body psychotherapy in the treatment of negative symptoms of schizophrenia--a multi-centre randomised controlled trial. BMC Psychiatry. 2013;13:26. doi: 10.1186/1471-244X-13-26. PMID: 23317474. Intervention not included in review.23317474
Prikryl R, Kasparek T, Skotakova S, . Treatment of negative symptoms of schizophrenia using repetitive transcranial magnetic stimulation in a double-blind, randomized controlled study.[Erratum appears in Schizophr Res. 2008 Feb;99(1–3):380–1]. Schizophr Res. 2007 Sep;95(1–3):151–7. PMID: 17689931. Inadequate duration (<12 weeks).17689931
Prikryl R, Ustohal L, Prikrylova Kucerova H, . A detailed analysis of the effect of repetitive transcranial magnetic stimulation on negative symptoms of schizophrenia: a double-blind trial. Schizophr Res. 2013 Sep;149(1–3):167–73. PMID: 23810122. Intervention not included in review.23810122
Puig O, Penades R, Baeza I, . Cognitive remediation therapy in adolescents with early-onset schizophrenia: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry. 2014 Aug;53(8):859–68. doi: 10.1016/j.jaac.2014.05.012. PMID: 25062593. Population ineligible for review.25062593
Pyle M, Norrie J, Schwannauer M, . Design and protocol for the Focusing on Clozapine Unresponsive Symptoms (FOCUS) trial: A randomised controlled trial. BMC Psychiatry. 2016 Dec;16 PMID: 27496180. Study design not included in review.26812906
Qiao Y, Yang F, Li C, . Add-on effects of a low-dose aripiprazole in resolving hyperprolactinemia induced by risperidone or paliperidone. Psychiatry Res. 2016;237:83–9. PMID: 26921057. Study design not included in review.26921057
Quraishi S, David A. Depot haloperidol decanoate for schizophrenia. Cochrane Database Syst Rev. 2009(4):Cd001361. doi: 10.1002/14651858.cd001361. PMID: 10796438. Study covered in a systematic review.10796438
Rabany L, Deutsch L, Levkovitz Y. Double-blind, randomized sham controlled study of deep-TMS add-on treatment for negative symptoms and cognitive deficits in schizophrenia. J Psychopharmacol. 2014;28(7):686–90. PMID: 24829210. Inadequate duration (<12 weeks).24829210
Radhakrishnan R, Kiluk BD, Tsai J. A meta-analytic review of non-specific effects in randomized controlled trials of cognitive remediation for schizophrenia. Psychiatr Q. 2016 Mar;87(1):57–62. doi: 10.1007/s11126-015-9362-6. PMID: 25952944. Outcome not included in review.25952944
Rakitzi S, Georgila P, Efthimiou K, . Efficacy and feasibility of the Integrated Psychological Therapy for outpatients with schizophrenia in Greece: Final results of a RCT. Psychiatry Res. 2016 Aug;242:137–43. doi: 10.1016/j.psychres.2016.05.039. PMID: 27280523. Sample size too small (<50).27280523
Ranasinghe I, Sin J. A systematic review of evidence-based treatment for individuals with treatment-resistant schizophrenia and a suboptimal response to clozapine monotherapy. Psychosis. 2014 Jul;6(3):253–65. doi: 10.1080/17522439.2013.830319. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.
Randolph ET, Eth S, Glynn SM, . Behavioural family management in schizophrenia. Outcome of a clinic-based intervention. Br J Psychiatry. 1994;164(APR.):501–6. PMID: 8038939. Study covered in a systematic review.8038939
Raposo NR, Ferreira AS, Gattaz WF. Body mass index increase, serum leptin, adiponectin, neuropeptide Y and lipid levels during treatment with olanzapine and haloperidol. Pharmacopsychiatry. 2011 Jul;44(5):169–72. doi: 10.1055/s-0031-1280793. PMID: 21732272. Study design not included in review.21732272
Rass O, Forsyth JK, Bolbecker AR, . Computer-assisted cognitive remediation for schizophrenia: a randomized single-blind pilot study. Schizophr Res. 2012 Aug;139(1–3):92–8. doi: 10.1016/j.schres.2012.05.016. PMID: 22682988. Sample size too small (<50).22682988
Rathbone J, Xia J. Acupuncture for schizophrenia. Cochrane Database Syst Rev. 2005 Oct 19(4):Cd005475. doi: 10.1002/14651858.cd005475. PMID: 16235404. Intervention not included in review.16235404
Rathod S, Kingdon D, Weiden P, . Cognitive-behavioral therapy for medication-resistant schizophrenia: a review. J Psychiatr Pract. 2008 Jan;14(1):22–33. doi: 10.1097/01.pra.0000308492.93003.db. PMID: 18212600. Not a study.18212600
Razali SM, Hasanah CI, Khan UA, . Psychosocial interventions for schizophrenia. J Ment Health. 2000;9(3):283–9. Comparator not included in review.
Rector NA, Seeman MV, Segal ZV. Cognitive therapy for schizophrenia: a preliminary randomized controlled trial. Schizophr Res. 2003 Sep 1;63(1–2):1–11. PMID: 12892853. Study covered in a systematic review.12892853
Reddy VP, Kozielska M, Suleiman AA, . Pharmacokinetic-pharmacodynamic modeling of antipsychotic drugs in patients with schizophrenia part I: the use of PANSS total score and clinical utility. Schizophr Res. 2013 May;146(1–3):144–52. doi: 10.1016/j.schres.2013.02.011. PMID: 23473810. Study design not included in review.23473810
Reddy VP, Kozielska M, Suleiman AA, . Pharmacokinetic-pharmacodynamic modelling of antipsychotic drugs in patients with schizophrenia: part II: the use of subscales of the PANSS score. Schizophr Res. 2013 May;146(1–3):153–61. doi: 10.1016/j.schres.2013.02.010. PMID: 23473811. Study design not included in review.23473811
Reeder C, Harris V, Pickles A, . Does change in cognitive function predict change in costs of care for people with a schizophrenia diagnosis following cognitive remediation therapy? Schizophr Bull. 2014 Nov;40(6):1472–81. doi: 10.1093/schbul/sbu046. PMID: 24682210. Outcome not included in review.24682210
Reeder C, Smedley N, Butt K, . Cognitive predictors of social functioning improvements following cognitive remediation for schizophrenia. Schizophr Bull. 2006 Oct;32 Suppl 1:S123–31. PMID: 16901950. Outcome not included in review.16901950
Reichenberg A, Harvey PD. Neuropsychological impairments in schizophrenia: integration of performance-based and brain imaging findings. Psychol Bull. 2007 Sep;133(5):833–58. doi: 10.1037/0033-2909.133.5.833. PMID: 17723032. Not a study.17723032
Resnick SG, Rosenheck RA, Canive JM, . Employment outcomes in a randomized trial of second-generation antipsychotics and perphenazine in the treatment of individuals with schizophrenia. J Behav Health Serv Res. 2008 Apr;35(2):215–25. PMID: 18246429. Study covered in a systematic review.18246429
Revell ER, Neill JC, Harte M, . A systematic review and meta-analysis of cognitive remediation in early schizophrenia. Schizophr Res. 2015 Oct;168(1–2):213–22. doi: 10.1016/j.schres.2015.08.017. PMID: 26305063. Comparator not included in review.26305063
Riedel M, Mayr A, Seemuller F, . Depressive symptoms and their association with acute treatment outcome in first-episode schizophrenia patients: comparing treatment with risperidone and haloperidol. World J Biol Psychiatry. 2012 Jan;13(1):30–8. doi: 10.3109/15622975.2011.552633. PMID: 21568628. Setting ineligible for review (i.e., inpatient only).21568628
Riedel M, Schmitz M, Ostergaard PK, . Comparison of the effects of quetiapine extended-release and quetiapine immediate-release on cognitive performance, sedation and patient satisfaction in patients with schizophrenia: a randomised, double-blind, crossover study (eXtRa). Schizophr Res. 2015 Mar;162(1–3):162–8. PMID: 25592805. Study design not included in review.25592805
Roberts DL, Combs DR, Willoughby M, . A randomized, controlled trial of Social Cognition and Interaction Training (SCIT) for outpatients with schizophrenia spectrum disorders. Br J Clin Psychol. 2014 Sep;53(3):281–98. doi: 10.1111/bjc.12044. PMID: 24417608. Interventions evaluated in a single study.24417608
Roberts DL, Penn DL. Social Cognition and Interaction Training (SCIT) for outpatients with schizophrenia: a preliminary study. Psychiatry Res. 2009;166(2–3):141–7. PMID: 19272654. Study design not included in review.19272654
Rocha NB, Queiros C. Metacognitive and social cognition training (MSCT) in schizophrenia: a preliminary efficacy study. Schizophr Res. 2013 Oct;150(1):64–8. doi: 10.1016/j.schres.2013.07.057. PMID: 23962827. Inadequate duration (<12 weeks).23962827
Roder V, Brenner H, Muller D, . Development of specific social skills training programmes for schizophrenia patients: results of a multicentre study. Acta Psychiatr Scand. 2002 May;105(5):363–71. doi: 10.1034/j.1600-0447.2002.1o214.x. PMID: 11942943. Comparator not included in review.11942943
Roder V, Mueller DR, Mueser KT, . Integrated psychological therapy (IPT) for schizophrenia: is it effective? Schizophr Bull. 2006 Oct;32 Suppl 1:S81–93. PMID: 16916888. Not a study.16916888
Roder V, Zorn P, Brenner H. Kognitiv-behaviorale Programme fur schizophren Erkrankte zum Aufbau sozialer Kompetenz im Wohn-Arbeits- und Freizeitbereich: uber-blick und empirische Ergebnisse. Verhaltenstherapie und psychosoziale Praxis. 2000;32:195–211. Not English language.
Rodewald K, Rentrop M, Holt DV, . Planning and problem-solving training for patients with schizophrenia: a randomized controlled trial. BMC Psychiatry. 2011;11:73. doi: 10.1186/1471-244X-11-73. PMID: 21527028. Comparator not included in review.21527028
Rohricht F, Priebe S. Effect of body-oriented psychological therapy on negative symptoms in schizophrenia: a randomized controlled trial. Psychol Med. 2006 May;36(5):669–78. PMID: 16608559. Intervention not included in review.16608559
Roosenschoon BJ, Mulder CL, Deen ML, . Effectiveness of illness management and recovery (IMR) in the Netherlands: a randomised clinical trial. BMC Psychiatry. 2016;16 (1)PMID: 26995361. Systematic review/meta-analysis used as a source document to identify individual studies.26995361
Rose A, Vinogradov S, Fisher M, . Randomized controlled trial of computer-based treatment of social cognition in schizophrenia: the TRuSST trial protocol. BMC Psychiatry. 2015;15 (142)PMID: 26138715. Study design not included in review.26138715
Rose D, Wykes TIL, Farrier D, . What do clients think of cognitive remediation therapy?: a consumer-led investigation of satisfaction and side effects. Am J Psychiatr Rehabil. 2008 2008/04/10;11(2):181–204. doi: 10.1080/15487760801963694. Study design not included in review.
Rosenbaum B, Valbak K, Harder S, . The Danish National Schizophrenia Project: prospective, comparative longitudinal treatment study of first-episode psychosis. Br J Psychiatry. 2005;186(MAY):394–9. PMID: 15863743. Study design not included in review.15863743
Rosenheck R, Neale M, Gallup P. Community-oriented mental health care: assessing diversity in clinical practice. Psychosoc Rehabil J. 1993;16(4):39–50. doi: 10.1037/h0095653. Study design not included in review.
Rotondi AJ, Anderson CM, Haas GL, . Web-based psychoeducational intervention for persons with schizophrenia and their supporters: one-year outcomes. Psychiatr Serv. 2010 Nov;61(11):1099–105. doi: 10.1176/appi.ps.61.11.1099. PMID: 21041348. Interventions evaluated in a single study.21041348
Royer A, Grosselin A, Bellot C, . Is there any impact of cognitive remediation on an ecological test in schizophrenia? Cogn Neuropsychiatry. 2012;17(1):19–35. doi: 10.1080/13546805.2011.564512. PMID: 21707472. Outcome not included in review.21707472
Ruberg SJ, Chen L, Stauffer V, . Identification of early changes in specific symptoms that predict longer-term response to atypical antipsychotics in the treatment of patients with schizophrenia. BMC Psychiatry. 2011;11 PMID: 21306626. Study design not included in review.21306626
Ruddy R, Milnes D. Art therapy for schizophrenia or schizophrenia-like illnesses. Cochrane Database Syst Rev. 2005(4):CD003728. PMID: 16235338. Intervention not included in review.16235338
Rus-Calafell M, Gutierrez-Maldonado J, Ortega-Bravo M, . A brief cognitive-behavioural social skills training for stabilised outpatients with schizophrenia: a preliminary study. Schizophr Res. 2013 Feb;143(2–3):327–36. doi: 10.1016/j.schres.2012.11.014. PMID: 23235141. Sample size too small (<50).23235141
Rybakowski JK, Vansteelandt K, Remlinger-Molenda A, . Extrapyramidal symptoms during treatment of first schizophrenia episode: results from EUFEST. Eur Neuropsychopharmacol. 2014;24(9):1500–5. PMID: 25085534. Study covered in a systematic review.25085534
Rybakowski JK, Vansteelandt K, Szafranski T, . Treatment of depression in first episode of schizophrenia: results from EUFEST. Eur Neuropsychopharmacol. 2012 Dec;22(12):875–82. doi: 10.1016/j.euroneuro.2012.04.001. PMID: 22627166. Outcome not included in review.22627166
Sachs G, Winklbaur B, Jagsch R, . Training of affect recognition (TAR) in schizophrenia--impact on functional outcome. Schizophr Res. 2012 Jul;138(2–3):262–7. PMID: 22464728. Inadequate duration (<12 weeks).22464728
Sajatovic M, Forester BP, Tsai J, . Efficacy of lurasidone in adults aged 55 years and older with bipolar depression: post hoc analysis of 2 double-blind, placebo-controlled studies. J Clin Psychiatry. 2016 Aug 16doi: 10.4088/JCP.15m10261. PMID: 27529375. Population ineligible for review.27529375
Sajatovic M, Levin J, Ramirez LF, . A prospective trial of customized adherence enhancement plus long-acting injectable antipsychotic medication in homeless or recently homeless individuals with schizophrenia or schizoaffective disorder. J Clin Psychiatry. 2013;74(12):1249–55. doi: 10.4088/JCP.12m08331. PMID: 24434094. Study design not included in review.24434094
Sakurai H, Bies RR, Stroup ST, . Dopamine D2 receptor occupancy and cognition in schizophrenia: analysis of the CATIE data. Schizophr Bull. 2013 May;39(3):564–74. doi: 10.1093/schbul/sbr189. PMID: 22290266. Study design not included in review.22290266
Salkever D, Gibbons B, Ran X. Do comprehensive, coordinated, recovery-oriented services alter the pattern of use of treatment services? Mental health treatment study impacts on SSDI beneficiaries’ use of inpatient, emergency, and crisis services.[Erratum appears in J Behav Health Serv Res. 2014 Oct;41(4):559]. J Behav Health Serv Res. 2014 Oct;41(4):434–46. doi: 10.1007/s11414-013-9388-1. PMID: 24481541. Outcome not included in review.24481541
Salyers MP, McGuire AB, Kukla M, . A randomized controlled trial of illness management and recovery with an active control group. Psychiatr Serv. 2014 Aug 1;65(8):1005–11. PMID: 24733680. Comparator not included in review.24733680
Sampford JR, Sampson S, Li BG, . Fluphenazine (oral) versus atypical antipsychotics for schizophrenia. Cochrane Database Syst Rev. 2016 Jul 02;7:CD010832. doi: 10.1002/14651858.CD010832.pub2. PMID: 27370402. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.27370402
Sampson S, Hosalli P, Furtado VA, . Risperidone (depot) for schizophrenia. Cochrane Database Syst Rev. 2016 Apr 14;4:Cd004161. doi: 10.1002/14651858.CD004161.pub2. PMID: 27078222. Study covered in a systematic review.27078222
Sampson S, Mansour M, Maayan N, . Intermittent drug techniques for schizophrenia. Cochrane Database Syst Rev. 2013 Jul 20(7):Cd006196. doi: 10.1002/14651858.CD006196.pub2. PMID: 23881657. Study design not included in review.23881657
Saperstein AM, Fiszdon JM, Bell MD. Intrinsic motivation as a predictor of work outcome after vocational rehabilitation in schizophrenia. J Nerv Ment Dis. 2011 Sep;199(9):672–7. doi: 10.1097/NMD.0b013e318229d0eb. PMID: 21878781. Study design not included in review.21878781
Sarin F, Wallin L. Cognitive model and cognitive behavior therapy for schizophrenia: an overview. Nord J Psychiatry. 2014 Apr;68(3):145–53. doi: 10.3109/08039488.2013.789074. PMID: 24627960. Not a study.24627960
Sarin F, Wallin L, Widerlov B. Cognitive behavior therapy for schizophrenia: a meta-analytical review of randomized controlled trials. Nord J Psychiatry. 2011 Jun;65(3):162–74. doi: 10.3109/08039488.2011.577188. PMID: 21563994. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.21563994
Sato S, Iwata K, Furukawa SI, . The effects of the combination of cognitive training and supported employment on improving clinical and working outcomes for people with schizophrenia in Japan. Clin Pract Epidemiol Ment Health. 2014;10(1):18–27. PMID: 24600481. Study design not included in review.24600481
Savitz AJ, Lane R, Nuamah I, . Efficacy and safety of paliperidone extended release in adolescents with schizophrenia: a randomized, double-blind study. J Am Acad Child Adolesc Psychiatry. 2015;54(2):126–37.e1. PMID: 25617253. Population ineligible for review.25617253
Schennach-Wolff R, Jager M, Mayr A, . Predictors of response and remission in the acute treatment of first-episode schizophrenia patients--is it all about early response? Eur Neuropsychopharmacol. 2011 May;21(5):370–8. doi: 10.1016/j.euroneuro.2010.10.003. PMID: 21255982. Study design not included in review.21255982
Schimmelmann BG, Schmidt SJ, Carbon M, . Treatment of adolescents with early-onset schizophrenia spectrum disorders: in search of a rational, evidence-informed approach. Curr Opin Psychiatry. 2013 Mar;26(2):219–30. doi: 10.1097/YCO.0b013e32835dcc2a. PMID: 23364281. Population ineligible for review.23364281
Schmidt HM, Hagen M, Kriston L, . Management of sexual dysfunction due to antipsychotic drug therapy. Cochrane Database Syst Rev. 2012 Nov 14;11:Cd003546. doi: 10.1002/14651858.CD003546.pub3. PMID: 23152218. Study design not included in review.23152218
Schmidt-Posner J, Jerrell JM. Qualitative analysis of three case management programs. Community Ment Health J. 1998 Aug;34(4):381–92. PMID: 9693866. Study design not included in review.9693866
Schnell T, Koethe D, Krasnianski A, . Ziprasidone versus clozapine in the treatment of dually diagnosed (DD) patients with schizophrenia and cannabis use disorders: a randomized study. Am J Addict. 2014 May–Jun;23(3):308–12. doi: 10.1111/j.1521-0391.2014.12126.x. PMID: 24628830. Sample size too small (<50).24628830
Schottle D, Schimmelmann BG, Karow A, . Effectiveness of integrated care including therapeutic assertive community treatment in severe schizophrenia spectrum and bipolar I disorders: the 24-month follow-up ACCESS II study. J Clin Psychiatry. 2014 Dec;75(12):1371–9. PMID: 25188752. Study design not included in review.25188752
Schreiner A, Aadamsoo K, Altamura AC, . Paliperidone palmitate versus oral antipsychotics in recently diagnosed schizophrenia. Schizophr Res. 2015;169(1–3):393–9. doi: 10.1016/j.schres.2015.08.015. PMID: 26431793. Comparator not included in review.26431793
Schulz M, Gray R, Spiekermann A, . Adherence therapy following an acute episode of schizophrenia: a multi-centre randomised controlled trial. Schizophr Res. 2013 May;146(1–3):59–63. doi: 10.1016/j.schres.2013.01.028. PMID: 23452506. Interventions evaluated in a single study.23452506
Scogin F, Morthland M, Kaufman A, . Improving quality of life in diverse rural older adults: a randomized trial of a psychological treatment. Psychol Aging. 2007 Dec;22(4):657–65. doi: 10.1037/0882-7974.22.4.657. PMID: 18179286. Population ineligible for review.18179286
Secher RG, Nordentoft M, Austin S, . The OPUS trial: Intensive, early, psychosocial intervention versus treatment as usual for people with a first episode within the schizophrenic spectrum. Results from the 10-year follow-up. Early Interv Psychiatry. 2012;6(21). Not a study.
Seeman MV. Clinic versus private treatment of psychosis. J Clin Psychiatry. 1978 Mar;39(3):213–5. PMID: 204624. Intervention not included in review.204624
Seemuller F, Schennach R, Mayr A, . Akathisia and suicidal ideation in first-episode schizophrenia. J Clin Psychopharmacol. 2012 Oct;32(5):694–8. PMID: 22926606. Study design not included in review.22926606
Sengul MCB, Kenar ANI, Hanci E, . Practice of acute and maintenance electroconvulsive therapy in the psychiatric clinic of a university hospital from Turkey: between 2007 and 2013. Clin Psychopharmacol Neurosci. 2016;14(1):57–63. PMID: 26792041. Study design not included in review.26792041
Sharifi V, Tehranidoost M, Yunesian M, . Effectiveness of a low-intensity home-based aftercare for patients with severe mental disorders: a 12-month randomized controlled study. Community Ment Health J. 2012 Dec;48(6):766–70. PMID: 22772746. Intervention not included in review.22772746
Shen X, Xia J, Adams CE. Acupuncture for schizophrenia. Cochrane Database Syst Rev. 2014 Oct 20;10:Cd005475. doi: 10.1002/14651858.CD005475.pub2. PMID: 25330045. Intervention not included in review.25330045
Shern DL, Tsemberis S, Anthony W, . Serving street-dwelling individuals with psychiatric disabilities: outcomes of a psychiatric rehabilitation clinical trial. Am J Public Health. 2000 Dec;90(12):1873–8. PMID: 11111259. Interventions evaluated in a single study.11111259
Shi C, Yu X, Cheung EF, . Revisiting the therapeutic effect of rTMS on negative symptoms in schizophrenia: a meta-analysis. Psychiatry Res. 2014 Mar 30;215(3):505–13. doi: 10.1016/j.psychres.2013.12.019. PMID: 24411074. Intervention not included in review.24411074
Shimodera S, Inoue S, Mino Y, . Expressed emotion and psychoeducational intervention for relatives of patients with schizophrenia: a randomized controlled study in Japan. Psychiatry Res. 2000 Oct 30;96(2):141–8. PMID: 11063786. Outcome not included in review.11063786
Shin SK, Lukens EP. Effects of psychoeducation for Korean Americans with chronic mental illness. Psychiatr Serv. 2002 Sep;53(9):1125–31. PMID: 12221311. Inadequate duration (<12 weeks).12221311
Sigrunarson V, Grawe RW, Morken G. Integrated treatment vs. treatment-as-usual for recent onset schizophrenia; 12 year follow-up on a randomized controlled trial. BMC Psychiatry. 2013;13:200. doi: 10.1186/1471-244X-13-200. PMID: 23898805. Sample size too small (<50).23898805
Silva BA, Cassilhas RC, Attux C, . A 20-week program of resistance or concurrent exercise improves symptoms of schizophrenia: results of a blind, randomized controlled trial. Rev Bras Psiquiatr. 2015 Oct–Dec;37(4):271–9. doi: 10.1590/1516-4446-2014-1595. PMID: 26375919. Intervention not included in review.26375919
Silverstein SM, Spaulding WD, Menditto AA, . Attention shaping: a reward-based learning method to enhance skills training outcomes in schizophrenia. Schizophr Bull. 2009 Jan;35(1):222–32. doi: 10.1093/schbul/sbm150. PMID: 18212327. Intervention not included in review.18212327
Singh J, Kour K, Jayaram MB. Acetylcholinesterase inhibitors for schizophrenia. Cochrane Database Syst Rev. 2012 Jan 18;1:Cd007967. doi: 10.1002/14651858.CD007967.pub2. PMID: 22258978. Intervention not included in review.22258978
Sivaraman P, Rattehalli RD, Jayaram MB. Levomepromazine for schizophrenia. Cochrane Database Syst Rev. 2010 Oct 06(10):Cd007779. doi: 10.1002/14651858.CD007779.pub2. PMID: 20927765. Intervention not included in review.20927765
Smeraldi E, Cavallaro R, Folnegovic-Smalc V, . Long-term remission in schizophrenia and schizoaffective disorder: Results from the risperidone long-acting injectable versus quetiapine relapse prevention trial (ConstaTRE). Ther Adv Psychopharmacol. 2013;3(4):191–9. PMID: 24167692 Outcome not included in review.24167692
Smith MJ, Fleming MF, Wright MA, . Virtual reality job interview training and 6-month employment outcomes for individuals with schizophrenia seeking employment. Schizophr Res. 2015 Aug;166(1–3):86–91. doi: 10.1016/j.schres.2015.05.022. PMID: 26032567. Interventions evaluated in a single study.26032567
Smith TE, Weston CA, Lieberman JA. Schizophrenia (maintenance treatment). BMJ Clin Evid. 2009 PMID: 19445748. Systematic review/meta-analysis used as a source document to identify individual studies.19445748
Soares-Weiser K, Bechard-Evans L, Lawson AH, . Time to all-cause treatment discontinuation of olanzapine compared to other antipsychotics in the treatment of schizophrenia: a systematic review and meta-analysis. Eur Neuropsychopharmacol. 2013 Feb;23(2):118–25. doi: 10.1016/j.euroneuro.2012.05.001. PMID: 22633617. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.22633617
Solomon P. Moving from psychoeducation to family education for families of adults with serious mental illness. Psychiatr Serv. 1996 Dec;47(12):1364–70. doi: 10.1176/ps.47.12.1364. PMID: 9117476. Not a study.9117476
Solomon P, Draine J. Consumer case management and attitudes concerning family relations among persons with mental illness. Psychiatr Q. 1995;66(3):249–61. PMID: 7568532. Outcome not included in review.7568532
Solomon P, Draine J. One-year outcomes of a randomized trial of case management with seriously mentally ill clients leaving jail. Eval Rev. 1995;19(3):256–73. doi: 10.1177/0193841X9501900302. Study covered in a systematic review.
Solomon P, Draine J, Mannion E, . Impact of brief family psychoeducation on self-efficacy. Schizophr Bull. 1996;22(1):41–50. PMID: 8685662. Outcome not included in review.8685662
Solomon P, Draine J, Mannion E, . Increased contact with community mental health resources as a potential benefit of family education. Psychiatr Serv. 1998 Mar;49(3):333–9. PMID: 9525792. Not a study.9525792
Soundy A, Freeman P, Stubbs B, . The transcending benefits of physical activity for individuals with schizophrenia: a systematic review and meta-ethnography. Psychiatry Res. 2014 Dec 15;220(1–2):11–9. doi: 10.1016/j.psychres.2014.07.083. PMID: 25149128. Intervention not included in review.25149128
Souza JS, Kayo M, Tassell I, . Efficacy of olanzapine in comparison with clozapine for treatment-resistant schizophrenia: evidence from a systematic review and meta-analyses. CNS Spectr. 2013 Apr;18(2):82–9. doi: 10.1017/S1092852912000806. PMID: 23253621. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23253621
Spencer PG, Gillespie CR, Ekisa EG. A controlled comparison of the effects of social skills training and remedial drama on the conversational skills of chronic schizophrenic inpatients. Br J Psychiatry. 1983;143:165–72. PMID: 6351955. Setting ineligible for review (i.e., inpatient only).6351955
Srihari VH, Tek C, Kucukgoncu S, . First-episode services for psychotic disorders in the U.S. public sector: a pragmatic randomized controlled trial. Psychiatr Serv. 2015 Jul;66(7):705–12. doi: 10.1176/appi.ps.201400236. PMID: 25639994. Population ineligible for review.25639994
Srisurapanont M, Suttajit S, Maneeton N, . Efficacy and safety of aripiprazole augmentation of clozapine in schizophrenia: a systematic review and meta-analysis of randomized-controlled trials. J Psychiatr Res. 2015 Mar;62:38–47. doi: 10.1016/j.jpsychires.2015.01.004. PMID: 25619176. Comparator not included in review.25619176
Stanton AH, Gunderson JG, Knapp PH, . Effects of psychotherapy in schizophrenia: I. design and implementation of a controlled study. Schizophr Bull. 1984;10(4):520–63. PMID: 6151245. Interventions evaluated in a single study.6151245
Stanton R, Happell B. A systematic review of the aerobic exercise program variables for people with schizophrenia. Curr Sports Med Rep. 2014 Jul–Aug;13(4):260–6. doi: 10.1249/JSR.0000000000000069. PMID: 25014392. Intervention not included in review.25014392
Startup M, Jackson MC, Bendix S. North Wales randomized controlled trial of cognitive behaviour therapy for acute schizophrenia spectrum disorders: outcomes at 6 and 12 months. Psychol Med. 2004 Apr;34(3):413–22. PMID: 15259826. Population ineligible for review.15259826
Startup M, Jackson MC, Evans KE, . North Wales randomized controlled trial of cognitive behaviour therapy for acute schizophrenia spectrum disorders: two-year follow-up and economic evaluation. Psychol Med. 2005 Sep;35(9):1307–16. PMID: 16168153. Study covered in a systematic review.16168153
Startup M, Jackson MC, Startup S. Insight and recovery from acute psychotic episodes: the effects of cognitive behavior therapy and premature termination of treatment. J Nerv Ment Dis. 2006;194(10):740–5. PMID: 17041285. Outcome not included in review.17041285
Statucka M, Walder DJ. Efficacy of social cognition remediation programs targeting facial affect recognition deficits in schizophrenia: a review and consideration of high-risk samples and sex differences. Psychiatry Res. 2013 Apr 30;206(2–3):125–39. doi: 10.1016/j.psychres.2012.12.005. PMID: 23375627. Not a study.23375627
Stauffer VL, Case M, Kinon BJ, . Early response to antipsychotic therapy as a clinical marker of subsequent response in the treatment of patients with first-episode psychosis. Psychiatry Res. 2011 May 15;187(1–2):42–8. PMID: 21168920. Study design not included in review.21168920
Steel C, van der Gaag M, Korrelboom K, . A randomised controlled trial of positive memory training for the treatment of depression within schizophrenia. BMC Psychiatry. 2015;15:85. doi: 10.1186/s12888-015-0453-6. PMID: 25886265. Not a study.25886265
Stevens H, Agerbo E, Dean K, . Reduction of crime in first-onset psychosis: a secondary analysis of the OPUS randomized trial. J Clin Psychiatry. 2013 May;74(5):e439–44. doi: 10.4088/JCP.12m08156. PMID: 23759464. Study design not included in review.23759464
Stikkelbroek Y, Bodden DHM, Dekovic M, . Effectiveness and cost effectiveness of cognitive behavioral therapy (CBT) in clinically depressed adolescents: individual CBT versus treatment as usual (TAU). BMC Psychiatry. 2013;13 PMID: 24261913. Population ineligible for review.24261913
Stip E, Vincent PD, Sablier J, . A randomized controlled trial with a canadian electronic pill dispenser used to measure and improve medication adherence in patients with schizophrenia. Front Pharmacol. 2013;4 PMID: 23950746. Intervention not included in review.23950746
Strkalj-Ivezic S, Vrdoljak M, Muzinic L, . The impact of a rehabilitation day centre program for persons suffering from schizophrenia on quality of life, social functioning and self-esteem. Psychiatr Danub. 2013 Sep;25 Suppl 2:S194–9. PMID: 23995175. Intervention not included in review.23995175
Stubbs B, Rosenbaum S, Ward PB, . No evidence of a control group response in exercise randomised controlled trials in people with schizophrenia: a systematic review and meta-analysis. Psychiatry Res. 2015 Oct 30;229(3):840–3. doi: 10.1016/j.psychres.2015.07.081. PMID: 26254799. Comparator not included in review.26254799
Subramaniam K, Luks T, Aldebot S, . Neuroplasticity-based cognitive training improves reality monitoring in schizophrenia patients: behavioral and fmri assessments. Schizophr Res. 2010;117(2–3):471. Not a study.
Subramaniam K, Luks TL, Garrett C, . Intensive cognitive training in schizophrenia enhances working memory and associated prefrontal cortical efficiency in a manner that drives long-term functional gains. Neuroimage. 2014 Oct 1;99:281–92. doi: 10.1016/j.neuroimage.2014.05.057. PMID: 24867353. Comparator not included in review.24867353
Sungur M, Soygur H, Guner P, . Identifying an optimal treatment for schizophrenia: a 2-year randomized controlled trial comparing integrated care to a high-quality routine treatment. Int J Psychiatry Clin Pract. 2011 Jun;15(2):118–27. doi: 10.3109/13651501.2011.554987. PMID: 22121860. Interventions evaluated in a single study.22121860
Sungur MZ, Guner P, Ustun B, . Optimal treatment project for schizophrenia: results from a randomized, controlled, longitudinal study. Seishin Shinkeigaku Zasshi. 2003;105(9):1175–80. PMID: 14639941. Interventions evaluated in a single study.14639941
Sunovion. A Twelve Week, Open Label Extension Study in Patients With Schizophrenia [Study completed November 2013; unpublished extension of NCT00044044]. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine; 2000-. https://clinicaltrials.gov/ct2/show/study/NCT01566162 Accessed February 6, 2017. NLM Identifier: NCT01566162. Study design not included in review.
Sunovion. A Randomized, Open-Label, Dose-Blinded, Multicenter, 6-Month Study of Safety and Tolerability of 3 Dose Levels of lurasidone in Patients With Schizophrenia [Study completed November 2013; unpublished extension of NCT00044044]. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine; 2000-. https://clinicaltrials.gov/ct2/show/study/NCT00044005. Accessed Accessed February 6, 2017. NLM Identifier: NCT00044005. Study design not included in review.
Suttajit S, Srisurapanont M, Xia J, . Quetiapine versus typical antipsychotic medications for schizophrenia. Cochrane Database Syst Rev. 2013 May 31(5):Cd007815. doi: 10.1002/14651858.CD007815.pub2. PMID: 23728667. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23728667
Suzuki H, Gen K. The influence of switching from haloperidol decanoate depot to risperidone long-acting injection on the clinical symptoms and cognitive function in schizophrenia. Hum Psychopharmacol. 2012 Sep;27(5):470–5. doi: 10.1002/hup.2249. PMID: 23001955. Study design not included in review.23001955
Suzuki H, Gen K, Inoue Y, . The influence of switching from risperidone to paliperidone on the extrapyramidal symptoms and cognitive function in elderly patients with schizophrenia: A preliminary open-label trial. Int J Psychiatry Clin Pract. 2014 Jan;18(1):58–62. doi: 10.3109/13651501.2013.845218. PMID: 24047427. Study design not included in review.24047427
Szmukler GI, Herrman H, Colusa S, . A controlled trial of a counselling intervention for caregivers of relatives with schizophrenia. Soc Psychiatry Psychiatr Epidemiol. 1996 Jun;31(3–4):149–55. PMID: 8766460. Intervention not included in review.8766460
Takacs R, Ivanyi Z, Ungvari GS, . Safety of the electroconvulsive therapy and amisulpride combination. Psychiatr Danub. 2013;25(1):76–9. PMID: 23470610 Study design not included in review.23470610
Takahashi H, Sassa T, Shibuya T, . Effects of sports participation on psychiatric symptoms and brain activations during sports observation in schizophrenia. Transl Psychiatry. 2012;2:e96. doi: 10.1038/tp.2012.22. PMID: 22832861. Study design not included in review.22832861
Takekita Y, Fabbri C, Kato M, . Antagonist and partial agonist at the dopamine D2 receptors in drug-naive and non-drug-naive schizophrenia: a randomized, controlled trial. Eur Arch Psychiatry Clin Neurosci. 2015;265(7):579–88. PMID: 26016467. Comparator not included in review.26016467
Takeuchi H, Fervaha G, Lee J, . Effectiveness of different dosing regimens of risperidone and olanzapine in schizophrenia. Eur Neuropsychopharmacol. 2015 Mar;25(3):295–302. doi: 10.1016/j.euroneuro.2014.12.008. PMID: 25649680. Outcome not included in review.25649680
Takeuchi H, Fervaha G, Remington G. Effect of antipsychotic dosing regimen on neurocognition in schizophrenia. J Clin Psychopharmacol. 2015 Dec;35(6):728–30. doi: 10.1097/JCP.0000000000000424. PMID: 26479222. Comparator not included in review.26479222
Takeuchi H, Fervaha G, Uchida H, . Impact of once- versus twice-daily perphenazine dosing on clinical outcomes: an analysis of the CATIE data. J Clin Psychiatry. 2014;75(5):506–11. PMID: 24569099. Comparator not included in review.24569099
Takeuchi H, Suzuki T, Bies RR, . Dose reduction of risperidone and olanzapine and estimated dopamine D2 receptor occupancy in stable patients with schizophrenia: findings from an open-label, randomized, controlled study. J Clin Psychiatry. 2014 Nov;75(11):1209–14. doi: 10.4088/JCP.13m08841. PMID: 25099201. Outcome not included in review.25099201
Takeuchi H, Suzuki T, Remington G, . Effects of risperidone and olanzapine dose reduction on cognitive function in stable patients with schizophrenia: an open-label, randomized, controlled, pilot study. Schizophr Bull. 2013 Sep;39(5):993–8. doi: 10.1093/schbul/sbt090. PMID: 23821768. Study design not included in review.23821768
Takeuchi H, Suzuki T, Remington G, . Lack of effect of risperidone or olanzapine dose reduction on subjective experiences in stable patients with schizophrenia. Psychiatry Res. 2014 Aug 15;218(1–2):244–6. doi: 10.1016/j.psychres.2014.04.019. PMID: 24768247. Study design not included in review.24768247
Tan BL, King R. The effects of cognitive remediation on functional outcomes among people with schizophrenia: a randomised controlled study. Aust N Z J Psychiatry. 2013 Nov;47(11):1068–80. doi: 10.1177/0004867413493521. PMID: 23785044. Country not eligible.23785044
Tan S, Zou Y, Wykes T, . Group cognitive remediation therapy for chronic schizophrenia: A randomized controlled trial. Neurosci Lett. 2016 Jul 28;626:106–11. doi: 10.1016/j.neulet.2015.08.036. PMID: 26314508. Country not eligible.26314508
Tardy M, Huhn M, Engel RR, . Fluphenazine versus low-potency first-generation antipsychotic drugs for schizophrenia. Cochrane Database Syst Rev. 2014 Aug 03(8):Cd009230. doi: 10.1002/14651858.CD009230.pub2. PMID: 25087165. Study covered in a systematic review.25087165
Tarrier N, Barrowclough C, Vaughn C, . The community management of schizophrenia: a controlled trial of a behavioural intervention with families to reduce relapse. Br J Psychiatry. 1988 Oct;153:532–42. doi: 10.1192/bjp.153.4.532. PMID: 3074860. Study covered in a systematic review.3074860
Tarrier N, Barrowclough C, Vaughn C, . Community management of schizophrenia: a two-year follow-up of a behavioral intervention with families. Br J Psychiatry. 1989 May;154:625–8. doi: 10.1192/bjp.154.5.625. PMID: 2597854. Study covered in a systematic review.2597854
Tarrier N, Beckett R, Harwood S, . A trial of two cognitive-behavioural methods of treating drug-resistant residual psychotic symptoms in schizophrenic patients: I. Outcome. Br J Psychiatry. 1993 Apr;162:524–32. doi: 10.1192/bjp.162.4.524. PMID: 8481745. Study covered in a systematic review.8481745
Tarrier N, Kinney C, McCarthy E, . Two-year follow-up of cognitive--behavioral therapy and supportive counseling in the treatment of persistent symptoms in chronic schizophrenia. J Consult Clin Psychol. 2000 Oct;68(5):917–22. PMID: 11068978. Study covered in a systematic review.11068978
Tarrier N, Kinney C, McCarthy E, . Are some types of psychotic symptoms more responsive to cognitive-behavior therapy? Behav Cogn Psychother. 2001 Jan;29(1):45–55. doi: 10.1017/S1352465801001060. Study covered in a systematic review.
Tarrier N, Sharpe L, Beckett R, . A trial of two cognitive behavioural methods of treating drug-resistant residual psychotic symptoms in schizophrenic patients. II. Treatment-specific changes in coping and problem-solving skills. Soc Psychiatry Psychiatr Epidemiol. 1993 Feb;28(1):5–10. PMID: 8096654. Study design not included in review.8096654
Tarrier N, Wykes T. Is there evidence that cognitive behaviour therapy is an effective treatment for schizophrenia? A cautious or cautionary tale? Behav Res Ther. 2004 Dec;42(12):1377–401. PMID: 15500811. Not a study.15500811
Tas C, Danaci AE, Cubukcuoglu Z, . Impact of family involvement on social cognition training in clinically stable outpatients with schizophrenia -- a randomized pilot study. Psychiatry Res. 2012 Jan 30;195(1–2):32–8. doi: 10.1016/j.psychres.2011.07.031. PMID: 21831453. Interventions evaluated in a single study.21831453
Tauber R, Wallace CJ, Lecomte T. Enlisting indigenous community supporters in skills training programs for persons with severe mental illness. Psychiatr Serv. 2000 Nov;51(11):1428–32. doi: 10.1176/appi.ps.51.11.1428. PMID: 11058191. Comparator not included in review.11058191
Telles C, Karno M, Mintz J, . Immigrant families coping with schizophrenia. Behavioral family intervention v. case management with a low-income Spanish-speaking population. Br J Psychiatry. 1995 Oct;167(4):473–9. PMID: 8829715 Study covered in a systematic review.8829715
Temple S, Ho BC. Cognitive therapy for persistent psychosis in schizophrenia: a case-controlled clinical trial. Schizophr Res. 2005 May 1;74(2–3):195–9. PMID: 15721999. Study design not included in review.15721999
Terzian E, Tognoni G, Bracco R, . Social network intervention in patients with schizophrenia and marked social withdrawal: a randomized controlled study. Can J Psychiatry. 2013 Nov;58(11):622–31. PMID: 24246433. Interventions evaluated in a single study.24246433
Tharyan P, Adams CE. Electroconvulsive therapy for schizophrenia. Cochrane Database Syst Rev. 2009 (4)PMID: 15846598. Intervention not included in review.15846598
The University of Texas Health Science Center at San Antonio. Cognitive adaptive training for improving medication adherence, symptoms, and function in people with schizophrenia ClinicalTrials.gov. 2015. Study covered in a systematic review.
Thomas N, Farhall J, Foley F, . Randomised controlled trial of a digitally assisted low intensity intervention to promote personal recovery in persisting psychosis: SMART-Therapy study protocol. BMC Psychiatry Vol 16 2016, ArtID 312. 2016 Dec;16 PMID: 27604363. Not a study.27604363
Thomas N, Shawyer F, Castle DJ, . A randomised controlled trial of acceptance and commitment therapy (ACT) for psychosis: study protocol. BMC Psychiatry. 2014;14 (1)PMID: 25015368. Study design not included in review.25015368
Thorsen AL, Johansson K, Loberg E-M. Neurobiology of cognitive remediation therapy for schizophrenia: a systematic review. Front Psychiatry. 2014 Aug;5:103. PMID: 25177300. Outcome not included in review.25177300
Thorup A, Albert N, Bertelsen M, . Gender differences in first-episode psychosis at 5-year follow-up--two different courses of disease? Results from the OPUS study at 5-year follow-up. Eur Psychiatry. 2014 Jan;29(1):44–51. PMID: 23394824. Study design not included in review.23394824
Thorup A, Petersen L, Jeppesen P, . Integrated treatment ameliorates negative symptoms in first episode psychosis--results from the Danish OPUS trial. Schizophr Res. 2005 Nov 1;79(1):95–105. PMID: 16122909. Study covered in a systematic review.16122909
Thorup A, Petersen L, Jeppesen P, . Social network among young adults with first-episode schizophrenia spectrum disorders: results from the Danish OPUS trial. Soc Psychiatry Psychiatr Epidemiol. 2006 Oct;41(10):761–70. PMID: 16900304. Study covered in a systematic review.16900304
Tomaras V, Mavreas V, Economou M, . The effect of family intervention on chronic schizophrenics under individual psychosocial treatment: a 3-year study. Soc Psychiatry Psychiatr Epidemiol. 2000 Nov;35(11):487–93. PMID: 11197923. Sample size too small (<50).11197923
Tonin FS, Piazza T, Wiens A, . Adverse events and treatment failure leading to discontinuation of recently approved antipsychotic drugs in schizophrenia: a network meta-analysis. Schizophr Res. 2015 Dec;169(1–3):483–5. doi: 10.1016/j.schres.2015.09.019. PMID: 26516102. Study design not included in review.26516102
Trapp W, Landgrebe M, Hoesl K, . Cognitive remediation improves cognition and good cognitive performance increases time to relapse - results of a 5 year catamnestic study in schizophrenia patients. BMC Psychiatry. 2013 Jul;13doi: 10.1186/1471-244X-13-184. PMID: 23837673. Comparator not included in review.23297686
Trower P, Birchwood M, Meaden A, . Cognitive therapy for command hallucinations: randomised controlled trial. Br J Psychiatry. 2004 Apr;184:312–20. PMID: 15056575. Study covered in a systematic review.15056575
Tsang HW, Chan A, Wong A, . Vocational outcomes of an integrated supported employment program for individuals with persistent and severe mental illness. J Behav Ther Exp Psychiatry. 2009 Jun;40(2):292–305. doi: 10.1016/j.jbtep.2008.12.007. PMID: 19154992. Study covered in a systematic review.19154992
Tsang HW, Pearson V. Work-related social skills training for people with schizophrenia in Hong Kong. Schizophr Bull. 2001;27(1):139–48. PMID: 11215542. Country not eligible.11215542
Tsapakis EM, Dimopoulou T, Tarazi FI. Clinical management of negative symptoms of schizophrenia: an update. Pharmacol Ther. 2015 Sep;153:135–47. doi: 10.1016/j.pharmthera.2015.06.008. PMID: 26116809. Not a study.26116809
Tsuboi T, Bies RR, Suzuki T, . Hyperprolactinemia and estimated dopamine D2 receptor occupancy in patients with schizophrenia: analysis of the CATIE data. Prog Neuropsychopharmacol Biol Psychiatry. 2013;45:178–82. PMID: 23727135. Study design not included in review.23727135
Tsuboi T, Suzuki T, Bies RR, . Challenging the need for sustained blockade of dopamine D2 receptor estimated from antipsychotic plasma levels in the maintenance treatment of schizophrenia: a single-blind, randomized, controlled study. Schizophr Res. 2015 May;164(1–3):149–54. doi: 10.1016/j.schres.2015.03.025. PMID: 25864950. Study design not included in review.25864950
Turkington D, Kingdon D, Rathod S, . Outcomes of an effectiveness trial of cognitive-behavioural intervention by mental health nurses in schizophrenia. Br J Psychiatry. 2006 Jul;189:36–40. PMID: 16816304. Not a study.16816304
Turkington D, Sensky T, Scott J, . A randomized controlled trial of cognitive-behavior therapy for persistent symptoms in schizophrenia: a five-year follow-up. Schizophr Res. 2008 Jan;98(1–3):1–7. PMID: 17936590. Study design not included in review.17936590
Twamley EW, Jeste DV, Bellack AS. A review of cognitive training in schizophrenia. Schizophr Bull. 2003;29(2):359–82. PMID: 14552510. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.14552510
Twamley EW, Jeste DV, Lehman AF. Vocational rehabilitation in schizophrenia and other psychotic disorders: a literature review and meta-analysis of randomized controlled trials. J Nerv Ment Dis. 2003 Aug;191(8):515–23. PMID: 12972854. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.12972854
Twamley EW, Narvaez JM, Becker DR, . Supported employment for middle-aged and older people with schizophrenia. Am J Psychiatr Rehabil. 2008 Jan–Mar;11(1):76–89. doi: 10.1080/15487760701853326. PMID: 19212460. Study covered in a systematic review.19212460
Twamley EW, Padin DS, Bayne KS, . Work rehabilitation for middle-aged and older people with schizophrenia: a comparison of three approaches. J Nerv Ment Dis. 2005 Sep;193(9):596–601. doi: 10.1097/01.nmd.0000177789.53840.e3. PMID: 16131942. Study design not included in review.16131942
Twamley EW, Vella L, Burton CZ, . The efficacy of supported employment for middle-aged and older people with schizophrenia. Schizophr Res. 2012 Mar;135(1–3):100–4. doi: 10.1016/j.schres.2011.11.036. PMID: 22197080. Comparator not included in review.22197080
Ulrich G, Houtmans T, Gold C. The additional therapeutic effect of group music therapy for schizophrenic patients: a randomized study. Acta Psychiatr Scand. 2007 Nov;116(5):362–70. PMID: 17919155. Intervention not included in review.17919155
University of California LA. Supported employment and skills training in conjunction with pharmacotherapy in schizophrenia patients. ClinicalTrials.gov. 2005. Study covered in a systematic review.
VA Office of Research and Development. Mindfulness meditation as a rehabilitation strategy for persons with schizophrenia. ClinicalTrials.gov. 2015. Intervention not included in review.
VA Office of Research and Development. Cognitive rehabilitation in schizophrenia ClinicalTrials.gov. 2016. Comparator not included in review.
VA Office of Research and Development. Remediation of working memory in schizophrenia. ClinicalTrials.gov. 2016. Comparator not included in review.
VA Office of Research and Development. The use of skills training to augment compensated work therapy (CWT)/VI for veterans with SMI (MPROVE). ClinicalTrials.gov. 2016. Comparator not included in review.
Valencia M, Caraveo J, Colin R, . Symptomatic remission and functional recovery in patients suffering from schizophrenia. Salud Ment. 2014 Jan–Feb;37(1):59–74. Not English language.
Valencia M, Moriana JA, Kopelowicz A, . Social-skills training for Spanish-speaking persons with schizophrenia: experiences from Latin America, Spain, and the United States. Am J Psychiatr Rehabil. 2015 Jul;18(3):209–46. Not a study.
Valimaki M, Athanasopoulou C, Lahti M, . Effectiveness of social media interventions for people with schizophrenia: a systematic review and meta-analysis. J Med Internet Res. 2016 Apr 22;18(4):e92. doi: 10.2196/jmir.5385. PMID: 27105939. Intervention not included in review.27105939
Valimaki M, Hatonen H, Lahti M, . Information and communication technology in patient education and support for people with schizophrenia. Cochrane Database Syst Rev. 2012 Oct 17;10:Cd007198. doi: 10.1002/14651858.CD007198.pub2. PMID: 23076932. Intervention not included in review.23076932
Valmaggia LR, van der Gaag M, Tarrier N, . Cognitive-behavioural therapy for refractory psychotic symptoms of schizophrenia resistant to atypical antipsychotic medication. Randomised controlled trial. Br J Psychiatry. 2005 Apr;186:324–30. PMID: 15802690. Study covered in a systematic review.15802690
van den Brink R, Wiersma D, Wolters K, . Non-uniform effectiveness of structured patient-clinician communication in community mental healthcare: an international comparison. Soc Psychiatry Psychiatr Epidemiol. 2011 Aug;46(8):685–93. PMID: 20490455. Interventions evaluated in a single study.20490455
van der Gaag M, Nieman DH, Rietdijk J, . Cognitive behavioral therapy for subjects at ultrahigh risk for developing psychosis: a randomized controlled clinical trial. Schizophr Bull. 2012 Nov;38(6):1180–8. doi: 10.1093/schbul/sbs105. PMID: 22941746. Population ineligible for review.22941746
van der Gaag M, van Oosterhout B, Daalman K, . Initial evaluation of the effects of competitive memory training (COMET) on depression in schizophrenia-spectrum patients with persistent auditory verbal hallucinations: a randomized controlled trial. Br J Clin Psychol. 2012 Jun;51(2):158–71. doi: 10.1111/j.2044-8260.2011.02025.x. PMID: 22574801. Outcome not included in review.22574801
van Oosterhout B, Krabbendam L, de Boer K, . Metacognitive group training for schizophrenia spectrum patients with delusions: a randomized controlled trial. Psychol Med. 2014 Oct;44(14):3025–35. doi: 10.1017/S0033291714000555. PMID: 25066223. Interventions evaluated in a single study.25066223
Vancampfort D, Vansteelandt K, Scheewe T, . Yoga in schizophrenia: a systematic review of randomised controlled trials. Acta Psychiatr Scand. 2012 Jul;126(1):12–20. doi: 10.1111/j.1600-0447.2012.01865.x. PMID: 22486714. Intervention not included in review.22486714
Vaughan K, Doyle M, McConaghy N, . The Sydney intervention trial: a controlled trial of relatives’ counselling to reduce schizophrenic relapse. Soc Psychiatry Psychiatr Epidemiol. 1992 Jan;27(1):16–21. doi: 10.1007/BF00788951. PMID: 1557677. Study covered in a systematic review.1557677
Vauth R, Corrigan PW, Clauss M, . Cognitive strategies versus self-management skills as adjunct to vocational rehabilitation. Schizophr Bull. 2005 Jan;31(1):55–66. PMID: 15888425. Comparator not included in review.15888425
Vazquez Perez ML, Godoy-Izquierdo D, Godoy JF. Clinical outcomes of a coping with stress training program among patients suffering from schizophrenia and schizoaffective disorder: a pilot study. Anxiety Stress Coping. 2013 Mar;26(2):154–70. PMID: 22300334. Interventions evaluated in a single study.22300334
Velligan DI, Bow-Thomas CC, Huntzinger C, . Randomized controlled trial of the use of compensatory strategies to enhance adaptive functioning in outpatients with schizophrenia. Am J Psychiatry. 2000 Aug;157(8):1317–23. PMID: 10910797. Sample size too small (<50).10910797
Velligan DI, Prihoda TJ, Ritch JL, . A randomized single-blind pilot study of compensatory strategies in schizophrenia outpatients. Schizophr Bull. 2002;28(2):283–92. PMID: 12693434. Study design not included in review.12693434
Velligan DI, Roberts D, Mintz J, . A randomized pilot study of MOtiVation and Enhancement (MOVE) Training for negative symptoms in schizophrenia. Schizophr Res. 2015 Jul;165(2–3):175–80. doi: 10.1016/j.schres.2015.04.008. PMID: 25937461. Interventions evaluated in a single study.25937461
Veltro F, Mazza M, Vendittelli N, . A comparison of the effectiveness of problem solving training and of cognitive-emotional rehabilitation on neurocognition, social cognition and social functioning in people with schizophrenia. Clin Pract Epidemiol Ment Health. 2011;7:123–32. PMID: 21792373. Comparator not included in review.21792373
Vera-Garcia E, Mayoral-Cleries F, Vancampfort D, . A systematic review of the benefits of physical therapy within a multidisciplinary care approach for people with schizophrenia: an update. Psychiatry Res. 2015 Oct 30;229(3):828–39. doi: 10.1016/j.psychres.2015.07.083. PMID: 26254795. Intervention not included in review.26254795
Vesterager L, Christensen T, Olsen B, . Cognitive remediation combined with a comprehensive psychosocial program for patients with first episode schizophrenia: The neuro com trial. Schizophr Bull. 2013;39(21). Not a study.
Vesterager L, Christensen TO, Olsen BB, . Cognitive training plus a comprehensive psychosocial programme (OPUS) versus the comprehensive psychosocial programme alone for patients with first-episode schizophrenia (the NEUROCOM trial): a study protocol for a centrally randomised, observer-blinded multi-centre clinical trial. Trials. 2011;12:35. doi: 10.1186/1745-6215-12-35. PMID: 21306612. Not a study.21306612
Victoroff J, Coburn K, Reeve A, . Pharmacological management of persistent hostility and aggression in persons with schizophrenia spectrum disorders: a systematic review. J Neuropsychiatry Clin Neurosci. 2014;26(4):283–312. doi: 10.1176/appi.neuropsych.13110335. PMID: 26037853. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.26037853
Visceglia E, Lewis S. Yoga therapy as an adjunctive treatment for schizophrenia: a randomized, controlled pilot study. J Altern Complement Med. 2011 Jul;17(7):601–7. doi: 10.1089/acm.2010.0075. PMID: 21711202. Inadequate duration (<12 weeks).21711202
Vita A, Cocchi A, Contini A, . Applicazione multicentrica del metodo riabilitativo strutturato IPT (Terapia Psicologica Integrata) per pazienti schizofrenici. Psichiatr Oggi. 2002:11–8. Not English language.
Vita A, De Peri L, Barlati S, . Psychopathologic, neuropsychological and functional outcome measures during cognitive rehabilitation in schizophrenia: a prospective controlled study in a real-world setting. Eur Psychiatry. 2011 Jul–Aug;26(5):276–83. doi: 10.1016/j.eurpsy.2010.03.008. PMID: 20561768. Study covered in a systematic review.20561768
Volavka J, Czobor P, Citrome L, . Effectiveness of antipsychotic drugs against hostility in patients with schizophrenia in the Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) study.[Erratum appears in CNS Spectr. 2014 Oct;19(5):466]. Cns Spectrums. 2014 Oct;19(5):374–81. doi: 10.1017/S1092852913000849. PMID: 24284234. Outcome not included in review.24284234
Vreeland B, Minsky S, Yanos PT, . Efficacy of the team solutions program for educating patients about illness management and treatment. Psychiatric Serv. 2006 Jun;57(6):822–8. PMID: 16754759. Study covered in a systematic review.16754759
Wang L, Zhou J, Yu X, . Psychosocial rehabilitation training in the treatment of schizophrenia outpatients: a randomized, psychosocial rehabilitation training-and monomedication-controlled study. Pak J Med Sci. 2013;29(2):597–600. PMID: 24353585. Interventions evaluated in a single study.24353585
Wang L-Q, Chien WT, Yip LK, . A randomized controlled trial of a mindfulness-based intervention program for people with schizophrenia: 6-month follow-up. Neuropsychiatr Dis Treat. 2016 Dec;12 PMID: 27994466. Intervention not included in review.27994466
Weiden PJ, Citrome L, Alva G, . A trial evaluating gradual- or immediate-switch strategies from risperidone, olanzapine, or aripiprazole to iloperidone in patients with schizophrenia. Schizophr Res. 2014 Mar;153(1–3):160–8. doi: 10.1016/j.schres.2013.11.042. PMID: 24529610. Study design not included in review.24529610
Weisman de Mamani A, Weintraub MJ, Gurak K, . A randomized clinical trial to test the efficacy of a family-focused, culturally informed therapy for schizophrenia. J Fam Psychol. 2014 Dec;28(6):800–10. doi: 10.1037/fam0000021. PMID: 25286175. Comparator not included in review.25286175
Widschwendter CG, Karayal ON, Kolluri S, . Relating spontaneously reported extrapyramidal adverse events to movement disorder rating scales. Int J Neuropsychopharmacol. 2015;18(12):1–6. PMID: 26116494. Study design not included in review.26116494
Wiedemann G, Hahlweg K, Muller U, . Effectiveness of targeted intervention and maintenance pharmacotherapy in conjunction with family intervention in schizophrenia. Eur Arch Psychiatry Clin Neurosci. 2001;251(2):72–84. PMID: 11407442. Study covered in a systematic review.11407442
Wiersma D, Jenner JA, Nienhuis FJ, . Hallucination focused integrative treatment improves quality of life in schizophrenia patients. Acta Psychiatr Scand. 2004 Mar;109(3):194–201. PMID: 14984391. Interventions evaluated in a single study.14984391
Wobrock T, Guse B, Cordes J, . Left prefrontal high-frequency repetitive transcranial magnetic stimulation for the treatment of schizophrenia with predominant negative symptoms: a sham-controlled, randomized multicenter trial. Biol Psychiatry. 2015 Jun 1;77(11):979–88. doi: 10.1016/j.biopsych.2014.10.009. PMID: 25582269. Intervention not included in review.25582269
Wood L, Burke E, Morrison A. Individual cognitive behavioural therapy for psychosis (CBTp): a systematic review of qualitative literature. Behav Cogn Psychother. 2015 May;43(3):285–97. doi: 10.1017/S1352465813000970. PMID: 24308817. Study design not included in review.24308817
Wood L, Byrne R, Varese F, . Psychosocial interventions for internalised stigma in people with a schizophrenia-spectrum diagnosis: a systematic narrative synthesis and meta-analysis. Schizophr Res. 2016 May:291–303. doi: 10.1016/j.schres.2016.05.001. PMID: 27256518. Outcome not included in review.27256518
Wykes T, Hayward P, Thomas N, . What are the effects of group cognitive behaviour therapy for voices? A randomised control trial. Schizophr Res. 2005 Sep 15;77(2–3):201–10. PMID: 15885983. Study covered in a systematic review.15885983
Wykes T, Huddy V. Cognitive remediation for schizophrenia: it is even more complicated. Curr Opin Psychiatry. 2009 Mar;22(2):161–7. doi: 10.1097/YCO.0b013e328322fbf4. PMID: 19553870. Not a study.19553870
Wykes T, Reeder C, Landau S, . Cognitive remediation therapy in schizophrenia: randomised controlled trial. Br J Psychiatry. 2007 May;190:421–7. PMID: 17470957. Study covered in a systematic review.17470957
Wykes T, Reeder C, Williams C, . Are the effects of cognitive remediation therapy (CRT) durable? Results from an exploratory trial in schizophrenia. Schizophr Res. 2003 Jun 1;61(2–3):163–74. PMID: 12729868. Study covered in a systematic review.12729868
Wykes T, Steel C, Everitt B, . Cognitive behavior therapy for schizophrenia: effect sizes, clinical models, and methodological rigor. Schizophr Bull. 2008 May;34(3):523–37. PMID: 17962231. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.17962231
Wykes T, Thompson N, Green N, . Changing voices: a randomised control trial of group cognitive behavioural treatment. Schizophr Res. 2003 3/15/;60(1, Supplement):331. doi: 10.1016/S0920-9964(03)80310-9. Study covered in a systematic review.
Xia J, Grant TJ. Dance therapy for schizophrenia. Cochrane Database Syst Rev. 2009 Jan 21(1):Cd006868. doi: 10.1002/14651858.CD006868.pub2. PMID: 19160306. Intervention not included in review.19160306
Xia J, Li C. Problem solving skills for schizophrenia. Cochrane Database Syst Rev. 2007(2):CD006365. PMID: 17443621. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.17443621
Xia J, Li C. Problem solving skills for schizophrenia. Cochrane Database Syst Rev. 2012 Apr 18(2):Cd006365. doi: 10.1002/14651858.CD006365.pub2. PMID: 17443621. Systematic review/meta-analysis used as a source document to identify individual studies.17443621
Xia J, Merinder BL, Belgamwar MR. Psychoeducation for schizophrenia. Cochrane Database Syst Rev. 2013 (1)PMID: 21678337. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.21678337
Xia J, Merinder LB, Belgamwar MR. Psychoeducation for schizophrenia. Schizophr Bull. 2011 Jan;37(1):21–2. doi: 10.1093/schbul/sbq138. PMID: 21147896. Setting ineligible for review (i.e., inpatient only).21147896
Xia J, Merinder LB, Belgamwar MR. Psychoeducation for schizophrenia. Cochrane Database Syst Rev. 2011 Jun 15(6):CD002831. doi: 10.1002/14651858.CD002831.pub2. PMID: 21678337. Setting ineligible for review (i.e., inpatient only).21678337
Xiang M, Ran M, Li S. A controlled evaluation of psychoeducational family intervention in a rural Chinese community. Br J Psychiatry. 1994 Oct;165(4):544–8. doi: 10.1192/bjp.165.4.544. PMID: 7804673. Study covered in a systematic review.7804673
Xiang Y, Weng Y, Li W, . Training patients with schizophrenia with the community re-entry module: a controlled study. Soc Psychiatry Psychiatr Epidemiol. 2006 Jun;41(6):464–9. PMID: 16565915. Comparator not included in review.16565915
Yildiz M, Veznedaroglu B, Eryavuz A, . Psychosocial skills training on social functioning and quality of life in the treatment of schizophrenia: a controlled study in Turkey. Int J Psychiatry Clin Pract. 2004 Dec;8(4):219–25. doi: 10.1080/13651500410005595. PMID: 24930550. Intervention not included in review.24930550
Yung AR, Phillips LJ, Nelson B, . Randomized controlled trial of interventions for young people at ultra high risk for psychosis: 6-month analysis. J Clin Psychiatry. 2011 Apr;72(4):430–40. doi: 10.4088/JCP.08m04979ora. PMID: 21034687. Population ineligible for review.21034687
Zanello A, Mohr S, Merlo MC, . Effectiveness of a brief group cognitive behavioral therapy for auditory verbal hallucinations: a 6-month follow-up study. J Nerv Ment Dis. 2014 Feb;202(2):144–53. doi: 10.1097/NMD.0000000000000084. PMID: 24469527. Not a study.24469527
Zastowny TR, Lehman AF, Cole RE, . Family management of schizophrenia: a comparison of behavioral and supportive family treatment. Psychiatr Q. 1992;63(2):159–86. PMID: 1488460. Comparator not included in review.1488460
Zhang J-P, Gallego JA, Robinson DG, . Efficacy and safety of individual second-generation vs. first generation antipsychotics in first-episode psychosis: a systematic review and meta-analysis. Int J Neuropsychopharmacol. 2013 Jul;16(6):1205–18. doi: 10.1017/S1461145712001277. PMID: 23199972. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.23199972
Zhang M, Wang M, Li J, . Randomised-control trial of family intervention for 78 first-episode male schizophrenic patients: an 18-month study in Suzhou, Jiangsu. Br J Psychiatry. 1994 Aug;165(Suppl 24):96–102. PMID: 7946238. Study covered in a systematic review.7946238
Zhang S, Lan G. Prospective 8-week trial on the effect of olanzapine, quetiapine, and aripiprazole on blood glucose and lipids among individuals with first-onset schizophrenia. Shanghai Arch Psychiatry. 2014 Dec;26(6):339–46. PMID: 25642108. Study covered in a systematic review.25642108
Zhao J, Song X, Ai X, . Adjunctive aripiprazole treatment for risperidone-induced hyperprolactinemia: an 8-week randomized, open-label, comparative clinical trial. PLoS One. 2015;10 (10)PMID: 26448615. Study design not included in review.26448615
Zhao S, Sampson S, Xia J, . Psychoeducation (brief) for people with serious mental illness. Cochrane Database Syst Rev. 2015 Apr 09(4):Cd010823. doi: 10.1002/14651858.CD010823.pub2. PMID: 25854522. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.25854522
Zimmermann G, Favrod J, Trieu VH, . The effect of cognitive behavioral treatment on the positive symptoms of schizophrenia spectrum disorders: a meta-analysis. Schizophr Res. 2005 Sep 1;77(1):1–9. PMID: 16005380. Excluded due to including a review that was more recent, more comprehensive, or had a more similar scope to this review scope.16005380
Zygmunt A, Olfson M, Boyer CA, . Interventions to improve medication adherence in schizophrenia. Am J Psychiatry. 2002 Oct;159(10):1653–64. PMID: 12359668. Outcome not included in review.12359668