# Appendix B Included Studies

1 Abou-Setta AM, Mousavi SS, Spooner C, . First-generation versus second-generation antipsychotics in adults: comparative effectiveness. Comparative effectiveness review No. 63. (Prepared by the University of Alberta Evidence-based Practice Center under Contract No. 290-200-10021.) AHRQ Publication No. 12-EHC054-EF. Rockville, MD: Agency for Healthcare Research and Quality: 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm Accessed April 22, 2017. PMID: 2303527523035275.
2 Amr M, Lakhan SE, Sanhan S, . Efficacy and tolerability of quetiapine versus haloperidol in first-episode schizophrenia: a randomized clinical trial. Int Arch Med. 2013;6 (1)PMID: 24308507.24308507
3 Arnold JG, Miller AL, Canive JM, . Comparison of outcomes for African Americans, Hispanics, and non-Hispanic whites in the CATIE study. Psychiatr Serv. 2013;64(6):570–8. PMID: 23494108.23494108
4 Barrowclough C, Tarrier N, Lewis S, . Randomised controlled effectiveness trial of a needs-based psychosocial intervention service for carers of people with schizophrenia. Br J Psychiatry. 1999 Jun;174:505–11. PMID: 10616628.10616628
5 Bartels SJ, Pratt SI, Mueser KT, . Long-term outcomes of a randomized trial of integrated skills training and preventive healthcare for older adults with serious mental illness. Am J Geriatr Psychiatry. 2014 Nov;22(11):1251–61. doi: 10.1016/j.jagp.2013.04.013. PMID: 23954039.23954039
6 Bertelsen M, Jeppesen P, Petersen L, . Course of illness in a sample of 265 patients with first-episode psychosis—five-year follow-up of the Danish OPUS trial. Schizophr Res. 2009;107(2–3):173–8. doi: 10.1016/j.schres.2008.09.018. PMID: 18945593.18945593
7 Bjorkman T, Hansson L, Sandlund M. Outcome of case management based on the strengths model compared to standard care. A randomised controlled trial. Soc Psychiatry Psychiatr Epidemiol. 2002 Apr;37(4):147–52. PMID: 12027240.12027240
8 Buckley LA, Maayan N, Soares-Weiser K, . Supportive therapy for schizophrenia. Cochrane Database Syst Rev. 2015 Apr 14(4):Cd004716. doi: 10.1002/14651858.CD004716.pub4. PMID: 25871462.25871462
9 Caroff SN, Davis VG, Miller DD, . Treatment outcomes of patients with tardive dyskinesia and chronic schizophrenia. J Clin Psychiatry. 2011 Mar;72(3):295–303. doi: 10.4088/JCP.09m05793yel. PMID: 20816031.20816031
10 Cella M, Preti A, Edwards C, . Cognitive remediation for negative symptoms of schizophrenia: A network meta-analysis. Clin Psychol Rev. 2017 Mar;52:43–51. doi: 10.1016/j.cpr.2016.11.009. PMID: 27930934.27930934
11 Citrome L, Ota A, Nagamizu K, . The effect of brexpiprazole (OPC-34712) and aripiprazole in adult patients with acute schizophrenia: results from a randomized, exploratory study. Int Clin Psychopharmacol. 2016 Jul;31(4):192–201. doi: 10.1097/yic.0000000000000123. PMID: 26963842.26963842
12 Cook JA, Blyler CR, Burke-Miller JK, . Effectiveness of supported employment for individuals with schizophrenia: results of a multi-site, randomized trial. Clin Schizophr Relat Psychoses. 2008;2(1):37–46.
13 Cook JA, Leff HS, Blyler CR, . Results of a multisite randomized trial of supported employment interventions for individuals with severe mental illness. Arch Gen Psychiatry. 2005 May;62(5):505–12. PMID: 15867103.15867103
14 Craig TK, Garety P, Power P, . The Lambeth Early Onset (LEO) team: randomised controlled trial of the effectiveness of specialised care for early psychosis. BMJ. 2004 Nov 6;329(7474):1067. doi: 10.1136/bmj.38246.594873.7C. PMID: 15485934.16.15485934
15 Crespo-Facorro B, Perez-Iglesias R, Mata I, . Effectiveness of haloperidol, risperidone and olanzapine in the treatment of first-episode non-affective psychosis: results of a randomized, flexible-dose, open-label 1-year follow-up comparison. J Psychopharmacol. 2011 Jun;25(6):744–54. PMID: 21292922.21292922
16 Deste G, Barlati S, Cacciani P, . Persistence of effectiveness of cognitive remediation interventions in schizophrenia: a 1-year follow-up study. Schizophr Res. 2015 Feb;161(2–3):403–6. doi: 10.1016/j.schres.2014.12.004. PMID: 25533593.25533593
17 Detke HC, Weiden PJ, Llorca PM, . Comparison of olanzapine long-acting injection and oral olanzapine: a 2-year, randomized, open-label study in outpatients with schizophrenia. J Clin Psychopharmacol. 2014 Aug;34(4):426–34. doi: 10.1097/JCP.0000000000000140. PMID: 24781441.24781441
18 Di Fiorino M, Montagnani G, Trespi G, . Extended-release quetiapine fumarate (quetiapine XR) versus risperidone in the treatment of depressive symptoms in patients with schizoaffective disorder or schizophrenia: a randomized, open-label, parallel-group, flexible-dose study. Int Clin Psychopharmacol. 2014 May;29(3):166–76. doi: 10.1097/YIC.0000000000000017. PMID: 24681810.24681810
19 Durgam S, Starace A, Li D, . An evaluation of the safety and efficacy of cariprazine in patients with acute exacerbation of schizophrenia: a phase II, randomized clinical trial. Schizophr Res. 2014 Feb;152(2–3):450–7. doi: 10.1016/j.schres.2013.11.041. PMID: 24412468.24412468
20 Dyck DG, Short RA, Hendryx MS, . Management of negative symptoms among patients with schizophrenia attending multiple-family groups. Psychiatr Serv. 2000 Apr;51(4):513–9. PMID: 10737828.10737828
21 Farreny A, Aguado J, Ochoa S, . REPYFLEC cognitive remediation group training in schizophrenia: looking for an integrative approach. Schizophr Res. 2012 Dec;142(1–3):137–44. doi: 10.1016/j.schres.2012.08.035. PMID: 23017827.23017827
22 Fervaha G, Agid O, Takeuchi H, . Effect of antipsychotic medication on overall life satisfaction among individuals with chronic schizophrenia: findings from the NIMH CATIE study. Eur Neuropsychopharmacol. 2014 Jul;24(7):1078–85. doi: 10.1016/j.euroneuro.2014.03.001. PMID: 24726579.24726579
23 Fleischhacker WW, Sanchez R, Perry PP, . Aripiprazole once-monthly for treatment of schizophrenia: double-blind, randomised, non-inferiority study. Br J Psychol. 2014 Aug;205(2):135–44. doi: 10.1192/bjp.bp.113.134213. PMID: 24925984.24925984
24 Freeman D, Dunn G, Startup H, . Effects of cognitive behaviour therapy for worry on persecutory delusions in patients with psychosis (WIT): a parallel, single-blind, randomised controlled trial with a mediation analysis. Lancet Psychiatry. 2015;2(4):305–13. PMID: 26360083.26360083
25 Garety PA, Craig TK, Dunn G, . Specialised care for early psychosis: symptoms, social functioning and patient satisfaction: randomised controlled trial. Br J Psychiatry. 2006 Jan;188:37–45. doi: 10.1192/bjp.bp.104.007286. PMID: 16388068.16388068
26 Garety PA, Fowler DG, Freeman D, . Cognitive--behavioural therapy and family intervention for relapse prevention and symptom reduction in psychosis: randomised controlled trial. Br J Psychiatry. 2008 Jun;192(6):412–23. doi: 10.1192/bjp.bp.107.043570. PMID: 18515890.18515890
27 Green AI, Brunette MF, Dawson R, . Long-acting injectable vs oral risperidone for schizophrenia and co-occurring alcohol use disorder: a randomized trial. J Clin Psychiatry. 2015 Oct;76(10):1359–65. doi: 10.4088/JCP.13m08838. PMID: 26302441.26302441
28 Guo X, Zhai J, Liu Z, . Effect of antipsychotic medication alone vs combined with psychosocial intervention on outcomes of early-stage schizophrenia: a randomized, 1-year study. Arch Gen Psychiatry. 2010 Sep;67(9):895–904. doi: 10.1001/archgenpsychiatry.2010.105. PMID: 20819983.20819983
29 Guo X, Zhao J, Liu Z, . Antipsychotic combination with psychosocial intervention on outcome of schizophrenia (acpios): rationale and design of the clinical trial. Clin Schizophr Relat Psychoses. 2007;1(2):185–92.
30 Hartling L, Abou-Setta AM, Dursun S, . Antipsychotics in adults with schizophrenia: comparative effectiveness of first-generation versus second-generation medications: a systematic review and meta-analysis. Ann Intern Med. 2012 Oct 2;157(7):498–511. PMID: 22893011.22893011
31 Hasson-Ohayon I, Roe D, Kravetz S. A randomized controlled trial of the effectiveness of the illness management and recovery program. Psychiatr Serv. 2007 Nov;58(11):1461–6. doi: 10.1176/ps.2007.58.11.1461. PMID: 17978257.17978257
32 Hunt GE, Siegfried N, Morley K, . Psychosocial interventions for people with both severe mental illness and substance misuse. Cochrane Database Syst Rev. 2013 Oct 03(10):Cd001088. doi: 10.1002/14651858.CD001088.pub3. PMID: 24092525.24092525
33 Ishigooka J, Nakamura J, Fujii Y, . Efficacy and safety of aripiprazole once-monthly in Asian patients with schizophrenia: a multicenter, randomized, double-blind, non-inferiority study versus oral aripiprazole. Schizophr Res. 2015 Feb;161(2–3):421–8. doi: 10.1016/j.schres.2014.12.013. PMID: 25556976.25556976
34 Jauhar S, McKenna PJ, Radua J, . Cognitive-behavioural therapy for the symptoms of schizophrenia: systematic review and meta-analysis with examination of potential bias. Br J Psychiatry. 2014 Jan;204(1):20–9. doi: 10.1192/bjp.bp.112.116285. PMID: 24385461.24385461
35 Jones C, Hacker D, Cormac I, . Cognitive behavioural therapy versus other psychosocial treatments for schizophrenia. Cochrane Database Syst Rev. 2012 Apr 18(4):Cd008712. doi: 10.1002/14651858.CD008712.pub2. PMID: 22513966.22513966
36 Kane JM, Robinson DG, Schooler NR, . Comprehensive versus usual community care for first-episode psychosis: 2-year outcomes from the NIMH RAISE early treatment program. Am J Psychiatry. 2016 Apr 1;173(4):362–72. doi: 10.1176/appi.ajp.2015.15050632. PMID: 26481174.26481174
37 Kane JM, Schooler NR, Marcy P, . The RAISE early treatment program for first-episode psychosis: background, rationale, and study design. J Clin Psychiatry. 2015 Mar;76(3):240–6. doi: 10.4088/JCP.14m09289. PMID: 25830446.25830446
38 Kinoshita Y, Furukawa TA, Kinoshita K, . Supported employment for adults with severe mental illness. Cochrane Database Syst Rev. 2013 Sep 13(9):Cd008297. doi: 10.1002/14651858.CD008297.pub2. PMID: 24030739.24030739
39 Kopelowicz A, Zarate R, Wallace CJ, . The ability of multifamily groups to improve treatment adherence in Mexican Americans with schizophrenia. Arch Gen Psychiatry. 2012 Mar;69(3):265–73. doi: 10.1001/archgenpsychiatry.2011.135. PMID: 22393219.22393219
40 Koshikawa Y, Takekita Y, Kato M, . The comparative effects of risperidone long-acting injection and paliperidone palmitate on social functioning in schizophrenia: a 6-month, open-label, randomized controlled pilot trial. Neuropsychobiology. 2016;73(1):35–42. doi: 10.1159/000442209. PMID: 2681261826812618
41 Li H, Luo J, Wang C, . Efficacy and safety of aripiprazole in Chinese Han schizophrenia subjects: a randomized, double-blind, active parallel-controlled, multicedinter clinical trial. Schizophr Res. 2014 Aug;157(1–3):112–9. doi: 10.1016/j.schres.2014.05.040. PMID: 24994555.24994555
42 Lieberman JA, Stroup TS, McEvoy JP, . Effectiveness of antipsychotic drugs in patients with chronic schizophrenia. N Engl J Med. 2005 Sep 22;353(12):1209–23. doi: 10.1056/NEJMoa051688. PMID: 16172203.16172203
43 Liu J, Sun J, Shen X, . Randomized controlled trial comparing changes in serum prolactin and weight among female patients with first-episode schizophrenia over 12 months of treatment with risperidone or quetiapine. Shanghai Arch Psychiatry. 2014;26(2):88–94. PMID: 25092954.25092954
44 Lysaker PH, Davis LW, Bryson GJ, . Effects of cognitive behavioral therapy on work outcomes in vocational rehabilitation for participants with schizophrenia spectrum disorders. Schizophr Res. 2009 Feb;107(2–3):186–91. doi: 10.1016/j.schres.2008.10.018. PMID: 19046856.19046856
45 Maat A, Cahn W, Gijsman HJ, . Open, randomized trial of the effects of aripiprazole versus risperidone on social cognition in schizophrenia. Eur Neuropsychopharmacol. 2014 Apr;24(4):575–84. PMID: 24418213.24418213
46 Malik N, Kingdon D, Pelton J, . Effectiveness of brief cognitive-behavioral therapy for schizophrenia delivered by mental health nurses: relapse and recovery at 24 months. J Clin Psychiatry. 2009 Feb;70(2):201–7. PMID: 19210949.19210949
47 Marshall M, Gray A, Lockwood A, . Case management for people with severe mental disorders. Cochrane Database Syst Rev. 2000b(2):Cd000050. doi: 10.1002/14651858.cd000050. PMID: 10796288.10796288
48 Marshall M, Lockwood A. Assertive community treatment for people with severe mental disorders. Cochrane Database Syst Rev. 2000a(2):Cd001089. doi: 10.1002/14651858.cd001089. PMID: 10796415.10796415
49 Mayoral F, Berrozpe A, de la Higuera J, . Efficacy of a family intervention program for prevention of hospitalization in patients with schizophrenia. A naturalistic multicenter controlled and randomized study in Spain. Revista de Psiquiatria y Salud Mental. 2015 Apr–Jun;8(2):83–91. doi: 10.1016/j.rpsm.2013.11.001. PMID: 25017624.25017624
50 McDonagh M, Peterson K, Fu R, . Second Generation Antipsychotic Drugs. Final Update 4 Report prepared by the Pacific Northwest Evidence-based Practice Center for the Drug Effectiveness Review Project. Oregon Health & Science University, Portland, Oregon, November 2013. 2013. Available with membership in the Drug Effectiveness Review Project. http://www.ohsu.edu/xd/research/centers-institutes/evidence-based-practice-center/drug-effectiveness-review-project/upload/SGA_final-update-4-report_Nov-2013_version-2.pdf. Accessed May 23, 2017.
51 McEvoy JP, Byerly M, Hamer RM, . Effectiveness of paliperidone palmitate vs haloperidol decanoate for maintenance treatment of schizophrenia: a randomized clinical trial. JAMA. 2014 May 21;311(19):1978–87. doi: 10.1001/jama.2014.4310. PMID: 24846035.24846035
52 Mueller DR, Schmidt SJ, Roder V. One-year randomized controlled trial and follow-up of integrated neurocognitive therapy for schizophrenia outpatients. Schizophr Bull. 2015 May;41(3):604–16. doi: 10.1093/schbul/sbu223. PMID: 25713462.25713462
53 Mueser KT, Clark RE, Haines M, . The Hartford study of supported employment for persons with severe mental illness. J Consult Clin Psychol. 2004 Jun;72(3):479–90. doi: 10.1037/0022-006x.72.3.479. PMID: 15279531.15279531
54 Mueser KT, Pratt SI, Bartels SJ, . Randomized trial of social rehabilitation and integrated health care for older people with severe mental illness. J Consult Clin Psychol. 2010 Aug;78(4):561–73. doi: 10.1037/a0019629. PMID: 20658812.20658812
55 Naber D, Hansen K, Forray C, . Qualify: a randomized head-to-head study of aripiprazole once-monthly and paliperidone palmitate in the treatment of schizophrenia. Schizophr Res. 2015;168(1–2):498–504. PMID: 2623224126232241
56 Naber D, Peuskens J, Schwarzmann N, . Subjective well-being in schizophrenia: a randomised controlled open-label 12-month non-inferiority study comparing quetiapine XR with risperidone (RECOVER). Eur Neuropsychopharmacol. 2013 Oct;23(10):1257–69. doi: 10.1016/j.euroneuro.2013.07.006. PMID: 23953270.23953270
57 Nemeth G, Laszlovszky I, Czobor P, . Cariprazine versus risperidone monotherapy for treatment of predominant negative symptoms in patients with schizophrenia: a randomised, double-blind, controlled trial. Lancet. 2017 Feb 07doi: 10.1016/s0140-6736(17)30060-0. PMID: 28185672.28185672
58 Parabiaghi A, Tettamanti M, D’Avanzo B, . Metabolic syndrome and drug discontinuation in schizophrenia: a randomized trial comparing aripiprazole olanzapine and haloperidol. Acta Psychiatr Scand. 2016;133(1):63–75. PMID: 26252780.26252780
59 Park S, Yi KK, Kim MS, . Effects of ziprasidone and olanzapine on body composition and metabolic parameters: an open-label comparative pilot study. Behav Brain Funct. 2013;9:27. doi: 10.1186/1744-9081-9-27. PMID: 23866300.23866300
60 Pekkala E, Merinder L. Psychoeducation for schizophrenia. Cochrane Database Syst Rev. 2002(2):Cd002831. doi: 10.1002/14651858.cd002831. PMID: 12076455.12076455
61 Pharoah F, Mari J, Rathbone J, . Family intervention for schizophrenia. Cochrane Database Syst Rev. 2010 Dec 08(12):CD000088. doi: 10.1002/14651858.CD000088.pub2. PMID: 21154340.21154340
62 Robinson DG, Gallego JA, John M, . A randomized comparison of aripiprazole and risperidone for the acute treatment of first-episode schizophrenia and related disorders: 3-month outcomes. Schizophr Bull. 2015;41(6):1227–36. PMID: 26338693.26338693
63 Rosenheck R, Lin H. Noninferiority of perphenazine vs. three second-generation antipsychotics in chronic schizophrenia. J Nerv Ment Dis. 2014 Jan;202(1):18–24. doi: 10.1097/NMD.0000000000000065. PMID: 24375207.24375207
64 San L, Arranz B, Perez V, . One-year, randomized, open trial comparing olanzapine, quetiapine, risperidone and ziprasidone effectiveness in antipsychotic-naive patients with a first-episode psychosis. Psychiatry Res. 2012 Dec 30;200(2–3):693–701. doi: 10.1016/j.psychres.2012.07.005. PMID: 22954905.22954905
65 Sanz-Fuentenebro J, Taboada D, Palomo T, . Randomized trial of clozapine vs. risperidone in treatment-naive first-episode schizophrenia: results after one year. Schizophr Res. 2013 Sep;149(1–3):156–61. doi: 10.1016/j.schres.2013.07.003. PMID: 23870807.23870807
66 Savitz AJ, Xu H, Gopal S, . Efficacy and safety of paliperidone palmitate 3-month formulation for patients with schizophrenia: a randomized, multicenter, double-blind, noninferiority study. Int J Neuropsychopharmacol. 2016 Jul;19(7)doi: 10.1093/ijnp/pyw018. PMID: 26902950.26902950
67 Secher RG, Hjorthoj CR, Austin SF, . Ten-year follow-up of the OPUS specialized early intervention trial for patients with a first episode of psychosis. Schizophr Bull. 2015 May;41(3):617–26. doi: 10.1093/schbul/sbu155. PMID: 25381449.25381449
68 Sellwood W, Barrowclough C, Tarrier N, . Needs-based cognitive-behavioural family intervention for carers of patients suffering from schizophrenia: 12-month follow-up. Acta Psychiatr Scand. 2001 Nov;104(5):346–55. PMID: 11722315.11722315
69 Sellwood W, Wittkowski A, Tarrier N, . Needs-based cognitive-behavioural family intervention for patients suffering from schizophrenia: 5-year follow-up of a randomized controlled effectiveness trial. Acta Psychiatr Scand. 2007 Dec;116(6):447–52. PMID: 17961200.17961200
70 Shoja Shafti S, Kaviani H. Quetiapine versus aripiprazole in the management of schizophrenia. Ther Adv Psychopharmacol. 2015;5(3):166–71. PMID: 26199719.26199719
71 Subotnik KL, Casaus LR, Ventura J, . Long-acting injectable risperidone for relapse prevention and control of breakthrough symptoms after a recent first episode of schizophrenia. A randomized clinical trial. JAMA Psychiatry. 2015 Aug;72(8):822–9. doi: 10.1001/jamapsychiatry.2015.0270. PMID: 26107752.26107752
72 Sytema S, Wunderink L, Bloemers W, . Assertive community treatment in the Netherlands: a randomized controlled trial. Acta Psychiatr Scand. 2007 Aug;116(2):105–12. PMID: 17650271.17650271
73 Takekita Y, Koshikawa Y, Fabbri C, . Cognitive function and risperidone long-acting injection vs. paliperidone palmitate in schizophrenia: a 6-month, open-label, randomized, pilot trial. BMC Psychiatry. 2016 May 29;16:172. doi: 10.1186/s12888-016-0883-9. PMID: 27236412.27236412
74 Tempier R, Balbuena L, Garety P, . Does assertive community outreach improve social support? Results from the Lambeth study of early-episode psychosis. Psychiatr Serv. 2012 Mar;63(3):216–22. doi: 10.1176/appi.ps.20110013. PMID: 22388528.22388528
75 Turkington D, Kingdon D, Turner T, . Effectiveness of a brief cognitive-behavioural therapy intervention in the treatment of schizophrenia. Br J Psychiatry. 2002 Jun;180:523–7. PMID: 12042231.12042231
76 Twamley EW, Vella L, Burton CZ, . Compensatory cognitive training for psychosis: effects in a randomized controlled trial. J Clin Psychiatry. 2012 Sep;73(9):1212–9. doi: 10.4088/JCP.12m07686. PMID: 22939029.22939029
77 Tybura P, Mak M, Samochowiec A, . The influence of antipsychotic therapy on the cognitive functions of schizophrenic patients. Psychiatr Pol. 2013;47(4):567–76. PMID: 24946464.24946464
78 Tybura P, Trzesniowska-Drukala B, Bienkowski P, . Pharmacogenetics of adverse events in schizophrenia treatment: comparison study of ziprasidone, olanzapine and perazine. Psychiatry Res. 2014 Oct 30;219(2):261–7. doi: 10.1016/j.psychres.2014.05.039. PMID: 24930580.24930580
79 Valencia M, Fresan A, Juarez F, . The beneficial effects of combining pharmacological and psychosocial treatment on remission and functional outcome in outpatients with schizophrenia. J Psychiatr Res. 2013 Dec;47(12):1886–92. doi: 10.1016/j.jpsychires.2013.09.006. PMID: 24112947.24112947
80 Valencia M, Rascon ML, Juarez F, . A psychosocial skills training approach in Mexican out-patients with schizophrenia. Psychol Med. 2007 Oct;37(10):1393–402. PMID: 17472761.17472761
81 Velligan DI, Diamond P, Mueller J, . The short-term impact of generic versus individualized environmental supports on functional outcomes and target behaviors in schizophrenia. Psychiatry Res. 2009 Jul 30;168(2):94–101. doi: 10.1016/j.psychres.2008.03.016. PMID: 19523690.19523690
82 Velligan DI, Diamond PM, Maples NJ, . Comparing the efficacy of interventions that use environmental supports to improve outcomes in patients with schizophrenia. Schizophr Res. 2008 Jul;102(1–3):312–9. doi: 10.1016/j.schres.2008.02.005. PMID: 18374542.18374542
83 Velligan DI, Diamond PM, Mintz J, . The use of individually tailored environmental supports to improve medication adherence and outcomes in schizophrenia. Schizophr Bull. 2008 May;34(3):483–93. PMID: 17932089.17932089
84 Velligan DI, Tai S, Roberts DL, . A randomized controlled trial comparing cognitive behavior therapy, cognitive adaptation training, their combination and treatment as usual in chronic schizophrenia. Schizophr Bull. 2015 May;41(3):597–603. doi: 10.1093/schbul/sbu127. PMID: 25193976.25193976
85 Velthorst E, Koeter M, van der Gaag M, . Adapted cognitive-behavioural therapy required for targeting negative symptoms in schizophrenia: meta-analysis and meta-regression. Psychol Med. 2015 Feb;45(3):453–65. doi: 10.1017/S0033291714001147. PMID: 24993642.24993642
86 Vita A, De Peri L, Barlati S, . Effectiveness of different modalities of cognitive remediation on symptomatological, neuropsychological, and functional outcome domains in schizophrenia: a prospective study in a real-world setting. Schizophr Res. 2011 Dec;133(1–3):223–31. doi: 10.1016/j.schres.2011.08.010. PMID: 21907544.21907544
87 Wani RA, Dar MA, Chandel RK, . Effects of switching from olanzapine to aripiprazole on the metabolic profiles of patients with schizophrenia and metabolic syndrome: a double-blind, randomized, open-label study. Neuropsychiatr Dis Treat. 2015;11:685–93. PMID: 25792838.25792838
88 Wykes T, Huddy V, Cellard C, . A meta-analysis of cognitive remediation for schizophrenia: methodology and effect sizes. Am J Psychiatry. 2011 May;168(5):472–85. doi: 10.1176/appi.ajp.2010.10060855. PMID: 21406461.21406461
89 Zhang J-P, Robinson DG, Gallego JA, . Association of a schizophrenia risk variant at the DRD2 locus with antipsychotic treatment response in first-episode psychosis. Schizophr Bull. 2015 Nov;41(6):1248–55. doi: 10.1093/schbul/sbv116. PMID: 26320194.26320194
90 Zimmer M, Duncan AV, Laitano D, . A twelve-week randomized controlled study of the cognitive-behavioral integrated psychological therapy program: positive effect on the social functioning of schizophrenic patients. Rev Bras Psiquiatr. 2007 Jun;29(2):140–7. PMID: 17650536.17650536
91 Zou H, Li Z, Nolan MT, . Self-management education interventions for persons with schizophrenia: a meta-analysis. Int J Ment Health Nurs. 2013 Jun;22(3):256–71. doi: 10.1111/j.1447-0349.2012.00863.x. PMID: 22882803.22882803