# Appendix A Search Strategies

## Key Question 1

### FGA Versus SGA

#### Database: Ovid MEDLINE

1. exp Schizophrenia/dt [Drug Therapy]
2. (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
3. (Fluphenazine or Haloperidol or Perphenazine).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
4. 1 and 2 and 3
5. limit 4 to english language
6. limit 5 to (meta analysis or systematic reviews)
7. limit 5 to randomized controlled trial
8. limit 5 to controlled clinical trial
9. 6 or 7 or 8
10. (201* not 2010*).ed,dp.
11. 9 and 10

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. schizophren*.mp. [mp=title, abstract, full text, keywords, caption text]
2. (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone).mp. [mp=title, abstract, full text, keywords, caption text]
3. (Fluphenazine or Haloperidol or Perphenazine).mp. [mp=title, abstract, full text, keywords, caption text]
4. 1 and 2 and 3
5. limit 4 to yr=“2011 – Current”

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. schizophren*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. (Fluphenazine or Haloperidol or Perphenazine).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. 1 and 2 and 3
5. limit 4 to yr=“2011 – Current”

#### Database: PsycINFO

1. exp Schizophrenia/
2. (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
3. (Fluphenazine or Haloperidol or Perphenazine).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
4. 1 and 2 and 3
5. limit 4 to english language
6. limit 5 to systematic reviews
7. limit 5 to “2000 treatment outcome/clinical trial”
8. random*.mp.
9. (clinical* adj5 (trial* or study or protocol*)).mp.
10. 8 and 9
11. ((random* or control*) adj5 (trial* or study or protocol*)).mp.
12. 5 and 10
13. 5 and 11
14. 6 or 7 or 12 or 13
15. (201* not 2010*).dp,up.
16. 14 and 15

### SGA Versus SGA

#### Database: Ovid MEDLINE

1. exp Schizophrenia/dt [Drug Therapy]
2. ((compar* or contrast* or evaluat* or analy* or measur* or quanti* or judg*) adj7 (((second or 2nd) adj2 generation) or atypical*) adj3 (antipsychotic* or anti-psychotic*)).mp.
3. (Aripiprazole and (Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
4. (Asenapine and (Aripiprazole or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
5. (Brexpiprazole and (Aripiprazole or Asenapine or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp.
6. (Cariprazine and (Aripiprazole or Asenapine or Brexpiprazole or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
7. (Clozapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
8. (Iloperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
9. (Lurasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
10. (Olanzapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
11. (Paliperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
12. (Quetiapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Risperidone or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
13. (Risperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Ziprasidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
14. (Ziprasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
15. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16. 1 and 15
17. limit 16 to english language
18. limit 17 to systematic reviews
19. limit 17 to randomized controlled trial
20. limit 17 to controlled clinical trial
21. 18 or 19 or 20
22. (2013* or 2014* or 2015* or 2016*).ed,dp.
23. 21 and 22

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. Schizophren*.mp. [mp=title, abstract, full text, keywords, caption text]
2. ((compar* or contrast* or evaluat* or analy* or measur* or quanti* or judg*) adj7 (((second or 2nd) adj2 generation) or atypical*) adj3 (antipsychotic* or anti-psychotic*)).mp.
3. (Aripiprazole and (Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
4. (Asenapine and (Aripiprazole or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
5. (Brexpiprazole and (Aripiprazole or Asenapine or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp.
6. (Cariprazine and (Aripiprazole or Asenapine or Brexpiprazole or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
7. (Clozapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
8. (Iloperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
9. (Lurasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
10. (Olanzapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
11. (Paliperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
12. (Quetiapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Risperidone or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
13. (Risperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Ziprasidone)).mp. [mp=title, abstract, full text, keywords, caption text]
14. (Ziprasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone)).mp. [mp=title, abstract, full text, keywords, caption text]
15. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16. 1 and 15
17. limit 16 to english language [Limit not valid; records were retained]
18. (2013* or 2014* or 2015* or 2016*).up.
19. 17 and 18

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. Schizophren*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. ((compar* or contrast* or evaluat* or analy* or measur* or quanti* or judg*) adj7 (((second or 2nd) adj2 generation) or atypical*) adj3 (antipsychotic* or anti-psychotic*)).mp.
3. (Aripiprazole and (Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. (Asenapine and (Aripiprazole or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. (Brexpiprazole and (Aripiprazole or Asenapine or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp.
6. (Cariprazine and (Aripiprazole or Asenapine or Brexpiprazole or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7. (Clozapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
8. (Iloperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9. (Lurasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
10. (Olanzapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11. (Paliperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
12. (Quetiapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Risperidone or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13. (Risperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Ziprasidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
14. (Ziprasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16. 1 and 15
17. limit 16 to english language
18. (2013* or 2014* or 2015* or 2016*).up.
19. 17 and 18

#### Database: PsycINFO

1. exp Schizophrenia/
2. ((compar* or contrast* or evaluat* or analy* or measur* or quanti* or judg*) adj7 (((second or 2nd) adj2 generation) or atypical*) adj3 (antipsychotic* or anti-psychotic*)).mp.
3. (Aripiprazole and (Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
4. (Asenapine and (Aripiprazole or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
5. (Brexpiprazole and (Aripiprazole or Asenapine or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp.
6. (Cariprazine and (Aripiprazole or Asenapine or Brexpiprazole or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
7. (Clozapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
8. (Iloperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
9. (Lurasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Olanzapine or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
10. (Olanzapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Paliperidone or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
11. (Paliperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Quetiapine or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
12. (Quetiapine and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Risperidone or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
13. (Risperidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Ziprasidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
14. (Ziprasidone and (Aripiprazole or Asenapine or Brexpiprazole or Cariprazine or Clozapine or Iloperidone or Lurasidone or Olanzapine or Paliperidone or Quetiapine or Risperidone)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
15. 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16. 1 and 15
17. limit 16 to english language
18. limit 17 to systematic reviews
19. limit 17 to “2000 treatment outcome/clinical trial”
20. random*.mp.
21. 17 and 20
22. ((random* or control*) adj5 (trial* or study or protocol*)).mp.
23. 17 and 22
24. (clinical* adj5 (trial* or study or protocol*)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
25. 21 and 24
26. 18 or 19 or 23 or 25
27. (2013* or 2014* or 2015* or 2016*).up,dp.
28. 26 and 27

## Key Question 2

### Broad Search

#### Database: Ovid MEDLINE(R)

1. *Schizophrenia/th [Therapy]
2. limit 1 to english language
3. limit 2 to (clinical trial or controlled clinical trial or randomized controlled trial)
4. limit 2 to (meta analysis or systematic reviews)
5. 3 or 4

#### Database: Ovid MEDLINE(R) without Revisions

1. *Schizophrenia/rh [Rehabilitation]
2. limit 1 to english language
3. limit 2 to (clinical trial or controlled clinical trial or randomized controlled trial)
4. limit 2 to (meta analysis or systematic reviews)
5. 3 or 4

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. *Schizophrenia/th [Therapy]
2. Schizophrenia/
3. schizophrenia.ti,ab.
4. (non-pharmacolog* or nonpharmacolog* or psychosocial or psycho-social).mp.
5. (2 or 3) and 4
6. 1 or 5
7. limit 6 to english language

#### Database: PsycINFO

1. Schizophrenia/
2. schizophrenia.ti,ab.
3. (non-pharmacolog* or nonpharmacolog* or psychosocial or psycho-social).mp.
4. (1 or 2) and 3
5. ((systematic* adj3 (review* or overview*)) or (methodologic* adj3 (review* or overview*))).ti,ab.
6. (meta-analy* or metaanaly* or systematic review*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
7. 4 and (5 or 6)

#### Database: PsycINFO

1. Schizophrenia/
2. schizophrenia.ti,ab.
3. (non-pharmacolog* or nonpharmacolog* or psychosocial or psycho-social).mp.
4. (1 or 2) and 3
5. (“randomi*ed controlled trial” or “RCT”).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
6. ((random* or control*) adj5 (trial or study)).mp.
7. 4 and (5 or 6)
8. limit 7 to english language

#### Database: ClinicalTrials.gov

NOT NOTEXT [FIRST-RECEIVED-RESULTS-DATE] AND EXACT “Interventional” [STUDY-TYPES] AND ( Schizophrenia OR Schizoaffective Disorder ) [DISEASE] AND Behavioral [TREATMENT] AND EXACT Adult [AGE-GROUP]

### Narrow Search

#### Database: Ovid MEDLINE(R)

1. exp schizophrenia/
2. exp Community Mental Health Services/
3. 1 and 2
4. exp Cognitive Therapy/
5. 1 and 4
6. (Cognit* adj5 Remediat*).mp.
7. 1 and 6
8. exp Family Therapy/
9. (((family or families) adj5 psychoeducat*) or ((family or families) adj3 (therap* or counsel*))).mp.
10. 8 or 9
11. 1 and 10
12. exp Peer Group/
13. 1 and 12
14. (peer* adj5 (support* or group*)).mp.
15. 1 and 14
16. (Intensiv* adj3 ((case or cases) adj3 manag*)).mp.
17. 1 and 16
18. exp Case Management/
19. 1 and 18
20. Skills Training.mp.
21. ((skill* or job or jobs or employment or vocation*) adj5 train*).mp.
22. 1 and 21
23. exp Employment, Supported/
24. ((support* or subsidiz*) adj2 educat*).mp.
25. exp Rehabilitation, Vocational/
26. exp Sheltered Workshops/
27. 23 or 24 or 25 or 26
28. 1 and 27
29. exp residential facilities/
30. ((support* or subsidiz*) adj2 hous*).mp.
31. 29 or 30
32. 1 and 31
33. ((“Illness Management and Recovery” or IMR) adj3 (toolkit* or tool kit*)).mp.
34. 1 and 33
35. 3 or 5 or 7 or 11 or 13 or 15 or 17 or 19 or 22 or 28 or 32 or 34
36. limit 35 to english language
37. limit 36 to systematic reviews
38. limit 36 to randomized controlled trial
39. limit 36 to controlled clinical trial
40. 37 or 38 or 39
41. limit 40 to yr=“1902 – 1995”

#### Database: Ovid MEDLINE(R) without Revisions

1. exp schizophrenia/
2. exp Community Mental Health Services/
3. 1 and 2
4. exp Cognitive Therapy/
5. 1 and 4
6. (Cognit* adj5 Remediat*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
7. 1 and 6
8. exp Family Therapy/
9. (((family or families) adj5 psychoeducat*) or ((family or families) adj3 (therap* or counsel*))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
10. 8 or 9
11. 1 and 10
12. exp Peer Group/
13. 1 and 12
14. (peer* adj5 (support* or group*)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
15. 1 and 14
16. (Intensiv* adj3 ((case or cases) adj3 manag*)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
17. 1 and 16
18. exp Case Management/
19. 1 and 18
20. Skills Training.mp.
21. ((skill* or job or jobs or employment or vocation*) adj5 train*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
22. 1 and 21
23. exp Employment, Supported/
24. ((support* or subsidiz*) adj2 educat*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
25. exp Rehabilitation, Vocational/
26. exp Sheltered Workshops/
27. 23 or 24 or 25 or 26
28. 1 and 27
29. exp residential facilities/
30. ((support* or subsidiz*) adj2 hous*).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
31. 29 or 30
32. 1 and 31
33. ((“Illness Management and Recovery” or IMR) adj3 (toolkit* or tool kit*)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
34. 1 and 33
35. 3 or 5 or 7 or 11 or 13 or 15 or 17 or 19 or 22 or 28 or 32 or 34
36. limit 35 to english
37. limit 36 to systematic reviews
38. limit 36 to randomized controlled trial
39. limit 36 to controlled clinical trial
40. 37 or 38 or 39

#### Database: EBM Reviews - Cochrane Database of Systematic Reviews

1. schizophren*.mp. [mp=title, abstract, full text, keywords, caption text]
2. (Communit* adj7 (mental* or psych*) adj5 (health* or servic* or clinic*)).mp. [mp=title, abstract, full text, keywords, caption text]
3. 1 and 2
4. (Cognit* adj3 (therap* or treat*)).mp. [mp=title, abstract, full text, keywords, caption text]
5. 1 and 4
6. (Cognit* adj5 Remediat*).mp. [mp=title, abstract, full text, keywords, caption text]
7. 1 and 6
8. (((family or families) adj5 psychoeducat*) or ((family or families) adj3 (therap* or counsel*))).mp. [mp=title, abstract, full text, keywords, caption text]
9. 1 and 8
10. (peer* adj5 (support* or group* or interact* or relation*)).mp. [mp=title, abstract, full text, keywords, caption text]
11. 1 and 10
12. (Intensiv* adj3 ((case or cases) adj3 manag*)).mp. [mp=title, abstract, full text, keywords, caption text]
13. 1 and 12
14. (case* adj2 manag*).mp. [mp=title, abstract, full text, keywords, caption text]
15. 1 and 14
16. ((skill* or job or jobs or employment or vocation*) adj5 train*).mp. [mp=title, abstract, full text, keywords, caption text]
17. 1 and 16
18. (support* adj3 (employ* or job* or occupation* or workplac* or vocation*)).mp. [mp=title, abstract, full text, keywords, caption text]
19. ((support* or subsidiz*) adj2 educat*).mp. [mp=title, abstract, full text, keywords, caption text]
20. (rehab* adj3 (vocational* or occupation* or workplac* or employment)).mp. [mp=title, abstract, full text, keywords, caption text]
21. (shelter* adj3 (Workshop* or workplac*)).mp. [mp=title, abstract, full text, keywords, caption text]
22. 18 or 19 or 20 or 21
23. 1 and 22
24. ((support* or subsidiz*) adj2 hous*).mp. [mp=title, abstract, full text, keywords, caption text]
25. 1 and 24
26. ((“Illness Management and Recovery” or IMR) adj3 (toolkit* or tool kit*)).mp. [mp=title, abstract, full text, keywords, caption text]
27. 1 and 26
28. 3 or 5 or 7 or 9 or 11 or 13 or 15 or 17 or 23 or 25 or 27
29. limit 28 to English

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. schizophren*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (Communit* adj7 (mental* or psych*) adj5 (health* or servic* or clinic*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2
4. (Cognit* adj3 (therap* or treat* or train* or interven*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. 1 and 4
6. (Cognit* adj5 Remediat*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7. 1 and 6
8. (((family or families) adj5 psychoeducat*) or ((family or families) adj3 (therap* or counsel*))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9. 1 and 8
10. (peer* adj5 (support* or group* or interact* or relation*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11. 1 and 10
12. (Intensiv* adj3 ((case or cases) adj3 manag*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13. 1 and 12
14. (case* adj2 manag*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15. 1 and 14
16. ((skill* or job or jobs or employment or vocation*) adj5 train*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
17. 1 and 16
18. (support* adj3 (employ* or job* or occupation* or workplac* or vocation*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
19. ((support* or subsidiz*) adj2 educat*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
20. (rehab* adj3 (vocational* or occupation* or workplac* or employment)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
21. (shelter* adj3 (Workshop* or workplac*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
22. 18 or 19 or 20 or 21
23. 1 and 22
24. ((support* or subsidiz*) adj2 hous*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
25. 1 and 24
26. ((“Illness Management and Recovery” or IMR) adj3 (toolkit* or tool kit*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
27. 1 and 26
28. 3 or 5 or 7 or 9 or 11 or 13 or 15 or 17 or 23 or 25 or 27
29. limit 28 to english
30. limit 29 to yr=“2011 – Current”
31. limit 29 to yr=“1898 – 2010”

#### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. schizophren*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2. (Communit* adj7 (mental* or psych*) adj5 (health* or servic* or clinic*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
3. 1 and 2
4. (Cognit* adj3 (therap* or treat* or train* or interven*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
5. 1 and 4
6. (Cognit* adj5 Remediat*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
7. 1 and 6
8. (((family or families) adj5 psychoeducat*) or ((family or families) adj3 (therap* or counsel*))).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
9. 1 and 8
10. (peer* adj5 (support* or group* or interact* or relation*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
11. 1 and 10
12. (Intensiv* adj3 ((case or cases) adj3 manag*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
13. 1 and 12
14. (case* adj2 manag*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
15. 1 and 14
16. ((skill* or job or jobs or employment or vocation*) adj5 train*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
17. 1 and 16
18. (support* adj3 (employ* or job* or occupation* or workplac* or vocation*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
19. ((support* or subsidiz*) adj2 educat*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
20. (rehab* adj3 (vocational* or occupation* or workplac* or employment)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
21. (shelter* adj3 (Workshop* or workplac*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
22. 18 or 19 or 20 or 21
23. 1 and 22
24. ((support* or subsidiz*) adj2 hous*).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
25. 1 and 24
26. ((“Illness Management and Recovery” or IMR) adj3 (toolkit* or tool kit*)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
27. 1 and 26
28. 3 or 5 or 7 or 9 or 11 or 13 or 15 or 17 or 23 or 25 or 27
29. limit 28 to english
30. limit 29 to yr=“2011 – Current”
31. limit 29 to yr=“1898 – 2010”

#### Database: PsycINFO

1. exp schizophrenia/
2. exp Community Mental Health Services/
3. 1 and 2
4. exp Cognitive Therapy/
5. 1 and 4
6. (Cognit* adj5 Remediat*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
7. 1 and 6
8. exp Family Therapy/
9. (((family or families) adj5 psychoeducat*) or ((family or families) adj3 (therap* or counsel*))).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
10. 8 or 9
11. 1 and 10
12. exp Peer Group/
13. 1 and 12
14. (peer* adj5 (support* or group*)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
15. 1 and 14
16. (Intensiv* adj3 ((case or cases) adj3 manag*)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
17. 1 and 16
18. exp Case Management/
19. 1 and 18
20. Skills Training.mp.
21. ((skill* or job or jobs or employment or vocation*) adj5 train*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
22. 1 and 21
23. exp Employment, Supported/
24. ((support* or subsidiz*) adj2 educat*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
25. exp Rehabilitation, Vocational/
26. exp Sheltered Workshops/
27. 23 or 24 or 25 or 26
28. 1 and 27
29. exp residential facilities/
30. ((support* or subsidiz*) adj2 hous*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
31. 29 or 30
32. 1 and 31
33. ((“Illness Management and Recovery” or IMR) adj3 (toolkit* or tool kit*)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
34. 1 and 33
35. 3 or 5 or 7 or 11 or 13 or 15 or 17 or 19 or 22 or 28 or 32 or 34
36. limit 35 to english
37. limit 36 to systematic reviews
38. random*.mp.
39. (clinical* adj5 (trial* or study or protocol*)).mp.
40. 38 and 39
41. ((random* or control*) adj5 (trial* or study or protocol*)).mp.
42. 40 or 41
43. 36 and 42
44. 37 or 43
45. limit 36 to “2000 treatment outcome/clinical trial”
46. 44 or 45

#### Database: PsycINFO

1. exp schizophrenia/
2. exp Community Mental Health Services/
3. 1 and 2
4. exp Cognitive Therapy/
5. 1 and 4
6. (Cognit* adj5 Remediat*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
7. 1 and 6
8. exp Family Therapy/
9. (((family or families) adj5 psychoeducat*) or ((family or families) adj3 (therap* or counsel*))).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
10. 8 or 9
11. 1 and 10
12. exp Peers/or exp peer relations/
13. 1 and 12
14. (peer* adj5 (support* or group*)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
15. 1 and 14
16. (Intensiv* adj3 ((case or cases) adj3 manag*)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
17. 1 and 16
18. exp Case Management/
19. 1 and 18
20. Skills Training.mp.
21. ((skill* or job or jobs or employment or vocation*) adj5 train*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
22. 1 and 21
23. exp supported employment/
24. ((support* or subsidiz*) adj2 educat*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
25. exp Rehabilitation, Vocational/
26. exp Sheltered Workshops/
27. 23 or 24 or 25 or 26
28. 1 and 27
29. ((support* or subsidiz*) adj2 hous*).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
30. 1 and 29
31. ((“Illness Management and Recovery” or IMR) adj3 (toolkit* or tool kit*)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
32. 1 and 31
33. 3 or 5 or 7 or 11 or 13 or 15 or 17 or 19 or 22 or 28 or 30 or 32
34. limit 33 to english
35. limit 34 to systematic reviews
36. random*.mp.
37. (clinical* adj5 (trial* or study or protocol*)).mp.
38. 36 and 37
39. ((random* or control*) adj5 (trial* or study or protocol*)).mp.
40. 38 or 39
41. 34 and 40
42. 35 or 41
43. limit 34 to “2000 treatment outcome/clinical trial”
44. 42 or 43