# Abbreviations

Abbreviation: Definition
ACT: assertive community treatment
AHRQ: Agency for Healthcare Research & Quality
APA: American Psychiatric Association
BPRS: Brief Psychiatric Rating Scale
CAT: cognitive adaption training
CATIE: Clinical Antipsychotic Trials of Intervention Effectiveness
CBT: cognitive behavioral therapy
CGI: Clinical Global Impression Scale
CGI-I: Clinical Global Impression – Improvement scale
CGI-S: Clinical Global Impression – Severity scale
CGI-SS: Clinical Global Impression of severity –Suicidality Scale
CI: confidence interval
CPRS: Comprehensive Psychopathology Rating Scale
DACT: Dartmouth Assertive Community Treatment Scale
DERP: Drug Effectiveness Review Project
df: degrees of freedom
DSM: American Psychiatric Association’s Diagnostic and Statistical Manual of Mental Disorders
DSM-III: American Psychiatric Association’s Diagnostic and Statistical Manual of Mental Disorders, version 3
DSM-IV: American Psychiatric Association’s Diagnostic and Statistical Manual of Mental Disorders, version 4
DSM-5: American Psychiatric Association’s Diagnostic and Statistical Manual of Mental Disorders, version 5
EHC: Effective Health Care
EPC: Evidence-based Practice Center
EPS: extrapyramidal symptoms
EQ-5D: EuroQol five dimensions questionnaire
ER: extended release
FDA: U.S. Food and Drug Administration
FEP: first-episode psychosis
FGA: first-generation antipsychotic
GAF: Global Assessment of Functioning
GAF-M: Global Assessment of Functioning – Modified version
GAS: Global Assessment Scale
GHQ: Global Health Questionnaire
HAM-D: Hamilton Depression Scale
HDI: United Nations International Human Development Index
HR: hazard ratio
ICM: intensive case management
ILSS: Independent Living Skills Survey
IPS: individual placement and support
IR: immediate release
KQ: key question
LAI: long-acting injectable
LSM: least squares mean
MADRS: Montgomery-Asberg Depression Scale
MCAS: The Multnomah Community Ability Scale
MD: mean difference
N: Number
NNT: number needed to treat
ODT: oral dissolving tablet
OR: odds ratio
PACT: Program of Assertive Community Treatment
PANSS: Positive and Negative Syndrome Scale
PEAT: Penn Emotional Acuity Test
PICOT: population, intervention, comparison, outcomes, timing
PSP: Personal and Social Performance Scale
QLS: Heinrich Carpenter Quality of Life Scale
QOLI: Subjective Quaity of Life
RCT: randomized controlled trial
RFS: Role Functioning Scale
RR: relative risk
RSES: Rosenberg Self-Esteem Scale
SAS: Social Adjustment Scale – Severely Mentally Ill version
SADS-C +PD: Schedule for Affective Disorders and Schizophrenia – Change Version with psychosis and disorganization
SANS: Scale for Assessment of Negative Symptoms
SAPS: Scale for the Assessment of Positive Symptoms
SF-12: 12-Item Short Form Health Survey
SFS: Social Function Scale
SGA: Second-generation antipsychotic
SIP: Scientific Information Packet
SMD: standardized mean difference
SOE: strength of evidence
SOFAS: Social and Occupational Functioning Assessment Scale
SOHO: Schizophrenia Outpatient Health Outcome
SQLS-R4: Schizophrenia Quality of Life Scale – Revision 4
SR: systematic review
SSPA: Social Skills Performance Assessment
SUD: substance use disorder
TEP: Technical Expert Panel
UPSA-B: San Diego Performance Based Skills Assessment - Brief
VPRS: Seven point verbal rating scale
vs.: Versus
WBI: Work Behavior Inventory
WBS: Well-being Scale
WMD: weighted mean difference