# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential non-financial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential non-financial conflicts of interest identified.

The list of Peer Reviewers:

- Benjamin Gaston, M.D.
  Rainbow Babies and Children’s Hospital and Case Western Reserve University
  Cleveland, OH
- Elliot Israel, M.D.
  Brigham and Women’s Hospital, Harvard Medical School
  Boston, MA
- Nicholas Kenyon, M.D.
  University of California, Davis
  Sacramento, CA
- Augusto Litonjua, M.D., M.P.H.
  Harvard Medical School
  Boston, MA
- John Sundy, M.D., P.h.D.
  Duke University School of Medicine
  Durham, NC