# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

Technical Experts who provided input to this report

- Anas Daghestani, M.D.
  Austin Regional Clinic
  Austin, TX
- Serpil C. Erzurum, M.D.
  Cleveland Clinic Foundation
  Cleveland, OH
- Rohit Katial, M.D.
  University of Colorado
  Denver, CO
- Todd A. Mahr, M.D.
  Gundersen Lutheran Medical Center
  La Crosse, WI
- John G. Mastronarde, M.D., M.S.c.^*^
  Providence Portland Medical Center and The Oregon Clinic
  Portland, OR
- Wayne J. Morgan, MD
  College of Medicine Tucson, University of Arizona
  Tucson, AZ
- Shahzeb Munir, M.D.^*^
  University of Wisconsin School of Medicine and Public Health
  Madison, WI
- Sally Wenzel, M.D.^*^
  University of Pittsburgh
  Pittsburgh, PA

* Technical Experts who also reviewed the report.