# Appendix J References

1 Arora R, Thornblade CE, Dauby PA, . Exhaled nitric oxide levels in military recruits with new onset asthma. Allergy Asthma Proc. 2006 Nov–Dec;27(6):493–8. doi: 10.2500/aap.2006.27.2904. PMID: 17176784.17176784
2 Avital A, Uwyyed K, Berkman N, . Exhaled nitric oxide and asthma in young children. Pediatr Pulmonol. 2001 Oct;32(4):308–13. PMID: 11568992.11568992
3 Backer V, Sverrild A, Porsbjerg C. FENO and AHR mannitol in patients referred to an out-of-hospital asthma clinic: a real-life study. J Asthma. 2014 May;51(4):411–6. doi: 10.3109/02770903.2013.878953. PMID: 24450977.24450977
4 Berkman N, Avital A, Breuer R, . Exhaled nitric oxide in the diagnosis of asthma: comparison with bronchial provocation tests. Thorax. 2005 May;60(5):383–8. doi: 10.1136/thx.2004.031104. PMID: 15860713.15860713
5 Berlyne GS, Parameswaran K, Kamada D, . A comparison of exhaled nitric oxide and induced sputum as markers of airway inflammation. J Allergy Clin Immunol. 2000 Oct;106(4):638–44. doi: 10.1067/mai.2000.109622. PMID: 11031333.11031333
6 Bommarito L, Migliore E, Bugiani M, . Exhaled nitric oxide in a population sample of adults. Respiration. 2008;75(4):386–92. doi: 10.1159/000104852. PMID: 17596680.17596680
7 Utility of nitric oxide for the diagnosis of asthma in an allergy clinic population. Allergy and Asthma Proceedings; 2011. OceanSide Publications, Inc; 32.
8 Deykin A, Massaro AF, Drazen JM, . Exhaled nitric oxide as a diagnostic test for asthma: online versus offline techniques and effect of flow rate. Am J Respir Crit Care Med. 2002 Jun 15;165(12):1597–601. doi: 10.1164/rccm.2201081. PMID: 12070059.12070059
9 Dupont LJ, Demedts MG, Verleden GM. Prospective evaluation of the validity of exhaled nitric oxide for the diagnosis of asthma. Chest. 2003 Mar;123(3):751–6. doi: 10.1378/chest.123.3.751. PMID: 12628874.12628874
10 Florentin A, Acouetey DS, Remen T, . Exhaled nitric oxide and screening for occupational asthma in two at-risk sectors: bakery and hairdressing. Int J Tuberc Lung Dis. 2014 Jun;18(6):744–50. doi: 10.5588/ijtld.13.0641. PMID: 24903948.24903948
11 Fortuna AM, Feixas T, Gonzalez M, . Diagnostic utility of inflammatory biomarkers in asthma: exhaled nitric oxide and induced sputum eosinophil count. Respir Med. 2007 Nov;101(11):2416–21. doi: 10.1016/j.rmed.2007.05.019. PMID: 17714927.17714927
12 Fukuhara A, Saito J, Sato S, . Validation study of asthma screening criteria based on subjective symptoms and fractional exhaled nitric oxide. Ann Allergy Asthma Immunol. 2011 Dec;107(6):480–6. doi: 10.1016/j.anai.2011.09.002. PMID: 22123376.22123376
13 Grzelewski T, Witkowski K, Makandjou-Ola E, . Diagnostic value of lung function parameters and FeNO for asthma in schoolchildren in large, real-life population. Pediatr Pulmonol. 2014 Jul;49(7):632–40. doi: 10.1002/ppul.22888. PMID: 24019244.24019244
14 Heffler E, Guida G, Marsico P, . Exhaled nitric oxide as a diagnostic test for asthma in rhinitic patients with asthmatic symptoms. Respir Med. 2006 Nov;100(11):1981–7. doi: 10.1016/j.rmed.2006.02.019. PMID: 16584881.16584881
15 Henriksen AH, Lingaas-Holmen T, Sue-Chu M, . Combined use of exhaled nitric oxide and airway hyperresponsiveness in characterizing asthma in a large population survey. Eur Respir J. 2000 May;15(5):849–55. doi: 10.1034/j.1399-3003.2000.15e07.x. PMID: 10853848.10853848
16 Ishizuka T, Matsuzaki S, Aoki H, . Prevalence of asthma symptoms based on the European Community Respiratory Health Survey questionnaire and FENO in university students: gender differences in symptoms and FENO. Allergy Asthma Clin Immunol. 2011 Sep 19;7(1):15. doi: 10.1186/1710-1492-7-15. PMID: 21923950.21923950
17 Jerzynska J, Majak P, Janas A, . Predictive value of fractional nitric oxide in asthma diagnosis-subgroup analyses. Nitric Oxide. 2014 Aug 31;40:87–91. doi: 10.1016/j.niox.2014.06.001. PMID: 24928560.24928560
18 Katsoulis K, Ganavias L, Michailopoulos P, . Exhaled nitric oxide as screening tool in subjects with suspected asthma without reversibility. Int Arch Allergy Immunol. 2013;162(1):58–64. doi: 10.1159/000350221. PMID: 23816757.23816757
19 Kostikas K, Papaioannou AI, Tanou K, . Portable exhaled nitric oxide as a screening tool for asthma in young adults during pollen season. Chest. 2008 Apr;133(4):906–13. doi: 10.1378/chest.07-1561. PMID: 17951619.17951619
20 Lemiere C, D’Alpaos V, Chaboillez S, . Investigation of occupational asthma: sputum cell counts or exhaled nitric oxide? Chest. 2010 Mar;137(3):617–22. doi: 10.1378/chest.09-2081. PMID: 19952060.19952060
21 Malinovschi A, Backer V, Harving H, . The value of exhaled nitric oxide to identify asthma in smoking patients with asthma-like symptoms. Respir Med. 2012 Jun;106(6):794–801. doi: 10.1016/j.rmed.2012.02.009. PMID: 22405608.22405608
22 Martin MJ, Wilson E, Gerrard-Tarpey W, . The utility of exhaled nitric oxide in patients with suspected asthma. Thorax. 2016 Jun;71(6):562–4. doi: 10.1136/thoraxjnl-2015-208014. PMID: 26903595.26903595
23 Matsunaga K, Hirano T, Akamatsu K, . Exhaled nitric oxide cutoff values for asthma diagnosis according to rhinitis and smoking status in Japanese subjects. Allergol Int. 2011 Sep;60(3):331–7. doi: 10.2332/allergolint.10-OA-0277. PMID: 21502803.21502803
24 Menzies D, Nair A, Lipworth BJ. Portable exhaled nitric oxide measurement: Comparison with the “gold standard” technique. Chest. 2007 Feb;131(2):410–4. doi: 10.1378/chest.06-1335. PMID: 17296641.17296641
25 Miedinger D, Chhajed PN, Tamm M, . Diagnostic tests for asthma in firefighters. Chest. 2007 Jun;131(6):1760–7. doi: 10.1378/chest.06-2218. PMID: 17400683.17400683
26 Miedinger D, Mosimann N, Meier R, . Asthma tests in the assessment of military conscripts. Clin Exp Allergy. 2010 Feb;40(2):224–31. doi: 10.1111/j.1365-2222.2009.03387.x. PMID: 19895592.19895592
27 Munnik P, van der Lee I, Fijn J, . Comparison of eNO and histamine hyperresponsiveness in diagnosing asthma in new referrals. Respir Med. 2010 Jun;104(6):801–7. doi: 10.1016/j.rmed.2009.12.002. PMID: 20036525.20036525
28 Nayak, U B, Morakhia, . A study of fraction of exhaled nitric oxide levels as a diagnostic marker in patients with bronchial asthma. Journal, Indian Academy of Clinical Medicine. 2013;14(2):123–7. PMID: 2013432566.
29 Pedrosa M, Cancelliere N, Barranco P, . Usefulness of exhaled nitric oxide for diagnosing asthma. J Asthma. 2010 Sep;47(7):817–21. doi: 10.3109/02770903.2010.491147. PMID: 20718633.20718633
30 Perez Tarazona S, Martinez Camacho RM, Alfonso Diego J, . [Diagnostic value of exhaled nitric oxide measurement in mild asthma]. An Pediatr (Barc). 2011 Nov;75(5):320–8. doi: 10.1016/j.anpedi.2011.05.008. PMID: 21703952.21703952
31 Usefulness of exhaled nitric oxide (FeNO) measured by a portable analyzer to diagnose cough variant asthma in a clinical setting of chronic cough. Allergy; 2009. WILEY-BLACKWELL PUBLISHING, INC COMMERCE PLACE, 350 MAIN ST, MALDEN 02148, MA USA; 64.
32 Ramser M, Hammer J, Amacher A, . The value of exhaled nitric oxide in predicting bronchial hyperresponsiveness in children. J Asthma. 2008 Apr;45(3):191–5. doi: 10.1080/02770900801890273. PMID: 18415824.18415824
33 Sachs-Olsen C, Lodrup Carlsen KC, Mowinckel P, . Diagnostic value of exhaled nitric oxide in childhood asthma and allergy. Pediatr Allergy Immunol. 2010 Feb;21(1 Pt 2):e213–21. doi: 10.1111/j.1399-3038.2009.00965.x. PMID: 21083852.21083852
34 Sato S, Saito J, Sato Y, . Clinical usefulness of fractional exhaled nitric oxide for diagnosing prolonged cough. Respir Med. 2008 Oct;102(10):1452–9. doi: 10.1016/j.rmed.2008.04.018. PMID: 18614345.18614345
35 Schleich FN, Asandei R, Manise M, . Is FENO50 useful diagnostic tool in suspected asthma? Int J Clin Pract. 2012 Feb;66(2):158–65. doi: 10.1111/j.1742-1241.2011.02840.x. PMID: 22257040.22257040
36 Schneider A, Schwarzbach J, Faderl B, . FENO measurement and sputum analysis for diagnosing asthma in clinical practice. Respir Med. 2013 Feb;107(2):209–16. doi: 10.1016/j.rmed.2012.10.003. PMID: 23107283.23107283
37 Schneider A, Faderl B, Schwarzbach J, . Prognostic value of bronchial provocation and FENO measurement for asthma diagnosis--results of a delayed type of diagnostic study. Respir Med. 2014 Jan;108(1):34–40. doi: 10.1016/j.rmed.2013.11.008. PMID: 24315470.24315470
38 Schneider A, Tilemann L, Schermer T, . Diagnosing asthma in general practice with portable exhaled nitric oxide measurement--results of a prospective diagnostic study: FENO < or = 16 ppb better than FENO < or =12 ppb to rule out mild and moderate to severe asthma [added]. Respir Res. 2009 Mar 03;10:15. doi: 10.1186/1465-9921-10-15. PMID: 19254389.19254389
39 Sivan Y, Gadish T, Fireman E, . The use of exhaled nitric oxide in the diagnosis of asthma in school children. J Pediatr. 2009 Aug;155(2):211–6. doi: 10.1016/j.jpeds.2009.02.034. PMID: 19394049.19394049
40 Smith AD, Cowan JO, Filsell S, . Diagnosing asthma: comparisons between exhaled nitric oxide measurements and conventional tests. Am J Respir Crit Care Med. 2004 Feb 15;169(4):473–8. doi: 10.1164/rccm.200310-1376OC. PMID: 14644933.14644933
41 Thomas PS, Gibson PG, Wang H, . The relationship of exhaled nitric oxide to airway inflammation and responsiveness in children. J Asthma. 2005 May;42(4):291–5. doi: 10.1081/JAS-200057908. PMID: 16032938.16032938
42 Travers J, Marsh S, Aldington S, . Reference ranges for exhaled nitric oxide derived from a random community survey of adults. Am J Respir Crit Care Med. 2007 Aug 01;176(3):238–42. doi: 10.1164/rccm.200609-1346OC. PMID: 17478616.17478616
43 Woo SI, Lee JH, Kim H, . Utility of fractional exhaled nitric oxide (F(E)NO) measurements in diagnosing asthma. Respir Med. 2012 Aug;106(8):1103–9. doi: 10.1016/j.rmed.2012.03.022. PMID: 22534041.22534041
44 Yao TC, Ou LS, Lee WI, . Exhaled nitric oxide discriminates children with and without allergic sensitization in a population-based study. Clinical & Experimental Allergy. 2011;41(4):556–64. doi: 10.1111/j.1365-2222.2010.03687.x.21338427
45 Agache I, Ciobanu C. Predictive value of lung function trend and FeNO for difficult asthma in children. J Investig Allergol Clin Immunol. 2012;22(6):419–26. PMID: 23101186.23101186
46 Beerthuizen T, Voorend-van Bergen S, van den Hout WB, . Cost-effectiveness of FENO-based and web-based monitoring in paediatric asthma management: a randomised controlled trial. Thorax. 2016 Jul;71(7):607–13. doi: 10.1136/thoraxjnl-2015-207593. PMID: 27048197.27048197
47 Berg J, Lindgren P. Economic evaluation of FE(NO) measurement in diagnosis and 1-year management of asthma in Germany. Respir Med. 2008 Feb;102(2):219–31. doi: 10.1016/j.rmed.2007.09.008. PMID: 18029165.18029165
48 Bernstein JA, Davis B, Alvarez-Puebla MJ, . Is exhaled nitric oxide a useful adjunctive test for assessing asthma? J Asthma. 2009 Nov;46(9):955–60. doi: 10.3109/02770900903265804. PMID: 19905926.19905926
49 Bora, M, Alpaydin, . Does asthma control as assessed by the asthma control test reflect airway inflammation? Multidisciplinary Respiratory Medicine. 2011 31 Oct;6(5):291–8. doi: 10.1186/2049-6958-6-5-291. PMID: 2012542916.22958759
50 Cano G, A, Carvajal U, . Clinical correlates and determinants of airway inflammation in pediatric asthma. Journal of Investigational Allergology and Clinical Immunology. 2010;20(4):303–10. PMID: 2010628842.20815308
51 Ciprandi G, Tosca MA, Capasso M. High exhaled nitric oxide levels may predict bronchial reversibility in allergic children with asthma or rhinitis. J Asthma. 2013 Feb;50(1):33–8. doi: 10.3109/02770903.2012.740119. PMID: 23157515.23157515
52 de B, C. M A, Moed, . Exhaled nitric oxide measures allergy not symptoms in children with allergic rhinitis in primary care: A prospective cross-sectional and longitudinal cohort study. Primary Care Respiratory Journal. 2013;22(1):44–50. PMID: 2013149138.
53 Delclaux C, Sembach N, Claessens YE, . Offline exhaled nitric oxide in emergency department and subsequent acute asthma control. J Asthma. 2008 Dec;45(10):867–73. doi: 10.1080/02770900802155429. PMID: 19085575.19085575
54 Fritsch M, Uxa S, Horak F, Jr., . Exhaled nitric oxide in the management of childhood asthma: a prospective 6-months study. Pediatr Pulmonol. 2006 Sep;41(9):855–62. doi: 10.1002/ppul.20455. PMID: 16850457.16850457
55 Gelb AF, Flynn Taylor C, Shinar CM, . Role of spirometry and exhaled nitric oxide to predict exacerbations in treated asthmatics. Chest. 2006 Jun;129(6):1492–9. doi: 10.1378/chest.129.6.1492. PMID: 16778266.16778266
56 Gill M, Walker S, Khan A, . Exhaled nitric oxide levels during acute asthma exacerbation. Acad Emerg Med. 2005 Jul;12(7):579–86. doi: 10.1197/j.aem.2005.01.018. PMID: 15995087.15995087
57 Griese M, Koch M, Latzin P, . Asthma severity, recommended changes of inhaled therapy and exhaled nitric oxide in children: a prospective, blinded trial. Eur J Med Res. 2000 Aug 18;5(8):334–40. PMID: 10958766.10958766
58 Gruffydd-Jones K, Ward S, Stonham C, . The use of exhaled nitric oxide monitoring in primary care asthma clinics: a pilot study. Prim Care Respir J. 2007 Dec;16(6):349–56. doi: 10.3132/pcrj.2007.00076. PMID: 18157462.18157462
59 Habib SS, Alzoghaibi MA, Abba AA, . Relationship of the Arabic version of the asthma control test with ventilatory function tests and levels of exhaled nitric oxide in adult asthmatics. Saudi Med J. 2014 Apr;35(4):397–402. PMID: 24749138.24749138
60 Hanson JR, De Lurgio SA, Williams DD, . Office-based exhaled nitric oxide measurement in children 4 years of age and older. Ann Allergy Asthma Immunol. 2013 Nov;111(5):358–63. doi: 10.1016/j.anai.2013.07.020. PMID: 24125141.24125141
61 Harkins MS, Fiato KL, Iwamoto GK. Exhaled nitric oxide predicts asthma exacerbation. J Asthma. 2004 Jun;41(4):471–6. doi: 10.1081/JAS-120033990. PMID: 15281333.15281333
62 Hayata A, Matsunaga K, Hirano T, . Stratifying a risk for an increased variation of airway caliber among the clinically stable asthma. Allergol Int. 2013 Sep;62(3):343–9. doi: 10.2332/allergolint.13-OA-0543. PMID: 23880616.23880616
63 Hsu JY, Huang WC, Huang PL, . Usefulness of offline fractional exhaled nitric oxide measurements in the elderly asthmatic patients. Allergy Asthma Proc. 2013 Sep–Oct;34(5):434–8. doi: 10.2500/aap.2013.34.3692. PMID: 23998240.23998240
64 Kavitha V, Mohan A, Madan K, . Fractional exhaled nitric oxide is a useful adjunctive modality for monitoring bronchial asthma. Lung India. 2017 Mar–Apr;34(2):132–7. doi: 10.4103/0970-2113.201322. PMID: WOS:000396130500005.28360460
65 Ko FW, Hui DS, Leung TF, . Evaluation of the asthma control test: a reliable determinant of disease stability and a predictor of future exacerbations. Respirology. 2012 Feb;17(2):370–8. doi: 10.1111/j.1440-1843.2011.02105.x. PMID: 22107482.22107482
66 Kostikas K, Papaioannou AI, Tanou K, . Exhaled NO and exhaled breath condensate pH in the evaluation of asthma control. Respir Med. 2011 Apr;105(4):526–32. doi: 10.1016/j.rmed.2010.10.015. PMID: 21051211.21051211
67 Kwok MY, Walsh-Kelly CM, Gorelick MH. The role of exhaled nitric oxide in evaluation of acute asthma in a pediatric emergency department. Acad Emerg Med. 2009 Jan;16(1):21–8. doi: 10.1111/j.1553-2712.2008.00304.x. PMID: 19055675.19055675
68 Leblanc A, Botelho C, Coimbra A, . Assessment of asthma control: clinical, functional and inflammatory aspects. Eur Ann Allergy Clin Immunol. 2013 May;45(3):90–6. PMID: 23862398.23862398
69 Lex C, Dymek S, Heying R, . Value of surrogate tests to predict exercise-induced bronchoconstriction in atopic childhood asthma. Pediatr Pulmonol. 2007 Mar;42(3):225–30. doi: 10.1002/ppul.20556. PMID: 17245730.17245730
70 Mahut B, Trinquart L, Le Bourgeois M, . Multicentre trial evaluating alveolar NO fraction as a marker of asthma control and severity. Allergy. 2010 May;65(5):636–44. doi: 10.1111/j.1398-9995.2009.02221.x. PMID: 19845572.19845572
71 Martins P, Caires I, Rosado Pinto J, . The clinical use of exhaled nitric oxide in wheezing children. Rev Port Pneumol. 2008 Mar–Apr;14(2):195–218. doi: 10.1016/S2173-5115(08)70254–9. PMID: 18363018.18363018
72 McCormack MC, Aloe C, Curtin-Brosnan J, . Guideline-recommended fractional exhaled nitric oxide is a poor predictor of health-care use among inner-city children and adolescents receiving usual asthma care. Chest. 2013 Sep;144(3):923–9. doi: 10.1378/chest.12-3098. PMID: 23764806.23764806
73 Menzies D, Jackson C, Mistry C, . Symptoms, spirometry, exhaled nitric oxide, and asthma exacerbations in clinical practice. Ann Allergy Asthma Immunol. 2008 Sep;101(3):248–55. doi: 10.1016/S1081-1206(10)60489-9. PMID: 18814447.18814447
74 Meyts I, Proesmans M, De Boeck K. Exhaled nitric oxide corresponds with office evaluation of asthma control. Pediatr Pulmonol. 2003 Oct;36(4):283–9. doi: 10.1002/ppul.10317. PMID: 12950039.12950039
75 Michils A, Baldassarre S, Van Muylem A. Exhaled nitric oxide and asthma control: a longitudinal study in unselected patients. Eur Respir J. 2008 Mar;31(3):539–46. doi: 10.1183/09031936.00020407. PMID: 18057062.18057062
76 Michils A, Louis R, Peche R, . Exhaled nitric oxide as a marker of asthma control in smoking patients. Eur Respir J. 2009 Jun;33(6):1295–301. doi: 10.1183/09031936.00154008. PMID: 19164346.19164346
77 Nittner-Marszalska M, Liebhart J, Pawlowicz R, . Fractioned exhaled nitric oxide (FE(NO)) is not a sufficiently reliable test for monitoring asthma in pregnancy. Nitric Oxide. 2013 Sep 01;33:56–63. doi: 10.1016/j.niox.2013.06.001. PMID: 23756211.23756211
78 Ozier A, Girodet PO, Bara I, . Control maintenance can be predicted by exhaled NO monitoring in asthmatic patients. Respir Med. 2011 Jul;105(7):989–96. doi: 10.1016/j.rmed.2011.01.006. PMID: 21292461.21292461
79 Papakosta D, Latsios D, Manika K, . Asthma control test is correlated to FEV1 and nitric oxide in Greek asthmatic patients: influence of treatment. J Asthma. 2011 Nov;48(9):901–6. doi: 10.3109/02770903.2011.611958. PMID: 21923284.21923284
80 Plaza V, Ramos-Barbon D, Munoz AM, . Exhaled nitric oxide fraction as an add-on to ACQ-7 for not well controlled asthma detection. PLoS One. 2013;8(10):e77085. doi: 10.1371/journal.pone.0077085. PMID: 24204742.24204742
81 Quaedvlieg V, Sele J, Henket M, . Association between asthma control and bronchial hyperresponsiveness and airways inflammation: a cross-sectional study in daily practice. Clin Exp Allergy. 2009 Dec;39(12):1822–9. doi: 10.1111/j.1365-2222.2009.03332.x. PMID: 19817755.19817755
82 Raj D, Lodha R, Mukherjee A, . Fractional exhaled nitric oxide in children with acute exacerbation of asthma. Indian Pediatr. 2014 Feb;51(2):105–11. PMID: 24277963.24277963
83 Ricciardolo FL, Sorbello V, Bellezza Fontana R, . Exhaled nitric oxide in relation to asthma control: A real-life survey. Allergol Immunopathol (Madr). 2016 May–Jun;44(3):197–205. doi: 10.1016/j.aller.2015.05.012. PMID: 26589339.26589339
84 Robroeks CM, van de Kant KD, Jobsis Q, . Exhaled nitric oxide and biomarkers in exhaled breath condensate indicate the presence, severity and control of childhood asthma. Clin Exp Allergy. 2007 Sep;37(9):1303–11. doi: 10.1111/j.1365-2222.2007.02788.x. PMID: 17845410.17845410
85 Rosias PP, Dompeling E, Dentener MA, . Childhood asthma: exhaled markers of airway inflammation, asthma control score, and lung function tests. Pediatr Pulmonol. 2004 Aug;38(2):107–14. doi: 10.1002/ppul.20056. PMID: 15211692.15211692
86 Sato R, Tomita K, Sano H, . The strategy for predicting future exacerbation of asthma using a combination of the Asthma Control Test and lung function test. J Asthma. 2009 Sep;46(7):677–82. doi: 10.1080/02770900902972160. PMID: 19728204.19728204
87 Shirai T, Furuhashi K, Suda T, . Relationship of the asthma control test with pulmonary function and exhaled nitric oxide. Ann Allergy Asthma Immunol. 2008 Dec;101(6):608–13. doi: 10.1016/S1081-1206(10)60223-2. PMID: 19119704.19119704
88 Szefler SJ, Mitchell H, Sorkness CA, . Management of asthma based on exhaled nitric oxide in addition to guideline-based treatment for inner-city adolescents and young adults: a randomised controlled trial. Lancet. 2008 Sep 20;372(9643):1065–72. doi: 10.1016/S0140-6736(08)61448-8. PMID: 18805335.18805335
89 van der Valk RJ, Baraldi E, Stern G, . Daily exhaled nitric oxide measurements and asthma exacerbations in children. Allergy. 2012 Feb;67(2):265–71. doi: 10.1111/j.1398-9995.2011.02734.x. PMID: 21999328.21999328
90 van Vliet D, Alonso A, Rijkers G, . Prediction of asthma exacerbations in children by innovative exhaled inflammatory markers: results of a longitudinal study. PLoS One. 2015;10(3):e0119434. doi: 10.1371/journal.pone.0119434. PMID: 25799487.25799487
91 Visitsunthorn N, Prottasan P, Jirapongsananuruk O, . Is fractional exhaled nitric oxide (FeNO) associated with asthma control in children? Asian Pac J Allergy Immunol. 2014 Sep;32(3):218–25. doi: 10.12932/AP0362.32.3.2014. PMID: 25268339.25268339
92 Visitsunthorn N, Mahawichit N, Maneechotesuwan K. Association between levels of fractional exhaled nitric oxide and asthma exacerbations in Thai children. Respirology. 2017 Jan;22(1):71–7. doi: 10.1111/resp.12857. PMID: WOS:000390681400012.27438353
93 Voorend-van Bergen S, Vaessen-Verberne AA, Brackel HJ, . Monitoring strategies in children with asthma: a randomised controlled trial. Thorax. 2015 Jun;70(6):543–50. doi: 10.1136/thoraxjnl-2014-206161. PMID: 25825006.25825006
94 Warke TJ, Mairs V, Fitch PS, . Exhaled nitric oxide in relation to the clinical features of childhood asthma. J Asthma. 2004 Oct;41(7):751–7. doi: 10.1081/JAS-200027838. PMID: 15584635.15584635
95 Yamashita, M, Shibanai, . Fractional exhaled nitric oxide levels as a predictor of long-term prognoses in patients with mild asthma. Respiratory Investigation. 2016 01 May;54(3):139–47. doi: 10.1016/j.resinv.2015.11.005. PMID: 20160075168.27108008
96 Yang S, Park J, Lee YK, . Association of longitudinal fractional exhaled nitric oxide measurements with asthma control in atopic children. Respir Med. 2015 May;109(5):572–9. doi: 10.1016/j.rmed.2015.03.003. PMID: 25840483.25840483
97 Yavuz ST, Civelek E, Sahiner UM, . Identifying uncontrolled asthma in children with the childhood asthma control test or exhaled nitric oxide measurement. Ann Allergy Asthma Immunol. 2012 Jul;109(1):36–40. doi: 10.1016/j.anai.2012.05.011. PMID: 22727155.22727155
98 Zeiger RS, Szefler SJ, Phillips BR, . Response profiles to fluticasone and montelukast in mild-to-moderate persistent childhood asthma. J Allergy Clin Immunol. 2006 Jan;117(1):45–52. doi: 10.1016/j.jaci.2005.10.012. PMID: 16387583.16387583
99 Zeiger RS, Schatz M, Zhang F, . Association of exhaled nitric oxide to asthma burden in asthmatics on inhaled corticosteroids. J Asthma. 2011 Feb;48(1):8–17. doi: 10.3109/02770903.2010.539295. PMID: 21155706.21155706
100 Beck-Ripp J, Griese M, Arenz S, . Changes of exhaled nitric oxide during steroid treatment of childhood asthma. Eur Respir J. 2002 Jun;19(6):1015–9. doi: 10.1183/09031936.02.01582001. PMID: 12108850.12108850
101 Vijverberg SJ, Koster ES, Koenderman L, . Exhaled NO is a poor marker of asthma control in children with a reported use of asthma medication: a pharmacy-based study. Pediatr Allergy Immunol. 2012 Sep;23(6):529–36. doi: 10.1111/j.1399-3038.2012.01279.x. PMID: 22624949.22624949
102 Calhoun WJ, Ameredes BT, King TS, . Comparison of physician-, biomarker-, and symptom-based strategies for adjustment of inhaled corticosteroid therapy in adults with asthma: the BASALT randomized controlled trial. JAMA. 2012 Sep 12;308(10):987–97. doi: 10.1001/2012.jama.10893. PMID: 22968888.22968888
103 de Jongste JC, Carraro S, Hop WC, . Daily telemonitoring of exhaled nitric oxide and symptoms in the treatment of childhood asthma. Am J Respir Crit Care Med. 2009 Jan 15;179(2):93–7. doi: 10.1164/rccm.200807-1010OC. PMID: 18931330.18931330
104 Hashimoto S, Brinke AT, Roldaan AC, . Internet-based tapering of oral corticosteroids in severe asthma: a pragmatic randomised controlled trial. Thorax. 2011 Jun;66(6):514–20. doi: 10.1136/thx.2010.153411. PMID: 21474498.21474498
105 Honkoop PJ, Loijmans RJ, Termeer EH, . Symptom- and fraction of exhaled nitric oxide-driven strategies for asthma control: A cluster-randomized trial in primary care. J Allergy Clin Immunol. 2015 Mar;135(3):682–8 e11. doi: 10.1016/j.jaci.2014.07.016. PMID: 25174865.25174865
106 Malerba M, Radaeli A, Olivini A, . The Combined Impact of Exhaled Nitric Oxide and Sputum Eosinophils Monitoring in Asthma Treatment: A Prospective Cohort Study. Curr Pharm Des. 2015;21(32):4752–62. PMID: 26166613.26166613
107 Peirsman EJ, Carvelli TJ, Hage PY, . Exhaled nitric oxide in childhood allergic asthma management: a randomised controlled trial. Pediatr Pulmonol. 2014 Jul;49(7):624–31. doi: 10.1002/ppul.22873. PMID: 24039119.24039119
108 Petsky HL, Li AM, Au CT, . Management based on exhaled nitric oxide levels adjusted for atopy reduces asthma exacerbations in children: A dual centre randomized controlled trial. Pediatr Pulmonol. 2015 Jun;50(6):535–43. doi: 10.1002/ppul.23064. PMID: 24891337.24891337
109 Pijnenburg MW, Bakker EM, Hop WC, . Titrating steroids on exhaled nitric oxide in children with asthma: a randomized controlled trial. Am J Respir Crit Care Med. 2005 Oct 01;172(7):831–6. doi: 10.1164/rccm.200503-458OC. PMID: 15976380.15976380
110 Pike K, Selby A, Price S, . Exhaled nitric oxide monitoring does not reduce exacerbation frequency or inhaled corticosteroid dose in paediatric asthma: a randomised controlled trial. Clin Respir J. 2013 Apr;7(2):204–13. doi: 10.1111/j.1752-699X.2012.00306.x. PMID: 22747899.22747899
111 Powell H, Murphy VE, Taylor DR, . Management of asthma in pregnancy guided by measurement of fraction of exhaled nitric oxide: a double-blind, randomised controlled trial. Lancet. 2011 Sep 10;378(9795):983–90. doi: 10.1016/S0140-6736(11)60971-9. PMID: 21907861.21907861
112 Shaw DE, Berry MA, Thomas M, . The use of exhaled nitric oxide to guide asthma management - A randomized controlled trial. American Journal of Respiratory and Critical Care Medicine. 2007 Aug 1;176(3):231–7. doi: 10.1164/rccm.200610-14270C. PMID: WOS:000248522100004.17496226
113 Smith AD, Cowan JO, Brassett KP, . Use of exhaled nitric oxide measurements to guide treatment in chronic asthma. N Engl J Med. 2005 May 26;352(21):2163–73. doi: 10.1056/NEJMoa043596. PMID: 15914548.15914548
114 Syk J, Malinovschi A, Johansson G, . Anti-inflammatory treatment of atopic asthma guided by exhaled nitric oxide: a randomized, controlled trial. J Allergy Clin Immunol Pract. 2013 Nov–Dec;1(6):639–48 e1–8. doi: 10.1016/j.jaip.2013.07.013. PMID: 24565712.24565712
115 Verini M, Consilvio NP, Di Pillo S, . FeNO as a marker of airways inflammation: the possible implications in childhood asthma management. Journal of allergy. 2010;2010doi:10.1155/2010/691425.
116 LaForce C, Brooks E, Herje N, . Impact of exhaled nitric oxide measurements on treatment decisions in an asthma specialty clinic. Ann Allergy Asthma Immunol. 2014 Dec;113(6):619–23. doi: 10.1016/j.anai.2014.06.013. PMID: 25060819.25060819
117 Malerba M, Ragnoli B, Radaeli A, . Usefulness of exhaled nitric oxide and sputum eosinophils in the long-term control of eosinophilic asthma. Chest. 2008 Oct;134(4):733–9. doi: 10.1378/chest.08-0763. PMID: 18842911.18842911
118 Malerba M, Ragnoli B, Radaeli A, . Long-Term Adjustment of Stable Asthma Treatment with Fractional Exhaled Nitric Oxide and Sputum Eosinophils. European Journal of Inflammation. 2012 Sep–Dec;10(3):383–92. doi: 10.1177/1721727X1201000314. PMID: WOS:000313668100014.
119 Wan KS, Chiu WH, Yang W. Asthma diagnosis and severity monitoring in primary school children: essential role of sequential testing of exhaled nitric oxide. Allergol Immunopathol (Madr). 2014 Sep–Oct;42(5):439–43. doi: 10.1016/j.aller.2013.04.007. PMID: 23830305.23830305
120 Ciolkowski J, Mazurek H, Hydzik P, . Inflammatory markers as exacerbation risk factors after asthma therapy switch from inhaled steroids to montelukast. Pulm Pharmacol Ther. 2016 Aug;39:7–13. doi: 10.1016/j.pupt.2016.05.002. PMID: 27234706.27234706
121 Cowan DC, Taylor DR, Peterson LE, . Biomarker-based asthma phenotypes of corticosteroid response. J Allergy Clin Immunol. 2015 Apr;135(4):877–83 e1. doi: 10.1016/j.jaci.2014.10.026. PMID: 25488689.25488689
122 Mahut B, Peyrard S, Delclaux C. Exhaled nitric oxide and clinical phenotypes of childhood asthma. Respir Res. 2011 May 20;12:65. doi: 10.1186/1465-9921-12-65. PMID: 21599913.21599913
123 Smith AD, Cowan JO, Brassett KP, . Exhaled nitric oxide: a predictor of steroid response. Am J Respir Crit Care Med. 2005 Aug 15;172(4):453–9. doi: 10.1164/rccm.200411-1498OC. PMID: 15901605.15901605
124 Bisgaard H, Loland L, Oj JA. NO in exhaled air of asthmatic children is reduced by the leukotriene receptor antagonist montelukast. Am J Respir Crit Care Med. 1999 Oct;160(4):1227–31. doi: 10.1164/ajrccm.160.4.9903004. PMID: 10508811.10508811
125 Bratton DL, Lanz MJ, Miyazawa N, . Exhaled nitric oxide before and after montelukast sodium therapy in school-age children with chronic asthma: a preliminary study. Pediatr Pulmonol. 1999 Dec;28(6):402–7. doi: 10.1002/(SICI)1099-0496(199912)28:6<402::AID-PPUL3>3.0.CO;2-V. PMID: 10587413.10587413
126 Montuschi P, Mondino C, Koch P, . Effects of montelukast treatment and withdrawal on fractional exhaled nitric oxide and lung function in children with asthma. Chest. 2007 Dec;132(6):1876–81. doi: 10.1378/chest.07-1587. PMID: 18079221.18079221
127 Ohkura, N, Fujimura, . Additional effects of pranlukast on exhaled nitric oxide levels in patients with persistent asthma. Therapeutic Research. 2009;30(8):1361–6. PMID: 2009544293.
128 Sandrini A, Ferreira IM, Gutierrez C, . Effect of montelukast on exhaled nitric oxide and nonvolatile markers of inflammation in mild asthma. Chest. 2003 Oct;124(4):1334–40. doi: 10.1378/chest.124.4.1334. PMID: 14555563.14555563
129 Silkoff PE, Romero FA, Gupta N, . Exhaled nitric oxide in children with asthma receiving Xolair (omalizumab), a monoclonal anti-immunoglobulin E antibody. Pediatrics. 2004 Apr;113(4):e308–12. PMID: 15060258.15060258
130 Tajiri T, Niimi A, Matsumoto H, . Comprehensive efficacy of omalizumab for severe refractory asthma: a time-series observational study. Ann Allergy Asthma Immunol. 2014 Oct;113(4):470–5 e2. doi: 10.1016/j.anai.2014.06.004. PMID: 24994694.24994694
131 Baraldi E, Azzolin NM, Zanconato S, . Corticosteroids decrease exhaled nitric oxide in children with acute asthma. J Pediatr. 1997 Sep;131(3):381–5. doi: 10.1016/S0022-3476(97)80062-5. PMID: 9329413.9329413
132 Bulac S, Cimrin A, Ellidokuz H. The effect of beclometasone dipropionate/formoterol extra-fine fixed combination on the peripheral airway inflammation in controlled asthma. J Aerosol Med Pulm Drug Deliv. 2015 Apr;28(2):82–7. doi: 10.1089/jamp.2013.1062. PMID: 25050594.25050594
133 Byrnes CA, Dinarevic S, Shinebourne EA, . Exhaled nitric oxide measurements in normal and asthmatic children. Pediatr Pulmonol. 1997 Nov;24(5):312–8. doi: 10.1002/(SICI)1099-0496(199711)24:5<312::AID-PPUL2>3.0.CO;2-K. PMID: 9407563.9407563
134 Dupont LJ, Rochette F, Demedts MG, . Exhaled nitric oxide correlates with airway hyperresponsiveness in steroid-naive patients with mild asthma. Am J Respir Crit Care Med. 1998 Mar;157(3 Pt 1):894–8. doi: 10.1164/ajrccm.157.3.9709064. PMID: 9517608.9517608
135 Ehrs PO, Sundblad BM, Larsson K. Effect of fluticasone on markers of inflammation and quality of life in steroid-naive patients with mild asthma. Clin Respir J. 2010 Jan;4(1):51–8. doi: 10.1111/j.1752-699X.2009.00145.x. PMID: 20298418.20298418
136 Erin EM, Zacharasiewicz AS, Nicholson GC, . Rapid effect of inhaled ciclesonide in asthma: a randomized, placebo-controlled study. Chest. 2008 Oct;134(4):740–5. doi: 10.1378/chest.07-2575. PMID: 18403668.18403668
137 Gelb AF, Taylor CF, Shinar CM, . Effect of fluticasone 250 microg/salmeterol 50 microg and montelukast on exhaled nitric oxide in asthmatic patients. Can Respir J. 2008 May–Jun;15(4):193–8. doi: 10.1155/2008/415391. PMID: 18551200.18551200
138 Hozawa S, Terada M, Hozawa M. Comparison of the effects of budesonide/formoterol maintenance and reliever therapy with fluticasone/salmeterol fixed-dose treatment on airway inflammation and small airway impairment in patients who need to step-up from inhaled corticosteroid monotherapy. Pulm Pharmacol Ther. 2014 Apr;27(2):190–6. doi: 10.1016/j.pupt.2013.12.003. PMID: 24388868.24388868
139 Kermode JA, Brown NJ, Hardaker KM, . The effect of airway remodelling on airway hyper-responsiveness in asthma. Respir Med. 2011 Dec;105(12):1798–804. doi: 10.1016/j.rmed.2011.07.010. PMID: 21820298.21820298
140 Kharitonov SA, Yates DH, Barnes PJ. Inhaled glucocorticoids decrease nitric oxide in exhaled air of asthmatic patients. Am J Respir Crit Care Med. 1996 Jan;153(1):454–7. doi: 10.1164/ajrccm.153.1.8542158. PMID: 8542158.8542158
141 Kharitonov SA, Donnelly LE, Montuschi P, . Dose-dependent onset and cessation of action of inhaled budesonide on exhaled nitric oxide and symptoms in mild asthma. Thorax. 2002 Oct;57(10):889–96. doi: 10.1136/thorax.57.10.889. PMID: 12324677.12324677
142 Mallol J, Aguirre V, Gallardo A, . Effect of once-daily generic ciclesonide on exhaled nitric oxide in atopic children with persistent asthma. Allergol Immunopathol (Madr). 2016 Mar–Apr;44(2):106–12. doi: 10.1016/j.aller.2015.01.011. PMID: 26001339.26001339
143 Nolte H, Pavord I, Backer V, . Dose-dependent anti-inflammatory effect of inhaled mometasone furoate/formoterol in subjects with asthma. Respir Med. 2013 May;107(5):656–64. doi: 10.1016/j.rmed.2013.02.010. PMID: 23490226.23490226
144 Park GM, Han HW, Kim JY, . Association of symptom control with changes in lung function, bronchial hyperresponsiveness, and exhaled nitric oxide after inhaled corticosteroid treatment in children with asthma. Allergol Int. 2016 Oct;65(4):439–43. doi: 10.1016/j.alit.2016.03.011. PMID: 27160342.27160342
145 Profita M, Riccobono L, Bonanno A, . Effect of nebulized beclomethasone on airway inflammation and clinical status of children with allergic asthma and rhinitis: a randomized, double-blind, placebo-controlled study. Int Arch Allergy Immunol. 2013 April;161(1):53–64. doi: 10.1159/000343137. PMID: 23257680.23257680
146 Silkoff PE, McClean P, Spino M, . Dose-response relationship and reproducibility of the fall in exhaled nitric oxide after inhaled beclomethasone dipropionate therapy in asthma patients. Chest. 2001 May;119(5):1322–8. doi: 10.1378/chest.119.5.1322. PMID: 11348935.11348935
147 Smith RW, Downey K, Snow N, . Association between fraction of exhaled nitrous oxide, bronchodilator response and inhaled corticosteroid type. Can Respir J. 2015 May–Jun;22(3):153–6. doi: 10.1155/2015/851063. PMID: 25874734.25874734
148 Spallarossa D, Battistini E, Silvestri M, . Time-dependent changes in orally exhaled nitric oxide and pulmonary functions induced by inhaled corticosteroids in childhood asthma. J Asthma. 2001 Oct;38(7):545–53. doi: 10.1081/JAS-100107119. PMID: 11714077.11714077
149 Thomas B, Chay OM, Allen JC, . Concordance between bronchial hyperresponsiveness, fractional exhaled nitric oxide, and asthma control in children. Pediatric Pulmonology. 2016 Oct;51(10):1004–9. doi: 10.1002/ppul.23426. PMID: WOS:000384681100003.27074221
150 Verini M, Peroni DG, Piacentini GL, . Comparison of add-on therapy to inhaled fluticasone propionate in children with asthma: residual volume and exhaled nitric oxide as outcome measures. Allergy Asthma Proc. 2007 Nov–Dec;28(6):691–4. doi: 10.2500/aap.2007.28.3054. PMID: 18201433.18201433
151 Fuglsang G, Vikre-Jorgensen J, Agertoft L, . Effect of salmeterol treatment on nitric oxide level in exhaled air and dose-response to terbutaline in children with mild asthma. Pediatr Pulmonol. 1998 May;25(5):314–21. PMID: 9635933.9635933
152 Inoue H, Niimi A, Matsumoto H, . A 12-week, randomized, parallel-group, proof-of-concept study of tulobuterol patch and salmeterol inhaler as add-on therapy in adult-onset mild-to-moderate asthma. Clinical and Experimental Pharmacology and Physiology. 2017;44(1):21–9. doi: 10.1111/1440-1681.12683.
153 Effects of the addition of tiotropium on airway dimensions in symptomatic asthma. Allergy and Asthma Proceedings; 2016. OceanSide Publications, Inc; 37.
154 Yates D, Kharitonov S, Barnes P. Effect of short- and long-acting inhaled beta<inf>2</inf>-agonists on exhaled nitric oxide in asthmatic patients. European Respiratory Journal. 1997 July;10(7):1483–8. PMID: 1997222010.9230234
155 Cabral AL, Vollmer WM, Barbirotto RM, . Exhaled nitric oxide as a predictor of exacerbation in children with moderate-to-severe asthma: a prospective, 5-month study. Ann Allergy Asthma Immunol. 2009 Sep;103(3):206–11. doi: 10.1016/S1081-1206(10)60183-4. PMID: 19788017.19788017
156 Hojo M, Mizutani T, Iikura M, . Asthma control can be maintained after fixed-dose, budesonide/formoterol combination inhaler therapy is stepped down from medium to low dose. Allergol Int. 2013 Mar;62(1):91–8. doi: 10.2332/allergolint.12-OA-0444. PMID: 23093793.23093793
157 Jones SL, Kittelson J, Cowan JO, . The predictive value of exhaled nitric oxide measurements in assessing changes in asthma control. Am J Respir Crit Care Med. 2001 Sep 01;164(5):738–43. doi: 10.1164/ajrccm.164.5.2012125. PMID: 11549525.11549525
158 Liu L, Urban P, Hunt JF, . Changes in exhaled nitric oxide and breath pH during fluticasone wean in asthma. Respiration. 2010;79(3):193–9. doi: 10.1159/000242496. PMID: 19786726.19786726
159 Obase Y, Ikeda M, Kurose K, . Step-down of budesonide/formoterol in early stages of asthma treatment leads to insufficient anti-inflammatory effect. J Asthma. 2013 Sep;50(7):718–21. doi: 10.3109/02770903.2013.795588. PMID: 23638898.23638898
160 Pijnenburg MW, Hofhuis W, Hop WC, . Exhaled nitric oxide predicts asthma relapse in children with clinical asthma remission. Thorax. 2005 Mar;60(3):215–8. doi: 10.1136/thx.2004.023374. PMID: 15741438.15741438
161 Prieto L, Bruno L, Gutierrez V, . Airway responsiveness to adenosine 5′-monophosphate and exhaled nitric oxide measurements: predictive value as markers for reducing the dose of inhaled corticosteroids in asthmatic subjects. Chest. 2003 Oct;124(4):1325–33. doi: 10.1378/chest.124.4.1325. PMID: 14555562.14555562
162 Tsurikisawa N, Oshikata C, Tsuburai T, . Markers for step-down of inhaled corticosteroid therapy in adult asthmatics. Allergol Int. 2012 Sep;61(3):419–29. doi: 10.2332/allergolint.11-OA-0402. PMID: 22722811.22722811
163 Balinotti, J E, Colom, . Association between the asthma predictive index and levels of exhaled nitric oxide in infants and toddlers with recurrent wheezing. [Spanish, English]. Archivos Argentinos de Pediatria. 2013 June;111(3):191–5. doi: 10.1590/S0325-00752013000300003. PMID: 2013369544.23732343
164 Bloemen K, Koppen G, Govarts E, . Application of non-invasive biomarkers in a birth cohort follow-up in relation to respiratory health outcome. Biomarkers. 2010 Nov;15(7):583–93. doi: 10.3109/1354750X.2010.504307. PMID: 20662605.20662605
165 Castro-Rodriguez JA, Sardon O, Perez-Yarza EG, . Young infants with recurrent wheezing and positive asthma predictive index have higher levels of exhaled nitric oxide. J Asthma. 2013 Mar;50(2):162–5. doi: 10.3109/02770903.2012.754030. PMID: 23286212.23286212
166 Caudri D, Wijga AH, Hoekstra MO, . Prediction of asthma in symptomatic preschool children using exhaled nitric oxide, Rint and specific IgE. Thorax. 2010 Sep;65(9):801–7. doi: 10.1136/thx.2009.126912. PMID: 20805175.20805175
167 Chang D, Yao W, Tiller CJ, . Exhaled nitric oxide during infancy as a risk factor for asthma and airway hyperreactivity. Eur Respir J. 2015 Jan;45(1):98–106. doi: 10.1183/09031936.00034614. PMID: 25261328.25261328
168 Elliott M, Heltshe SL, Stamey DC, . Exhaled nitric oxide predicts persistence of wheezing, exacerbations, and decline in lung function in wheezy infants and toddlers. Clin Exp Allergy. 2013 Dec;43(12):1351–61. doi: 10.1111/cea.12171. PMID: 24261945.24261945
169 Klaassen, E. MM, Van De K, . Symptoms, but not a biomarker response to inhaled corticosteroids, predict asthma in preschool children with recurrent wheeze. Mediators of Inflammation. 2012;2012 (no pagination)(162571)doi: 10.1155/2012/162571. PMID: 2013000972.23304059
170 Prado OS, Perez-Yarza EG, Ruiz AA, . Fraction of exhaled nitric oxide and asthma predictive index in infants less than two years-old. Arch Bronconeumol. 2011 May;47(5):234–8. doi: 10.1016/j.arbres.2010.11.005. PMID: 21420218.21420218
171 van Wonderen KE, van der Mark LB, Mohrs J, . Prediction and treatment of asthma in preschool children at risk: study design and baseline data of a prospective cohort study in general practice (ARCADE). BMC Pulm Med. 2009 Apr 15;9:13. doi: 10.1186/1471-2466-9-13. PMID: 19368704.19368704
172 Schneider A, Tilemann L, Schermer T, . Diagnosing asthma in general practice with portable exhaled nitric oxide measurement--results of a prospective diagnostic study: FENO < or = 16 ppb better than FENO < or =12 ppb to rule out mild and moderate to severe asthma [added]. Respir Res. 2009 Mar 03;10(1):15. doi: 10.1186/1465-9921-10-15. PMID: 19254389.19254389
173 Sayao LB, de Britto MC, Burity E, . Exhaled nitric oxide as a diagnostic tool for wheezing in preschool children: A diagnostic accuracy study. Respir Med. 2016 Apr;113:15–21. doi: 10.1016/j.rmed.2016.02.008. PMID: 27021575.27021575
174 Malmberg LP, Pelkonen AS, Haahtela T, . Exhaled nitric oxide rather than lung function distinguishes preschool children with probable asthma. Thorax. 2003 Jun;58(6):494–9. doi: 10.1136/thorax.58.6.494. PMID: 12775859.12775859
175 Oh MA, Shim JY, Jung YH, . Fraction of exhaled nitric oxide and wheezing phenotypes in preschool children. Pediatr Pulmonol. 2013 Jun;48(6):563–70. doi: 10.1002/ppul.22705. PMID: 23129540.23129540
176 Ratjen F, Kavuk I, Gartig S, . Airway nitric oxide in infants with acute wheezy bronchitis. Pediatr Allergy Immunol. 2000 Nov;11(4):230–5. doi: 10.1034/j.1399-3038.2000.00093.x. PMID: 11110577.11110577
177 Latzin P, Kuehni CE, Baldwin DN, . Elevated exhaled nitric oxide in newborns of atopic mothers precedes respiratory symptoms. Am J Respir Crit Care Med. 2006 Dec 15;174(12):1292–8. doi: 10.1164/rccm.200606-782OC. PMID: 16973980.16973980
178 Franklin PJ, Turner SW, Mutch RC, . Measuring exhaled nitric oxide in infants during tidal breathing: methodological issues. Pediatr Pulmonol. 2004 Jan;37(1):24–30. doi: 10.1002/ppul.10382. PMID: 14679485.14679485
179 Wildhaber JH, Hall GL, Stick SM. Measurements of exhaled nitric oxide with the single-breath technique and positive expiratory pressure in infants. Am J Respir Crit Care Med. 1999 Jan;159(1):74–8. doi: 10.1164/ajrccm.159.1.9805021. PMID: 9872821.9872821