# Appendix I Additional Tables

Table I.1 Studies correlating FeNO performed in early childhood to current wheezing (excluded from this systematic review)

Author | Year of Publication | Conclusions
Sayao ^173^ | 2016 | In children (age 3–5 years), FeNO at 6ppb and 10ppb diagnoses wheezers from non-wheezers and from non-current wheezers; respectively
Malmberg ^174^ | 2003 | In children (age 3.8–7.5 years) with probable asthma, FeNO was higher than control children
Oh ^175^ | 2013 | In children age 4–6, FeNO was higher in persistent wheezers than transient wheezers and non-wheezers. Among persistent wheezers, FeNO was higher in those with atopy and airway hyperresponsiveness.
Wildhaber ^179^ | 1999 | In healthy infants 3–24 months, single breath FeNO was higher in wheezy infants and those with a family history of atopy
Latzin ^177^ | 2006 | FeNO measured after birth was associated with increased risk of subsequent respiratory symptoms and in infants of smoking mothers
Ratjen ^176^ | 2000 | Reduced airway NO concentrations in infants with virus-associated acute wheezy bronchitis
Franklin ^178^ | 2004 | In infants (5–100 weeks), no significant difference in FeNO found between healthy and wheezy ones, but those with doctor-diagnosed eczema had significantly raised levels

Table I.2 FeNO based algorithms used in randomized trials

Author, Year (ref) | Intervention
Calhoun, 2012^102^ | Asthmatics had their inhaled corticosteroids adjusted (inhaled beclomethasone or equivalent dose) adjustedevery 6 weeks for each group; Physician Assessment based adjustment (PABA) group; based on National Heart, Lung and Blood Institute guidelines. Biomarker - based adjustment (BBA) group; using FeNO measurement as following; If FeNO < 22 ppb, step down one level of therapy, 22–35 ppb, maintaine current level, > 36 ppb, step up one level. Symptom based adjustment (SBA) group; clinical symptoms promoting albuterol rescue use. After randomization, all outcomes were measured at 2, 4, 6, 12, 18, 24, 30, and 36 weeks visit. Primary outcomes: time to first treatment failure, hospitalizations, urgent care visits and other adverse events. Secondary outcomes: spirometry, albuterol reversibility, methacholine responsiveness, sputum eosinophils, daytime and nighttime symptom and rescue beta-agonist diaries, Asthma Control Questionnaire, Asthma Symptom Utility Index, and AQLQ.
De Jongste, 2009^103^ | Participants were seen after randomization at 3, 12, 21, and 30 weeks. Assessments included FeNO. Spirometry before and after salbutamol, and recording of adverse events. PACQLQS was administered at the first and last visits. All parents were phoned every 3 weeks between visits, and medication (inhaled budesonide or equivalent ICS doses) was adapted as following; FeNO group: according to geometric mean FeNO over the preceding 3 weeks and cumulative symptom scores. If FeNO > 20–25 ppb, increase ICS. If FeNO < 20–25 ppb, then decrease ICS if symptoms score < 60 cumulative in 3 weeks or no change in ICS doses if symptoms score > 60 cumulative in 3 weeks. Symptom group: adjusted only for symptoms.
Hashimoto, 2011^104^ | Monthly clinic visit for 6 months. FeNO were measured on a daily basis before medicine intake. ACT and spirometry were completed weekly. AQLQ was completed at baseline and every 3 months afterward. Internet strategy group: oral prednisone or equivalent oral steroid dose was adjusted based on the 3 components: electronic diary, monitoring support by nurses, and algorithm (which includes ACQ and daily FeNO measurement). If FeNO increase by > 10 ppb, step up ICS. If FeNO decrease by > 10 ppb, step down ICS. Conventional strategy group: steroids were down-titrated based on GINA guidelines at monthly visits.
Honkoop, 2015^105^ | Participants were seen every 3 months over the course of 1 year. At each visit, a patient’s asthma control status was classified based on the ACQ score as controlled (ACQ score < 0.75), partially controlled (ACQ score > 0.75) or uncontrolled (ACQ score> 1.5). Additionally in the FeNO controlled (FCa) strategy as 3 subcategories of FeNO: low/absence of airway inflammation for values < 25 ppb, intermediate at 26 to 50 ppb, and high/presence of airway inflammation > 50 ppb. Treatment (inhaled beclomethasone or equivalent ICS doses) decisions were based on a dedicated algorithm for each strategy. If FeNO low, step down ICS, if FeNO intermediate, no change in ICS doses, if FeNO high, step up ICS.
Malerba, 2015^106^ | Patients attended five visits after recruitment; 3, 6, 12, 18 and 24 months. At each visit, patients underwent clinical evaluation, lung function tests, sputum induction, and FeNO measurements were carried out according to the ATS guidelines. In group A, treatment (inaheld beclomethasone or ICS equivalent doses) was based on FeNO as following: if FeNO < 10ppb, step down therapy, if FeNO 11–20 ppb, no change in ICS dose, and if FeNO > 20 pbb, step up therapy. Also, sputum eosinophil values, symptoms and bronchodilator use were considered. In group B, treatment was prescribed according to the clinical symptoms score.
Peirsman, 2014^107^ | All patients attended five visits; one every 3 months over a year. Clinical group, at each visit, asthma control and treatment (LTRA, LABA, and inhaled budesonide or equivalent ICS doses) adjustments were determined by the reporting of symptoms, the need for rescue treatment during the two preceding weeks and spirometry, based on the GINA guidelines. FeNO group, FeNO measurements were primarily used to adjust the treatment. If FeNO < 20 ppb and controlled, add LTRA, decrease ICS stop LABA. If FeNO < 20 ppb and uncontrolled, add LTRA, consider decrease ICS and stop LABA. if FeNO > 20 ppb regardless of symptoms, then increase ICS, add LTRA and stop LABA.
Petsky, 2015^108^ | Monthly visits for the first 4 months and every 2 months thereafter over a year. At each visit, patients assessed with FeNO first, then spirometry before and after 400 mg inhaled salbutamol. Group 1: treatment strategy was based on FeNO levels, adjusted for atopy. If FeNO was elevated (FeNO > 10 ppb in children with no positive skin prick test (SPT), >12 ppb in children with one positive SPT, and >20 ppb in children with 2 or more positive SPT), then therapy was stepped up. If FeNO was low for two consecutive visits, medications were stepped down. Group 2: symptoms-based management.
Pijnenburg, 2005^110^ | Participants were seen for a year, at five visits with 3-month intervals. At each visit, FeNO was measured and the ICS dose was then adapted to FeNO and/or symptom scores recorded during the previous 2 weeks. At visits 1 and 5, pulmonary function tests and bronchoprovocation tests with methacholine were performed. FeNO Group: treatment (inhaled budesonide or equivalent ICS doses) was made on both FeNO and symptoms. If FeNO > 30 ppb regardless of symptoms, increase ICS dose, if FeNO < 30 ppb and symptoms > 14, then continue with ICS dose, if FeNO < 30 ppb and symptoms < 14, then decrease ICS dose. Symptom Group: treatment was made only on symptoms.
Pike, 2013^110^ | Participants were assessed 2 monthly for 12 months. At each visit, a single measure of FeNO and FEV_1_ were taken according to ATS/ERS guidelines. Finally, an assessing clinician assessed treatment adherence by direct questioning, recorded exacerbations and administered a questionnaire reviewing symptoms and reliever use over the preceding 2 months. Group 1: therapy (LTRA, LABA and inhaled beclomethasone or equivalent doses of budesonide or fluticasone) adjusted by FeNO measurements. If asthma poor controlled; FeNO > 25 ppb, increase ICS or add LTRA, FeNO <25 ppb, increase LABA. If asthma well controlled; FeNO > 25 ppb, increase ICS or add add LTRA, FeNO 15–25 ppb, continue current treatment, FeNO < 15 ppb, reduce ICS and LABA. Group 2: standard management
Powell, 2011^111^ | Women were reviewed monthly at the antenatal clinic until delivery. At each visit, clinical symptoms, ACQ score, present treatment, FeNO, and FEV_1_ were measured. ACQ score, FeNO concentration, and treatment (inhaled budesonide or equivalent ICS doses) were sent by facsimile to the algorithm keeper for treatment changes recommendation. FeNO group: they used a sequential process, first, the FeNO concentration to adjust inhaled corticosteroids dose and second, the ACQ score to adjust the dose of long acting β2 agonist. Clinical group: they were based on asthma control using Juniper ACQ with cutoff points defined as: well controlled asthma (ACQ score < 0.75), partially controlled (ACQ score 0.75–1.50) and uncontrolled (ACQ score > 1.5).
Shaw, 2007^112^ | Participants were seen monthly for the first 4 months and every 2 months thereafter. At each visit, FeNO, FEV_1_ and Juniper asthma control questionnaire were taken. At the 6- and 12-month visit, induced sputum and methacholine challenge testing were also performed. FeNO group: when FeNO > 26 ppb, ICS ICS (daily beclomethasone diproprionate (BDP) or equivalent ICS doses) was increased. If < 16 ppb, or < 26 ppb on 2 separate occasions, treatment was decreased Control group: when JACS > 1.57, treatment was doubled. If JACS < 1.57 for 2 consecutive months, the treatment was halved
Smith, 2005^113^ | A 12 months phase where patients were evaluated on six occasions at intervals of two months. At each visit, FeNO were measured. If the FeNO > 15 ppb or if the asthma was uncontrolled, treatment (inhaled fluticasone) was increased by one step. If the FeNO level < 15 ppb or if the asthma was controlled for two consecutive visits, the dose was titrated back down one step. However, treatment was not decreased below the optimal dose or to placebo.
Syk, 2013^114^ | Participants were seen after baseline at 2, 4, 8, and 12 month. At each visit, FeNO, ACT, and registration of exacerbations were taken. mAQLQ and GQLI were taken at baseline, month 4, and month 12. FeNO group: treatment (inhaled budesonide or equivalent ICS dose) was adjusted according to a FeNO algorithm and 6 fixed treatment steps. Control group: treatment was adjusted according to usual care including patient-reported symptoms, SABA use, physical examination, and lung functions results.
Verini, 2010^115^ | ASS, AEf, ATS, and immunoallergological and functional data were evaluated at the start of the study, 6 months, and 1 year later. FeNO group: therapy consisted of ICS, LABA and LTRA was assessed by FeNO measurements (as the mean of three readings represent the value for each measurement, FeNO > 12 ppb were considered as an indication to increase the number of drugs, whereas < 12 ppb lead to a reduction or to a maintenance in the amount of drugs) and GINA guidelines. GINA group: therapy was assessed based on symptoms, short acting β2-agonist use, and lung function, according to GINA guidelines.

ACQ score: Asthma Control Questionnaire score; ACT score: asthma control test; AEf: Asthma Exacerbation frequency; AQLQ: Asthma Quality of Life Questionnaire; ASS: Asthma Severity score; ATS guidelines: American Thoracic Society guidelines; ATS/ERS guidelines: The American Thoracic Society/European Respiratory Society guidelines; ATS: Asthma Therapy score; FeNO: Fractional exhaled nitric oxide; FEV_1_: forced expiratory volume in the first second; FEV_1_% pred: forced expiratory volume in the first second percentage predicted; GINA guidelines: Global Initiative for Asthma guidelines; GQLI: Gothenburg Quality of Life Instrument; ICS: Inhaled corticosteroid; LABA: Long-acting beta-2-agonists; LTRA: Leukotriene receptor antagonist; mAQLQ: Mini Asthma Quality of Life Questionnaire; PACQLQS: Pediatric Asthma Caregiver Quality of Life Questionnaire with Standardized activities; SABA: Short-acting beta-2 agonist.