# Appendix H Assessment of the Strength of Evidence

Table H.1 Assessment of the Strength of Evidence KQ1a

FeNO CutOff | Reference Test | Study Design and Sample Size | Risk of Bias | Consistency | Directness | Precision | Publication Bias | Strength of Evidence
<20 ppb | Clinical Diagnosis | 8 observational studies^4, 6, 15, 23, 24, 28, 30, 33^ (1,199 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
| Positive bronchial challenge | 5 observational studies^1, 2, 4, 8, 32^ (320 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
| Combination of clinical diagnosis, bronchial challenge, and/or Bronchodilator response | 9 observational studies^5, 9, 10, 13, 14, 19, 21, 38, 39^ (2,683Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
| Overall (all available studies regardless of reference test) | 21 observational studies ^1, 2, 4–6, 8–10, 13–15, 19, 21, 23, 24, 28, 30, 32, 33, 38, 39^ (4,129 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
20–30 ppb | Clinical Diagnosis | 5 observational studies^7, 23, 33, 38, 44^ (2,637 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
| Combination of clinical diagnosis, bronchial challenge/Bronchodilator response | 15 observational studies^9–11, 14, 17, 19, 21, 25, 26, 36–40, 42, 43^ (2,327Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
| Overall (all available studies regardless of reference test) | 22 observational studies^1, 3, 7, 9–11, 14, 17, 19, 21, 23, 25, 26, 30, 33, 36–40, 42–44^ (5,189 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
30–40 ppb | Overall (all available studies regardless of reference test) | 10 observational studies^8, 9, 14, 16, 19, 26, 32, 34, 35, 38^ (1,753 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
>=40 ppb | Combination of clinical diagnosis, bronchial challenge/Bronchodilator response | 8 observational studies^10, 12, 14, 25, 31, 38, 42, 43^ (1,142 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate
| Overall (all available studies regardless of reference test) | 10 observational studies^10, 12, 14, 25, 29, 31, 32, 42, 43, 172^ (1,368 Patients) | Medium | Consistent | Direct | Precise | Undetected | Moderate

Table H.2 Assessment of the Strength of Evidence KQ1b. Narrative Evaluation

Question | Study Design and Sample Size | Risk of Bias | Consistency | Directness | Precision | Publication Bias | Strength of Evidence
Can FeNO levels predict the current control of asthma or the risk of future exacerbations? | 19 observational studies in adults ^48, 49, 55, 59, 61–63, 65, 66, 73, 75–77, 79–81, 86, 87, 99^ (4,146 Patients) 21 observational in children^45, 46, 50–52, 54, 57, 60, 69, 71, 72, 74, 85, 89–91, 93, 94, 96–98, 101^ (3,926 Patients) | Low | Consistent | Direct | Precise | Undetected | Low (Observational studies)
Can FeNO be used to monitor asthma status during acute exacerbations? | 4 observational studies ^53, 56, 67, 82^ (1,013 patients) | Low | Consistent | Direct | Precise | Undetected | Low (Observational studies)
Can FeNO be used to monitor adherence to asthma medications? | 3 observational studies ^88, 100, 101^ (1,035 patients) | Low | Consistent | Direct | Precise | Undetected | Low (Observational studies)

Table H.3 Assessment of the Strength of Evidence KQ1c

Question | Study Design and Sample Size | Risk of Bias | Consistency | Directness | Precision | Publication Bias | Strength of Evidence
Adults
Exacerbations^1^ | 6 RCTs^88, 105, 111–114^ (1,536 patients) | Low^a^ | Consistent | Direct | Precise | Undetected | High
Exacerbations requiring systemic steroids | 4 RCTs^88, 111, 113, 114^ (1,041 patients) | Low | Consistent | Direct | Imprecise^b^ | Undetected | Moderate (Imprecision)
Hospitalizations | 4 RCTs^88, 111, 112, 114^ (1,034 patients) | Low | Consistent | Direct | Severely Imprecise | Undetected | Low (Severe imprecision)
Quality of life | 2 RCTs^102, 105^ (621 patients) | Low | Consistent | Direct | Severely Imprecise | Undetected | Low (Severe imprecision)
FEV_1_ % predicted | 5 RCTs^88, 105, 111, 113, 114^ (1,348 patients) | Low | Consistent | Indirect | Severely Imprecise | Undetected | Insufficient (Severe imprecision and indirectness)
Asthma control test | 5 RCTs^88, 102, 111, 112, 114^ (1,523 patients) | Low | Consistent | Direct | Severely Imprecise | Undetected | Low (Severe imprecision)
Children
Exacerbations^1^ | 7 RCTs^54, 93, 103, 107–110^ (733 patients) | Low^a^ | Consistent | Direct | Precise | Undetected | High
Exacerbations requiring systemic steroids | 6 RCTs^54, 93, 103, 107–109^ (733 patients) | Low | Consistent | Direct | Imprecise^b^ | Undetected | Moderate (Imprecision)
Hospitalizations | (623 patients) 5 RCTs^93, 103, 107, 108, 110^ (564 patients) | Low | Consistent | Direct | Severely Imprecise | Undetected | Low (Severe imprecision)
Quality of life | 3 RCTs^93, 103, 108^ (380 patients) | Low | Consistent | Direct | Severely Imprecise | Undetected | Low (Severe imprecision)
FEV_1_ % predicted | 5 RCTs^93, 103, 107–110^ (635 patients) | Low | Inconsistent | Indirect | Severely Imprecise | Undetected | Insufficient (Severe imprecision, indirectness and inconsistency)
Asthma control test | 1 RCT^93^ (178 patients) | Low | Consistent | Direct | Severely Imprecise | Undetected | Low (Severe imprecision)

a Six trials were unblinded (3 in adults and 3 in children). Therefore, it is also reasonable to reduce the strength of evidence due to study limitations making it moderate. We did not rate down because results were consistent in blinded vs unblinded trials.

b The pooled effect of adults and children is precise, suggesting that the outcome in either subgroup (adults or children) is underpowered and the apparent imprecision is just due to small sample size. The effect size in children becomes statistically significant using the DerSimonian-Laird method.

Table H.4 Assessment of the Strength of Evidence KQ1e. Narrative Evaluation

Question | Study Design and Sample Size | Risk of Bias | Consistency | Directness | Precision | Publication Bias | Strength of Evidence
FeNO testing done at age 0–4 years for the prediction of a future diagnosis of asthma. | 3 observational studies^166, 167, 169^ (346 patients) | Low | Inconsistent^a^ | Direct | Precise | Undetected | Insufficient (inconsistency)
The association between FeNO testing done at age 0–4 years with the Asthma Predictive Index | 5 observational studies^163–165, 168, 170^ (959 patients) | Low | Consistent | Direct | Precise | Undetected | Low (Observational studies)
The association between FeNO testing done at age 0–4 years with wheezing | 7 observational studies^173–179^ (1,126 patients) | Low | Consistent | Direct | Precise | Undetected | Low (Observational studies)

a Studies were showing opposing and inconsistent conclusions