# Appendix G Risk of Bias

Table G.1 Risk of Bias (QUADAS-2) for studies answering KQ 1a

Author, Year (ref) | Consecutive or Random Sample of Patients | Case-Control Design Avoided | Inappropriate Exclusions Avoided | Concerns Regarding Applicability | The Index Test Results Interpreted | The Threshold Pre-specified | Concern About the Index Test | The Reference Standard Correctly Classify the Target Condition | The Reference Standard Results Appropriately Interpreted | Concern That the Target Condition Does not Match the Question | An Appropriate Interval Between Index Test(s) and Reference Standard | All Patients Received a Reference Standard | Patients Received the Same Reference Standard | All Patients Included in the Analysis | Overall RoB
Arora, 2006^1^ | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Avital, 2001^2^ | High | Low | Unclear | High | Low | High | Low | Low | Low | Low | Unclear | Low | Low | Low | Medium
Backer, 2014^3^ | Low | Low | Medium | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | High | Medium
Berkman, 2005^4^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Berlyne, 2000^5^ | High | Low | High | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | High
Bommarito, 2007^6^ | High | Low | Unclear | Unclear | Low | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low
Cordeiro, 2011^7^ | High | Low | Low | Low | Low | Low | Low | Low | Low | Low | Unclear | Low | Low | Medium | Medium
Deykin, 2002^8^ | High | Low | Low | Low | Low | Low | Low | Low | Low | Low | Unclear | Unclear | Unclear | Low | Medium
Dupont, 2003^9^ | Low | Low | Low | Low | Low | Low | Low | Low | High | Low | Low | Low | Low | Low | Medium
Florentin 2014^10^ | High | High | Low | Medium | Low | Low | Low | Low | Low | Low | Low | Low | Low | High | High
Fortuna, 2007^11^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Fukuhara, 2011^12^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Grzelewski, 2014^12^ | High | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | High | Medium
Heffler, 2006^14^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Henriksen, 2000^15^ | High | Low | Low | Low | Low | Low | Low | High | Low | High | Low | Low | Low | High | High
Ishizuka, 2011^16^ | High | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | High | High
Jerzynska, 2014^17^ | High | Low | Low | Low | Low | Low | Low | High | High | High | High | High | Low | High | High
Katsoulis, 2013^18^ | Low | Low | Low | Unclear | Low | Low | Low | Low | Low | Unclear | Low | Low | Low | High | Medium
Kostikas, 2008^19^ | Unclear | Low | Low | Low | Low | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Medium
Lemiere, 2010^20^ | Unclear | Low | Low | Low | Low | Unclear | Low | Low | Low | Low | Unclear | Low | Low | Low | Low
Malinovschi, 2012^21^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Martin, 2016^22^ | Unclear | Low | Low | Low | Low | High | High | Low | Low | Low | Low | Low | Low | High | High
Matsunaga, 2011^23^ | Unclear | Low | Low | Low | Low | Low | Low | High | High | High | Low | Low | Low | Low | High
Menzies, 2007^24^ | High | Low | Unclear | Low | Unclear | Unclear | Low | High | Low | High | Unclear | High | High | Low | High
Miedinger, 2007^25^ | High | Low | High | High | Low | Unclear | Low | Low | Unclear | Low | Unclear | Low | Low | Low | Medium
Miedinger, 2009^26^ | Unclear | Low | High | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | High | Low
Munnik, 2009^27^ | High | Low | High | Low | Low | Unclear | Low | Low | Low | Low | Unclear | Low | Low | Low | Medium
Nayak, 2013^28^ | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Medium
Pedrosa, 2010^29^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Unclear | Low | Low | Low | Low
Perez Tarazona, 2011^30^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Pizzimenti, 2009^31^ | Low | Low | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low | Unclear | Unclear | Medium
Ramser, 2008^32^ | Low | Low | Unclear | Low | Low | Unclear | Low | High | Low | High | Unclear | Low | Low | Low | Low
Sachs-Olsen, 2010^33^ | Unclear | Low | Unclear | Low | Low | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low
Sato, 2008^34^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Schleich, 2012^35^ | High | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Medium
Schneider, 2009^38^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Schneider, 2012 Schneider, 2014^36, 37^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Sivan, 2009^39^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Smith, 2004^40^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Medium | Low
Thomas, 2005^41^ | High | Low | Low | Low | Medium | Low | Low | High | High | High | Low | Low | Low | High | High
Traves, 2007^42^ | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Woo, 2012^43^ | Low | Low | Unclear | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low | Low
Yao, 2011^44^ | Low | Low | Low | Low | Low | Low | Low | Low | Low | High | Low | Low | Low | Low | Medium

Table G.2 Risk of Bias for RCTs (Cochrane ROB tool) for studies answering KQ 1b

Author, Year (ref) | Sequence Generation | Allocation Concealment | Blinding of Participants, Personnel | Blinding of Outcome Assessors | Incomplete Outcome Data | Selective Outcome Reporting | Other Sources of Bias | Overall RoB
| High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear
Beck-Ripp, 2002^100^ | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Unclear | High
Beerthuizen, 2016^46^ | Low | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Fritsch, 2006^54^ | Low | Unclear | Low | Unclear | Unclear | Unclear | Low | Unclear
Powell, 2011^111^ | Low | Low | Low | Low | Low | Low | Low | Low
Szefler, 2008^88^ | Low | Low | Low | Low | Low | Low | Low | Low
Voorend-van Bergen, 2015^93^ | Low | High | Low | High | Low | Low | Low | High
Zeiger, 2006^98^ | Low | Unclear | Low | Low | Low | Low | Unclear | Unclear

Table G.3 Risk of Bias for observational studies (Newcastle-Ottawa Quality Assessment Scale) for studies answering KQ 1b

Author, Year (ref) | Representativeness of the Study Population | Ascertainment of Exposure | Comparability of Cohorts On the Basis Of the Design or Analysis | Assessment of Outcome | Follow-up Long Enough for Outcomes to Occur | Adequacy of Follow up Of Cohorts | Overall RoB
Agache, 2012^45^ | Low | Low | Low | Low | Low | High | Low
Bernstein, 2009^48^ | Unclear | Unclear | Low | Low | Low | Low | Medium
Berg, 2008^47^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear
Bora, 2011^49^ | High | High | High | Low | Low | Low | High
Cano-Garcinuño, 2010^50^ | Low | Low | Unclear | Low | Unclear | Low | Low
Ciprandi, 2013^51^ | Low | Low | Low | Low | Unclear | Low | Low
de Bot, 2013^52^ | Low | Low | Unclear | Low | High | Low | Medium
Delclaux, 2008^53^ | Low | Low | Low | Low | Unclear | High | Medium
Gelb, 2006^55^ | Low | Low | Low | Low | Low | Low | Low
Gill, 2005^56^ | High | Low | High | Low | Low | Low | High
Griese, 2000^57^ | Low | Low | Low | Low | Low | Low | Low
Gruffydd-Jones, 2007^58^ | Low | Low | Low | Low | Low | Low | Low
Habib, 2014^59^ | High | High | High | High | High | High | High
Hanson, 2013^60^ | Low | High | High | Low | High | High | High
Harkins, 2004^61^ | Low | Low | High | Low | Medium | Low | Medium
Hayata, 2013^62^ | Unclear | Low | High | Low | High | Low | Medium
Hsu, 2013^63^ | Unclear | Unclear | Low | Low | Unclear | Unclear | High
Kavitha, 2017^64^ | Low | Low | Unclear | Low | Medium | High | Medium
Ko, 2011^65^ | Unclear | Low | Low | Low | Low | Low | Low
Kostikas, 2011^66^ | Medium | Low | Medium | Low | Unclear | Low | Medium
Kwok, 2008^67^ | Unclear | Low | Unclear | Low | High | Low | High
Leblanc, 2013^68^ | Unclear | Low | High | Low | Low | Low | Medium
Lex, 2007^69^ | Low | Low | Unclear | Low | Unclear | Unclear | Medium
Mahut, 2010^70^ | Low | Low | Unclear | Low | Unclear | Low | Low
Malerba, 2012^118^ | Low | Low | Unclear | Low | Low | Low | Low
Martins, 2008^71^ | High | High | High | High | Low | High | High
McCormack, 2013^72^ | Low | Low | Low | Low | Low | Low | Low
Menzies, 2008^73^ | Unclear | Low | Low | Low | Low | Low | Low
Meyts, 2003^74^ | High | Low | High | High | Low | Low | High
Michils, 2008^75^ | Low | Low | Unclear | Low | Low | Low | Low
Michils, 2009^76^ | Low | Unclear | Low | Unclear | Low | Unclear | Medium
Nayak, 2013^28^ | Unclear | Low | Low | Low | High | Unclear | Medium
Nittner-Marszalska, 2013^77^ | Unclear | Low | Low | Low | Low | Low | Low
Ozier, 2011^78^ | Low | Low | Low | Medium | Low | Low | Medium
Papakosta, 2011^79^ | Low | Low | Unclear | Low | Low | Unclear | Medium
Plaza, 2013^80^ | Low | Low | Unclear | Low | Low | Low | Low
Quaedvlieg, 2009^81^ | Low | Low | Low | Low | Unclear | Low | Low
Raj, 2014^82^ | Low | Unclear | Unclear | Low | Unclear | Unclear | Medium
Ricciardolo, 2016^83^ | Low | High | Unclear | Low | Unclear | High | High
Robroeks, 2007^84^ | High | High | High | Low | High | High | High
Rosias, 2004^85^ | Low | Low | Unclear | Low | Unclear | Low | Medium
Sato, 2009^86^ | Unclear | Unclear | Low | Unclear | Low | Unclear | Medium
Shirai, 2008^87^ | Medium | Medium | Low | Low | High | Low | High
van der Valk, 2012^89^ | High | Unclear | Unclear | Low | Low | Low | Medium
van Vliet, 2015^90^ | Unclear | Low | Unclear | Low | Low | Low | Low
Vijverberg, 2012^101^ | Low | Low | Low | Low | High | Low | Medium
Visitsunthorn, 2013^91^ | High | High | Low | High | High | High | High
Visitsunthorn, 2017^92^ | Low | Low | Medium | Low | Low | Low | Low
Warke, 2004^94^ | High | Low | Unclear | Low | Low | Unclear | High
Yamashita, 2015^95^ | Low | Low | Medium | Low | Low | High | High
Yang, 2015^96^ | High | Low | Unclear | Low | Low | Low | Medium
Yavuz, 2012^97^ | Low | Low | Low | Low | Low | High | Low
Zeiger, 2011^99^ | Low | Unclear | Low | Low | Unclear | Low | Medium

Table G.4 Risk of Bias for RCTs (Cochrane ROB tool) for studies answering KQ 1c

Author, Year (ref) | Sequence Generation | Allocation Concealment | Blinding of Participants, Personnel | Blinding of Outcome Assessors | Incomplete Outcome Data | Selective Outcome Reporting | Other Sources of Bias | Overall RoB
| High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear
Calhoun, 2012^102^ | Unclear | Unclear | Low | Low | Low | Low | Unclear | Unclear
De Jongste, 2009^103^ | Low | Unclear | High | Unclear | Low | Low | Low | High
Hashimoto, 2011^104^ | Low | Unclear | High | High | Low | Low | Low | High
Honkoop, 2015^105^ | Low | Low | High | High | Low | Low | Low | High
Malerba, 2015^106^ | High | High | Low | High | Low | Low | Low | Unclear
Peirsman, 2014^107^ | High | High | Low | High | Low | Low | Low | High
Petsky, 2015^108^ | Low | Low | Low | Low | Low | Low | Low | Low
Pijnenburg, 2005^109^ | High | High | High | High | Low | Low | Low | High
Pike, 2013^110^ | Low | Low | Low | Low | Low | Low | Low | Low
Powell, 2011^111^ | Low | Low | Low | Low | Low | Low | Low | Low
Shaw, 2007^112^ | Low | Low | Low | High | Low | Low | Low | Low
Smith, 2005^113^ | Low | Unclear | Low | High | Low | Low | Low | Unclear
Syk, 2013^114^ | Low | Low | High | High | Low | Low | Low | High
Verini, 2010^115^ | Low | Unclear | High | Unclear | Low | Low | Low | High

Table G.5 Risk of Bias for observational studies (Newcastle-Ottawa Quality Assessment Scale) for studies answering KQ 1c

Author, Year (ref) | Representativeness of the Study Population | Ascertainment of Exposure | Comparability of Cohorts On the Basis Of the Design or Analysis | Assessment of Outcome | Follow-up Long Enough for Outcomes to Occur | Adequacy of Follow up Of Cohorts | Overall RoB
| High/Medium/Low/Unclear | High/Medium/Low/Unclear | High/Medium/Low/Unclear | High/Medium/Low/Unclear | High/Medium/Low/Unclear | High/Medium/Low/Unclear | High/Medium/Low
Ciolkowski, 2016^120^ | High | High | High | Low | Low | Low | High
Cowan, 2015^121^ | Low | Low | Low | Low | Unclear | Low | Low
Griese, 2000^57^ | Low | Low | Low | Low | Low | Low | Low
Laforce, 2014^116^ | High | High | Low | Low | Unclear | Unclear | High
Mahut, 2011^122^ | Unclear | Low | Low | Low | High | Low | Medium
Malerba, 2008^117^ | Unclear | Low | Unclear | Low | Low | Low | Medium
Malerba, 2012^118^ | Low | Low | Unclear | Low | Low | Low | Low
Martin, 2016^22^ | Low | Low | High | Low | Low | Low | Low
Smith, 2005^123^ | Low | Low | Low | Low | Low | Low | Low
Wan, 2014^119^ | High | Low | High | Low | Low | Low | High

Table G.6 Risk of Bias for RCTs (Cochrane ROB tool) for studies answering KQ 1d

Author, Year (ref) | Sequence Generation | Allocation Concealment | Blinding of Participants, Personnel | Blinding of Outcome Assessors | Incomplete Outcome Data | Selective Outcome Reporting | Other Sources of Bias | Overall RoB
| High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear | High/Low/Unclear
Beck-Ripp, 2002^100^ | Unclear | Unclear | Unclear | Unclear | Unclear | Low | Unclear | High
Bisgaard, 1999^124^ | Low | Unclear | Low | Low | Unclear | Low | Low | Unclear
Ehrs, 2010^135^ | Low | Unclear | Low | Low | Low | Low | Low | Low
Erin, 2008^136^ | Low | Low | Low | Low | High | Low | High | High
Fuglsang, 1998^151^ | Low | Unclear | Low | Low | Low | Low | Low | Low
Hoshino, 2016^153^ | High | High | High | Unclear | Low | Low | Low | High
Hozawa, 2014^138^ | Low | Unclear | Low | High | Low | Low | High | High
Inoue, 2016^152^ | Low | Low | Unclear | unclear | Low | Low | Low | Low
Kharitonov, 1996^140^ | Unclear | Unclear | Low | Low | Low | Low | Unclear | Unclear
Kharitonov, 2002^141^ | Low | Unclear | Low | Low | Low | Low | Low | Low
Mallol, 2016^142^ | High | High | Low | Unclear | Low | Low | Low | High
Montuschi, 2007^126^ | Low | Unclear | Low | Low | Low | Low | Low | Low
Nolte, 2013^143^ | Low | Unclear | Low | Low | Low | Low | Unclear | Unclear
Obase, 2013^159^ | Low | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Profita, 2013^145^ | Unclear | Unclear | Low | Low | Low | Low | Low | Unclear
Sandrini, 2003^128^ | Low | Unclear | Unclear | Unclear | Low | Low | Low | Unclear
Silkoff, 2004^129^ | Low | Low | Low | Low | Low | Low | Unclear | Low
Verini, 2007^150^ | Low | Unclear | High | Low | Low | Low | Low | Unclear
Yates, 1997^154^ | Low | Unclear | Low | Low | Low | Low | Low | Low
Zeiger, 2006^98^ | Low | Unclear | Low | Low | Low | Low | Unclear | Unclear

Table G.7 Risk of Bias for for observational studies (Newcastle-Ottawa Quality Assessment Scale) for studies answering KQ 1d

Author, Year (ref) | Representativeness of the Study Population | Ascertainment of Exposure | Comparability of Cohorts On the Basis Of the Design or Analysis | Assessment of Outcome | Follow-up Long Enough for Outcomes to Occur | Adequacy of Follow up Of Cohorts | Overall RoB
Baraldi, 1997^131^ | Low | Low | Unclear | Low | High | Low | High
Bratton, 1999^125^ | Low | Low | Low | Low | High | High | High
Bulac, 2015^132^ | Low | Low | Low | Low | Low | Low | Low
Byrnes, 1997^133^ | Medium | Low | Unclear | Low | Medium | Unclear | Medium
Cabral, 2009^155^ | Low | Low | Unclear | Low | Low | High | Medium
Dupont, 1998^134^ | Medium | Low | Unclear | Low | High | High | High
Gelb, 2008^137^ | Unclear | Low | High | Low | Unclear | Low | High
Hojo, 2013^156^ | Unclear | Low | Low | Low | Low | Low | Low
Jones, 2001^157^ | Low | Low | Low | Low | Low | Low | Low
Kermode, 2011^139^ | Low | Low | High | Low | Low | Low | Medium
Liu, 2010^158^ | Low | Low | Unclear | Low | Low | High | Medium
Ohkura, 2009^127^ | Low | Low | Unclear | Low | Low | Low | Low
Park, 2016^144^ | Low | Low | High | Low | Low | Low | Medium
Pijnenburg, 2005^160^ | Low | Low | Low | Low | Low | Low | Low
Prieto, 2003^161^ | High | Low | Low | Low | Low | Low | High
Silkoff, 2001^146^ | Unclear | Low | Low | Low | High | Unclear | High
Smith, 2015^147^ | Unclear | Low | High | Low | Low | Low | Medium
Spallarossa, 2001^148^ | Low | Low | Low | Low | Unclear | High | Medium
Tajiri, 2014^130^ | Low | Low | Unclear | Low | High | Low | Medium
Thomas 2016 | Low | Low | Low | Low | Low | Low | Low
Tsurikisawa, 2012^162^ | Low | Low | Low | Low | Low | Low | Low

Table G.8 Risk of Bias for observational studies (Newcastle-Ottawa Quality Assessment Scale) for studies answering KQ 1e

Author, Year (ref) | Representativeness of the Study Population | Ascertainment of Exposure | Comparability of Cohorts On the Basis Of the Design or Analysis | Assessment of Outcome | Follow-up Long Enough for Outcomes to Occur | Adequacy of Follow up Of Cohorts | Overall RoB
Balinotti, 2013^163^ | Low | Low | Low | Low | Low | Low | Low
Bloemen, 2010^164^ | High | High | Low | Low | High | Low | High
Castro-Rodriguez, 2013^165^ | Low | Low | Low | Low | Low | Low | Low
Caudri, 2010^166^ | Low | Low | Low | Low | Low | Low | Low
Chang, 2015^167^ | Low | Low | Low | Low | Low | Low | Low
Elliot, 2013^168^ | Unclear | Unclear | Unclear | Low | Low | High | High
Klaassen, 2012^169^ | Low | Low | Unclear | Low | Low | Low | Low
Prado, 2011^170^ | Low | Unclear | High | Low | Unclear | Unclear | Medium
van Wonderen, 2009 ^171^ | Low | Low | Unclear | Low | Low | Low | Low