# Appendix F Sensitivity Analysis

## KQ 1.a What is the diagnostic accuracy of FeNO measurement(s) for making the diagnosis of asthma in individuals ages 5 and older?

Table F.1 Including only studies with ICS naiive or atopy

FeNO CutOff | Number of Included Studies | Conclusion
Not taking ICS | 13 studies | Sensitivity 0.57; 95% CI (0.46 to 0.67) Specificity 0.85; 95% CI (0.78 to 0.91) DOR 7.76; 95% CI (4.94 to 12.18) LR+ 3.91; 95% CI (2.73 to 5.61) LR− 0.50; 95% CI (0.41 to 0.62)
<20 ppb | 6 studies | Sensitivity 0.79; 95% CI (0.67 to 0.87) Specificity 0.77; 95% CI (0.56 to 0.90) DOR 12.25; 95% CI (5.73 to 26.21) LR+ 3.40; 95% CI (1.75 to 6.61) LR− 0.28; 95% CI (0.19 to 0.40)
20–30 ppb | 8 studies | Sensitivity 0.59; 95% CI (0.45 to 0.71) Specificity 0.84; 95% CI (0.69 to 0.92) DOR 7.25; 95% CI (2.70 to 19.44) LR+ 3.60; 95% CI (1.73 to 7.47) LR− 0.50; 95% CI (0.35 to 0.70)
30–40 ppb | 6 studies | Sensitivity 0.37; 95% CI (0.26 to 0.49) Specificity 0.88; 95% CI (0.81 to 0.93) DOR 4.16; 95% CI (2.71 to 6.39) LR+ 3.01; 95% CI (2.11 to 4.28) LR− 0.72; 95% CI (0.62 to 0.84)
Atopic | 4 studies | Sensitivity 0.63; 95% CI (0.43 to 0.80) Specificity 0.79; 95% CI (0.65 to 0.89) DOR 6.67; 95% CI (1.59 to 27.95) LR+ 3.07; 95% CI (1.35 to 6.97) LR− 0.46; 95% CI (0.24 to 0.87)

CI: confidence interval; DOR: diagnostic odds ratio; FeNO: fraction exhaled nitric oxide; ICS: inhaled corticosteroid; LR+: positive likelihood ratio; LR−: negative likelihood ratio; ppb: parts per billion.