# Appendix E Subgroup Analyses

## KQ 1.a What is the diagnostic accuracy of FeNO measurement(s) for making the diagnosis of asthma in individuals ages 5 and older?

Table E.1 Subgroup analysis (reference group: healthy versus symptomatic individuals without asthma)

FeNO CutOff | Subgroup | Number of Included Studies | Conclusion
<20 ppb | Healthy | 13 studies | Sensitivity 0.82; 95% CI (0.72 to 0.90) Specificity 0.78; 95% CI (0.62 to 0.88) DOR 16.45; 95% CI (7.85 to 34.49) LR+ 3.71; 95% CI (2.14 to 6.43) LR− 0.23; 95% CI (0.14 to 0.36)
| Symptomatic no asthma | 9 studies | Sensitivity 0.73; 95% CI (0.60 to 0.83) Specificity 0.62; 95% CI (0.45 to 0.77) DOR 4.42; 95% CI (2.33 to 8.35) LR+ 1.92; 95% CI (1.32 to 2.78) LR− 0.43; 95% CI (0.30 to 0.63)
20–30 ppb | Healthy | 10 studies | Sensitivity 0.67; 95% CI (0.52 to 0.79) Specificity 0.77; 95% CI (0.64 to 0.86) DOR 6.82; 95% CI (2.87 to 16.17) LR+ 2.92; 95% CI (1.74 to 4.88) LR− 0.43; 95% CI (0.28 to 0.66)
| Symptomatic no asthma | 13 studies | Sensitivity 0.57; 95% CI (0.47 to 0.67) Specificity 0.84; 95% CI (0.76 to 0.90) DOR 7.30; 95% CI (4.57 to 11.66) LR+ 3.68; 95% CI (2.51 to 5.39) LR− 0.50; 95% CI (0.41 to 0.62)
30–40 ppb | Symptomatic no asthma | 6 studies | Sensitivity 0.57; 95% CI (0.32 to 0.79) Specificity 0.87; 95% CI (0.76 to 0.93) DOR 8.89; 95% CI (4.65 to 17.01) LR+ 4.38; 95% CI (2.96 to 6.50) LR− 0.49; 95% CI (0.29 to 0.84)

CI: confidence interval; DOR: diagnostic odds ratio; FeNO: fraction exhaled nitric oxide; LR+: positive likelihood ratio; LR-: negative likelihood ratio; NA: not available; ppb: parts per billion

Table E.2 Subgroup analysis based on risk of bias

FeNO CutOff | Subgroup | Number of Included Studies | Conclusion
<20 ppb | Low risk of bias | 11 studies | Sensitivity 0.80; 95% CI (0.67 to 0.88) Specificity 0.69; 95% CI (0.48 to 0.84) DOR 8.81; 95% CI (4.27 to 18.20) LR+ 2.57; 95% CI (1.50 to 4.45) LR− 0.29; 95% CI (0.19 to 0.45)
<20 ppb | Moderate risk of bias | 6 studies | Sensitivity 0.74; 95% CI (0.62 to 0.84) Specificity 0.78; 95% CI (0.64 to 0.88) DOR 10.33; 95% CI (3.68 to 29.02) LR+ 3.4; 95% CI (1.85 to 6.27) LR− 0.33; 95% CI (0.20 to 0.54)
<20 ppb | High risk of bias | 5 studies | Sensitivity 0.84; 95% CI (0.60 to 0.95) Specificity 0.68; 95% CI (0.41 to 0.86) DOR 11.29; 95% CI (2.75 to 46.30) LR+ 2.63; 95% CI (1.28 to 5.41) LR− 0.23; 95% CI (0.09 to 0.64)
20–30 ppb | Low risk of bias | 13 studies | Sensitivity 0.68; 95% CI (0.56 to 0.78) Specificity 0.78; 95% CI (0.67 to 0.85) DOR 7.29; 95% CI (4.12 to 12.91) LR+ 3.03; 95% CI (2.09 to 4.40) LR− 0.42; 95% CI (0.30 to 0.57)
20–30 ppb | Moderate risk of bias | 6 studies | Sensitivity 0.53; 95% CI (0.43 to 0.62) Specificity 0.84; 95% CI (0.61 to 0.94) DOR 5.77; 95% CI (1.65 to 20.21) LR+ 3.26; 95% CI (1.18 to 8.99) LR− 0.56; 95% CI (0.43 to 0.75)
30–40 ppb | Low risk of bias | 5 studies | Sensitivity 0.57; 95% CI (0.37 to 0.74) Specificity 0.79; 95% CI (0.72 to 0.85) DOR 5.02; 95% CI (2.66 to 9.44) LR+ 2.75; 95% CI (2.05 to 3.67) LR− 0.55; 95% CI (0.37 to 0.81)
30–40 ppb | Moderate risk of bias | 4 studies | Sensitivity 0.37; 95% CI (0.21 to 0.57) Specificity 0.91; 95% CI (0.82 to 0.95) DOR 5.83; 95% CI (3.28 to 10.37) LR+ 4.04; 95% CI (2.52 to 6.46) LR− 0.69; 95% CI (0.54 to 0.89)
>=40 ppb | Low risk of bias | 7 studies | Sensitivity 0.41; 95% CI (0.24 to 0.59) Specificity 0.92; 95% CI (0.85 to 0.96) DOR 8.3; 95% CI (5.38 to 12.79) LR+ 5.33; 95% CI (3.59 to 7.91) LR− 0.64; 95% CI (0.50 to 0.83)

CI: confidence interval; DOR: diagnostic odds ratio; FeNO: fraction exhaled nitric oxide; LR+: positive likelihood ratio; LR-: negative likelihood ratio; NA: not available; ppb: parts per billion.

Table E.3 Subgroup analysis based on smoking status

Subgroup | Number of Included Studies | Conclusion
Non smokers | 17 studies | Sensitivity 0.70; 95% CI (0.61 to 0.78) Specificity 0.80; 95% CI (0.74 to 0.85) DOR 9.49; 95% CI (5.62 to 16.01) LR+ 3.51; 95% CI (2.62 to 4.70) LR− 0.37; 95% CI (0.27 to 0.50)
Current Smokers | 1 study | Sensitivity 0.63 Specificity 0.86 DOR 10.64 LR+ 4.50 LR− 0.43
Ex-smokers | 1 study | Sensitivity: 0.53 Specificity: 0.83 DOR: 5.46 LR+: 3.10 LR−: 0.57
Smokers | 1 study | Sensitivity 0.29 Specificity 0.86 DOR 2.53 LR+ 2.07 LR− 0.83

CI: confidence interval; DOR: diagnostic odds ratio; LR+: positive likelihood ratio; LR−: negative likelihood ratio.

Table E.4 Subgroup analysis based on age

FeNO CutOff | Subgroup | Number of Included Studies | Conclusion
<20 ppb | 18 years or older | 12 studies | Sensitivity 0.80; 95% CI (0.72 to 0.86) Specificity 0.64; 95% CI (0.46 to 0.79) DOR 7.28; 95% CI (4.04 to 13.11) LR+ 2.25; 95% CI (1.47 to 3.44) LR− 0.31; 95% CI (0.23 to 0.41)
<20 ppb | Younger than 18 years | 6 studies | Sensitivity 0.78; 95% CI (0.59 to 0.90) Specificity 0.79; 95% CI (0.55 to 0.92) DOR 13.44; 95% CI (3.56 to 50.71) LR+ 3.76; 95% CI (1.53 to 9.26) LR− 0.28; 95% CI (0.14 to 0.56)
20–30 ppb | 18 years or older | 6 studies | Sensitivity 0.69; 95% CI (0.57 to 0.79) Specificity 0.78; 95% CI (0.66 to 0.86) DOR 7.70; 95% CI (4.12 to 14.40) LR+ 3.10; 95% CI (2.02 to 4.74) LR− 0.40; 95% CI (0.29 to 0.56)
20–30 ppb | Younger than 18 years | 6 studies | Sensitivity 0.61; 95% CI (0.44 to 0.76) Specificity 0.89; 95% CI (0.80 to 0.94) DOR 12.13; 95% CI (5.98 to 24.63) LR+ 5.34; 95% CI (3.12 to 9.14) LR− 0.44; 95% CI (0.30 to 0.65)
30–40 ppb | 18 years or older | 9 studies | Sensitivity 0.53; 95% CI (0.35 to 0.70) Specificity 0.85; 95% CI (0.77 to 0.90) DOR 6.27; 95% CI (3.70 to 10.64) LR+ 3.46; 95% CI (2.57 to 4.66) LR− 0.55; 95% CI (0.39 to 0.78)
>=40 ppb | 18 years or older | 7 studies | Sensitivity 0.41; 95% CI (0.24 to 0.62) Specificity 0.93; 95% CI (0.86 to 0.97) DOR 9.84; 95% CI (5.46 to 17.75) LR+ 6.18; 95% CI (3.64 to 10.47) LR− 0.63; 95% CI (0.47 to 0.85)
>=40 ppb | Younger than 18 years | NA | NA

CI: confidence interval; DOR: diagnostic odds ratio; LR+: positive likelihood ratio; LR−: negative likelihood ratio; NA: not available; ppb: parts per billion.