# Appendix C Description of Included Studies

Table C.1 Characteristics of the included studies in KQ 1a

Table C.2 Characteristics of the included studies in KQ 1b

Table C.3 Characteristics of the included studies in KQ 1b (Adherence)

Table C.4 Characteristics of the included studies in KQ 1c (Algorithm using FeNO to guide drug therapy for RCTs)

Table C.5 Characteristics of the included studies in KQ 1c (Algorithm using FeNO to guide drug therapy NON-RCTs)

Table C.6 Characteristics of the included studies in KQ 1c (Drug selection)

Table C.7 Characteristics of the included studies in KQ 1d FeNO response to administration of Leukotriene receptor antagonists (LTRA)

Table C.8 Characteristics of the included studies in KQ 1d FeNO response to administration of Omalizumab

Table C.9 Characteristics of the included studies in KQ 1d FeNO response to administration of Cortisone

Table C.10 Characteristics of the included studies in KQ 1d FeNO response to administration of bronchodilators (beta agonists and anticholinergics)

Table C.11 Characteristics of the included studies in KQ 1d for FeNO use for ICS reduction or withdrawal

Table C.12 Characteristics of the included studies in KQ 1e