# Appendix B Excluded Studies

Abuzayan I, Turner SW. Changes in exhaled nitric oxide after ingestion of L-arginine in children: a pilot study. Pediatr Pulmonol. 2010 Mar;45(3):236–40. doi: 10.1002/ppul.21110. PMID: 20131381. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20131381
Acouetey DS, Zmirou-Navier D, Avogbe PH, . Genetic predictors of inflammation in the risk of occupational asthma in young apprentices. Ann Allergy Asthma Immunol. 2013 Jun;110(6):423–8 e5. doi: 10.1016/j.anai.2013.04.005. PMID: 23706710. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23706710
Adar SD, D’Souza J, Sheppard L, . Adopting Clean Fuels and Technologies on School Buses. Pollution and Health Impacts in Children. Am J Respir Crit Care Med. 2015 Jun 15;191(12):1413–21. doi: 10.1164/rccm.201410-1924OC. PMID: 25867003 The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)25867003
Adema, A Y, Verwey, . Effect of a short-term stay in a high altitude clinic. Tijdschrift voor Kindergeneeskunde. 2009;77(1):30–6. The study does not evaluate FeNO.
Adisesh LA, Kharitonov SA, Yates DH, . Exhaled and nasal nitric oxide is increased in laboratory animal allergy. Clinical and Experimental Allergy. 1998 Jul;28(7):876–80. DOI: 10.1046/j.1365-2222.1998.00332.x. PMID: WOS:000075104800014. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)9720822
Akamatsu T, Shirai T, Kato M, . Effect of switching from salmeterol/fluticasone to formoterol/budesonide combinations in patients with uncontrolled asthma. Allergol Int. 2012 Jun;61(2):323–9. doi: 10.2332/allergolint.11-OA-0384. PMID: 22441635. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22441635
Akamatsu T, Shirai T, Kato M, . Switching from salmeterol/fluticasone to formoterol/budesonide combinations improves peripheral airway/alveolar inflammation in asthma. Pulm Pharmacol Ther. 2014 Feb;27(1):52–6. doi: 10.1016/j.pupt.2013.04.001. PMID: 23583566. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23583566
Akashi K, Mezawa H, Tabata Y, . Optimal step-down approach for pediatric asthma controlled by salmeterol/fluticasone: A randomized, controlled trial (OSCAR study). Allergol Int. 2016 Jul;65(3):306–11. doi: 10.1016/j.alit.2016.02.010. PMID: 27155753. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)27155753
Al-Ali MK, Eames C, Howarth PH. Exhaled nitric oxide; relationship to clinicophysiological markers of asthma severity. Respiratory Medicine. 1998 Jul;92(7):908–13. doi: Doi 10.1016/S0954-6111(98)90189-5. PMID: WOS:000075609700003. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10070563
Al-Ali MK, Howarth PH. Exhaled nitric oxide levels in exacerbations of asthma, chronic obstructive pulmonary disease and pneumonia. Saudi Med J. 2001 Mar;22(3):249–53. PMID: 11307112. The study does not have a comparison group (studies must have a comparison group or pre/post design)11307112
Alcazar-Navarrete B, Romero-Palacios PJ, Ruiz-Sancho A, . Diagnostic performance of the measurement of nitric oxide in exhaled air in the diagnosis of COPD phenotypes. Nitric Oxide-Biology and Chemistry. 2016 Apr 1;54:67–72. doi: 10.1016/j.niox.2016.02.003. PMID: WOS:000373658000008. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)26916083
Ali M, Khoo SK, Turner S, . NOS1 polymorphism is associated with atopy but not exhaled nitric oxide levels in healthy children. Pediatr Allergy Immunol. 2003 Aug;14(4):261–5. doi: 10.1034/j.1399-3038.2003.00065.x. PMID: 12911502. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)12911502
Allen RW, Mar T, Koenig J, . Changes in lung function and airway inflammation among asthmatic children residing in a woodsmoke-impacted urban area. Inhalation Toxicology. 2008 February;20(4):423–33. doi: 10.1080/08958370801903826. PMID: WOS:000253642800006. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18302050
Alvarez-Gutierrez FJ, Medina-Gallardo JF, Perez-Navarro P, . [Comparison of the Asthma Control Test (ACT) with lung function, levels of exhaled nitric oxide and control according to the Global Initiative for Asthma (GINA)]. Arch Bronconeumol. 2010 Jul;46(7):370–7. doi: 10.1016/j.arbres.2010.04.003. PMID: 20605310. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20605310
Alvarez-Puebla MJ, Olaguibel JM, Almudevar E, . Mannitol versus hypertonic saline: Safety and efficacy of mannitol and hypertonic saline in sputum induction and bronchial hyperreactivity assessment. Chronic Respiratory Disease. 2015 Aug;12(3):197–203. doi: 10.1177/1479972315576144. PMID: WOS:000358381700003. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25761367
Amer, M, Cowan, . Effect of inhaled beta2-agonist on exhaled nitric oxide in chronic obstructive pulmonary disease. PLoS ONE. 2016 01 Jun;11 (6) (no pagination)(e0157019). doi: 10.1371/journal.pone.0157019. PMID: 20160431719. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)27258087
Amimoto, Y, Arakaki, . Relationship between compliance with inhaled corticosteroids and changes in the fraction of exhaled nitric oxide during summer camp for asthmatic children. Japanese Journal of Allergology. 2011;60(12):1641–5. doi: 10.15036/arerugi.60.1641. The study is not original (commentaries, letters, etc. should be excluded)22343779
Amore M, Antonucci C, Bettini E, . Disease Control in Patients with Asthma is Associated with Alexithymia but not with Depression or Anxiety. Behavioral Medicine. 2013 Oct 1;39(4):138–45. doi: 10.1080/08964289.2013.818931. PMID: WOS:000327945800006. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24236811
Anderson WJ, Lipworth BJ. Does body mass index influence responsiveness to inhaled corticosteroids in persistent asthma? Ann Allergy Asthma Immunol. 2012 Apr;108(4):237–42. doi: 10.1016/j.anai.2011.12.006. PMID: 22469442. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22469442
Anderson WJ, Lipworth BJ. Relationship of mannitol challenge to methacholine challenge and inflammatory markers in persistent asthmatics receiving inhaled corticosteroids. Lung. 2012 Oct;190(5):513–21. doi: 10.1007/s00408-012-9396-6. PMID: 22684880. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22684880
Ansarin, K, Chatkin, . Exhaled nitric oxide in chronic obstructive pulmonary disease: Relationship to pulmonary function. European Respiratory Journal. 2001;17(5):934–8. PMID: 2001232784. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11488329
Antczak A, Kharitonov SA, Montuschi P, . Inflammatory response to sputum induction measured by exhaled markers. Respiration. 2005 Nov–Dec;72(6):594–9. doi: 10.1159/000086721. PMID: 15988171. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15988171
Arabkhazaeli A, Vijverberg SJ, van Erp FC, . Characteristics and severity of asthma in children with and without atopic conditions: a cross-sectional study. BMC Pediatr. 2015 Nov 06;15:172. doi: 10.1186/s12887-015-0481-x. PMID: 26545978. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26545978
Araujo L, Jacinto T, Moreira A, . Clinical efficacy of web-based versus standard asthma self-management. J Investig Allergol Clin Immunol. 2012;22(1):28–34. PMID: 22448451. Other reason22448451
Araujo L, Moreira A, Palmares C, . Induced sputum in children: success determinants, safety, and cell profiles. J Investig Allergol Clin Immunol. 2011;21(3):216–21. PMID: 21548450. The study does not evaluate FeNO21548450
Arga M, Bakirtas A, Topal E, . Can exhaled nitric oxide be a surrogate marker of bronchial hyperresponsiveness to adenosine 5′-monophosphate in steroid-naive asthmatic children? Clin Exp Allergy. 2015 Apr;45(4):758–66. doi: 10.1111/cea.12447. PMID: 25378028. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25378028
Arnold DH, Gebretsadik T, Abramo TJ, . Noninvasive testing of lung function and inflammation in pediatric patients with acute asthma exacerbations. J Asthma. 2012 Feb;49(1):29–35. doi: 10.3109/02770903.2011.637599. PMID: 22133263. The study does not have a comparison group (studies must have a comparison group or pre/post design)22133263
Aronsson D, Tufvesson E, Bjermer L. Allergic rhinitis with or without concomitant asthma: difference in perception of dyspnoea and levels of fractional exhaled nitric oxide. Clin Exp Allergy. 2005 Nov;35(11):1457–61. doi: 10.1111/j.1365-2222.2005.02363.x. PMID: 16297142. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16297142
Arroyave, W D, Rabito, . Asthma severity, not asthma control, is worse in atopic compared with nonatopic adolescents with asthma. Annals of Allergy, Asthma and Immunology. 2016 01 Jan;116(1):18–25. doi: 10.1016/j.anai.2015.10.015. PMID: 20160035478. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Arshad SH, Raza A, Lau L, . Pathophysiological characterization of asthma transitions across adolescence. Respir Res. 2014 Nov 29;15:153. doi: 10.1186/s12931-014-0153-7. PMID: 25472820. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25472820
Badorrek P, Dick M, Emmert L, . Pollen starch granules in bronchial inflammation. Ann Allergy Asthma Immunol. 2012 Sep;109(3):208–14 e6. doi: 10.1016/j.anai.2012.06.019. PMID: 22920077. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22920077
Baines KJ, Simpson JL, Wood LG, . Transcriptional phenotypes of asthma defined by gene expression profiling of induced sputum samples. J Allergy Clin Immunol. 2011 Jan;127(1):153–60, 60 e1–9. doi: 10.1016/j.jaci.2010.10.024. PMID: 21211650. Other reason21211650
Balboa de P, F, Rueda E, . Exhaled nitric oxygen in healthy and asthmatic children. [Spanish]. Anales Espanoles de Pediatria. 2002;57(1):12–7. PMID: 2002277965. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12139887
Baptist, A P, Ross, . Older adults with asthma: Does age of asthma onset make a difference? Journal of Asthma. 2013 October;50(8):836–41. doi: 10.3109/02770903.2013.816967. PMID: 2013584398. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23782329
Baptist AP, Li L, Dichiaro CA. The importance of atopy on exhaled nitric oxide levels in African American children. Ann Allergy Asthma Immunol. 2015 May;114(5):399–403. doi: 10.1016/j.anai.2015.02.005. PMID: 25752733. The study does not have a comparison group (studies must have a comparison group or pre/post design)25752733
Baptist AP, Sengupta R, Pranathiageswaran S, . Evaluation of exhaled nitric oxide measurements in the emergency department for patients with acute asthma. Ann Allergy Asthma Immunol. 2008 May;100(5):415–9. doi: 10.1016/S1081-1206(10)60464-4. PMID: 18517071. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18517071
Baptist AP, Shah B, Wang Y, . Exhaled nitric oxide levels during treatment in patients hospitalized with asthma. Allergy Asthma Proc. 2008 Mar–Apr;29(2):171–6. doi: 10.2500/aap.2008.29.3098. PMID: 18430315. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18430315
Baptist AP, Ross JA, Yang Y, . A randomized controlled trial of a self-regulation intervention for older adults with asthma. J Am Geriatr Soc. 2013 May;61(5):747–53. doi: 10.1111/jgs.12218. PMID: 23617712. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23617712
Baptist, Alan P, Shah, . Exhaled nitric oxide levels during treatment in patients hospitalized with asthma. Allergy & Asthma Proceedings. 2008 Mar–Apr;29(2):171–6. PMID: 18430315. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18430315
Baraket, Melissa, Oliver, . Is low dose inhaled corticosteroid therapy as effective for inflammation and remodeling in asthma? A randomized, parallel group study. Respiratory Research. 2012;13:11. PMID: 22300506. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22300506
Baraket M, Oliver BG, Burgess JK, . Is low dose inhaled corticosteroid therapy as effective for inflammation and remodeling in asthma? A randomized, parallel group study. Respir Res. 2012 Feb 02;13:11. doi: 10.1186/1465-9921-13-11. PMID: 22300506. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22300506
Baraldi E, Carra S, Dario C, . Effect of natural grass pollen exposure on exhaled nitric oxide in asthmatic children. Am J Respir Crit Care Med. 1999 Jan;159(1):262–6. doi: 10.1164/ajrccm.159.1.9804063. PMID: 9872848. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9872848
Baraldi E, Carraro S, Alinovi R, . Cysteinyl leukotrienes and 8-isoprostane in exhaled breath condensate of children with asthma exacerbations. Thorax. 2003 Jun;58(6):505–9. doi: 10.1136/thorax.58.6.505. PMID: 12775861. The study does not have a comparison group (studies must have a comparison group or pre/post design)12775861
Baraldi E, Ghiro L, Piovan V, . Safety and success of exhaled breath condensate collection in asthma. Arch Dis Child. 2003 Apr;88(4):358–60. doi: 10.1136/adc.88.4.358. PMID: 12651772. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12651772
Baraldi E, Giordano G, Pasquale MF, . 3-Nitrotyrosine, a marker of nitrosative stress, is increased in breath condensate of allergic asthmatic children. Allergy. 2006 Jan;61(1):90–6. doi: 10.1111/j.1398-9995.2006.00996.x. PMID: 16364162. Other reason16364162
Baraldi E, Scollo M, Zaramella C, . A simple flow-driven method for online measurement of exhaled NO starting at the age of 4 to 5 years. Am J Respir Crit Care Med. 2000 Nov;162(5):1828–32. doi: 10.1164/ajrccm.162.5.2002014. PMID: 11069821. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11069821
Baraldi E, Bonetto G, Zacchello F, . Low exhaled nitric oxide in school-age children with bronchopulmonary dysplasia and airflow limitation. Am J Respir Crit Care Med. 2005 Jan 01;171(1):68–72. doi: 10.1164/rccm.200403-298OC. PMID: 15477497. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)15477497
Baraldi E, Ghiro L, Piovan V, . Increased exhaled 8-isoprostane in childhood asthma. Chest. 2003 Jul;124(1):25–31. doi: 10.1378/chest.124.1.25. PMID: 12853498. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12853498
Barben J, Strippoli MP, Trachsel D, . Effect of mannitol dry powder challenge on exhaled nitric oxide in children. PLoS One. 2013 18 Jan;8(1):e54521. doi: 10.1371/journal.pone.0054521. PMID: 23349918. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23349918
Bardin P, Kanniess F, Gauvreau G, . Roflumilast for asthma: Efficacy findings in mechanism of action studies. Pulm Pharmacol Ther. 2015 Dec;35 Suppl:S4–10. doi: 10.1016/j.pupt.2015.08.006. PMID: 26296794. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26296794
Barraza-Villarreal A, Sunyer J, Hernandez-Cadena L, . Air pollution, airway inflammation, and lung function in a cohort study of Mexico City schoolchildren. Environ Health Perspect. 2008 Jun;116(6):832–8. doi: 10.1289/ehp.10926. PMID: 18560490. The study does not evaluate FeNO18560490
Barreto M, Bonafoni S, Barberi S, . Does a parent-reported history of pneumonia increase the likelihood of respiratory symptoms needing therapy in asthmatic children and adolescents? J Asthma. 2011 Sep;48(7):714–20. doi: 10.3109/02770903.2011.601779. PMID: 21793780. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21793780
Barreto M, Rennerova Z, Montesano M, . Variations in exhaled nitric oxide in children with asthma during a 1-week stay in a mountain village sanatorium. J Asthma. 2008 Aug;45(6):453–8. doi: 10.1080/02770900802040035. PMID: 18612896. The study does not have a comparison group (studies must have a comparison group or pre/post design)18612896
Barreto M, Villa MP, Olita C, . 8-Isoprostane in exhaled breath condensate and exercise-induced bronchoconstriction in asthmatic children and adolescents. Chest. 2009 Jan;135(1):66–73. doi: 10.1378/chest.08-0722. PMID: 18753466. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18753466
Barreto M, Villa MP, Montesano M, . Reduced exhaled nitric oxide in children after testing of maximal expiratory pressures. Pediatr Pulmonol. 2006 Feb;41(2):141–5. doi: 10.1002/ppul.20358. PMID: 16358341. The study does not have a comparison group (studies must have a comparison group or pre/post design)16358341
Barros R, Moreira A, Fonseca J, . Adherence to the Mediterranean diet and fresh fruit intake are associated with improved asthma control. Allergy. 2008 Jul;63(7):917–23. doi: 10.1111/j.1398-9995.2008.01665.x. PMID: 18588559. Other reason18588559
Barros R, Moreira A, Fonseca J, . Dietary intake of alpha-linolenic acid and low ratio of n-6:n-3 PUFA are associated with decreased exhaled NO and improved asthma control. British Journal of Nutrition. 2011 Aug 14;106(3):441–50. doi: 10.1017/S0007114511000328. PMID: 2011524628. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21443816
Battaglia S, den Hertog H, Timmers MC, . Small airways function and molecular markers in exhaled air in mild asthma. Thorax. 2005 Aug;60(8):639–44. doi: 10.1136/thx.2004.035279. PMID: 16061704. The study does not have a comparison group (studies must have a comparison group or pre/post design)16061704
Beck-Ripp J, Latzin P, Griese M. Exhaled carbon monoxide is not flow dependent in children with cystic fibrosis and asthma. Eur J Med Res. 2004 Nov 29;9(11):518–22. PMID: 15649862. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15649862
Beck J, Griese M, Latzin P, . Characteristics of flow dependency of nitric oxide in exhaled air in children with cystic fibrosis and asthma. Eur J Med Res. 1999 Aug 25;4(8):335–40. PMID: 10471545. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10471545
Beg MF, Alzoghaibi MA, Abba AA, . Exhaled nitric oxide in stable chronic obstructive pulmonary disease. Ann Thorac Med. 2009 Apr;4(2):65–70. doi: 10.4103/1817-1737.44649. PMID: 19561927. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)19561927
Behndig AF, Larsson N, Brown JL, . Proinflammatory doses of diesel exhaust in healthy subjects fail to elicit equivalent or augmented airway inflammation in subjects with asthma. Thorax. 2011 Jan;66(1):12–9. doi: 10.1136/thx.2010.140053. PMID: 20837873. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20837873
Beier J, Beeh KM, Kornmann O, . Sputum induction leads to a decrease of exhaled nitric oxide unrelated to airflow. Eur Respir J. 2003 Aug;22(2):354–7. doi: 10.1183/09031936.03.00118602. PMID: 12952273. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)12952273
Benor S, Alcalay Y, Domany KA, . Ultrafine particle content in exhaled breath condensate in airways of asthmatic children. J Breath Res. 2015 Apr 01;9(2):026001. doi: 10.1088/1752-7155/9/2/026001. PMID: 25830607. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25830607
Berce V, Potocnik U. Association of Q551R polymorphism in the interleukin 4 receptor gene with nonatopic asthma in Slovenian children. Wien Klin Wochenschr. 2010 May;122 Suppl 2(SUPPL. 2):11–8. doi: 10.1007/s00508-010-1339-8. PMID: 20517665. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20517665
Berce V, Repnik K, Potocnik U. Association of CCR5-delta32 mutation with reduced risk of nonatopic asthma in Slovenian children. J Asthma. 2008 Nov;45(9):780–4. doi: 10.1080/02770900802386024. PMID: 18972295. The study does not evaluate FeNO18972295
Berg J, Lindgren P. Economic evaluation of FE(NO) measurement in diagnosis and 1-year management of asthma in Germany. Respiratory Medicine. 2008 Feb;102(2):219–31. PMID: 18029165. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects).18029165
Berkman N, Avital A, Bardach E, . The effect of montelukast on bronchial provocation tests and exhaled nitric oxide levels in asthmatic patients. Isr Med Assoc J. 2003 Nov;5(11):778–81. PMID: 14650101. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)14650101
Berry M, Hargadon B, Morgan A, . Alveolar nitric oxide in adults with asthma: evidence of distal lung inflammation in refractory asthma. Eur Respir J. 2005 Jun;25(6):986–91. doi: 10.1183/09031936.05.00132404. PMID: 15929952. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15929952
Biernacki WA, Kharitonov SA, Biernacka HM, . Effect of montelukast on exhaled leukotrienes and quality of life in asthmatic patients. Chest. 2005 Oct;128(4):1958–63. doi: 10.1378/chest.128.4.1958. PMID: 16236841. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16236841
Bikov A, Galffy G, Tamasi L, . Exhaled breath condensate pH is influenced by respiratory droplet dilution. Journal of Breath Research. 2012 Dec;6(4)doi: 10.1088/1752-7155/6/4/046002. PMID: 2012708508. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Bloemen K, Van Den Heuvel R, Govarts E, . A new approach to study exhaled proteins as potential biomarkers for asthma. Clinical and Experimental Allergy. 2011 Mar;41(3):346–56. doi: 10.1111/j.1365-2222.2010.03638.x. PMID: 2011077082. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21105917
Bodini A, Peroni DG, Zardini F, . Flunisolide decreases exhaled nitric oxide and nitrotyrosine levels in asthmatic children. Mediators Inflamm. 2006;2006(4):31919. doi: 10.1155/MI/2006/31919. PMID: 17047290. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17047290
Bohadana AB, Hannhart B, Ghezzo H, . Exhaled nitric oxide and spirometry in respiratory health surveillance. Occup Med (Lond). 2011 Mar;61(2):108–14. doi: 10.1093/occmed/kqq184. PMID: 21285029. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21285029
Bonsignore MR, La Grutta S, Cibella F, . Effects of exercise training and montelukast in children with mild asthma. Med Sci Sports Exerc. 2008 Mar;40(3):405–12. doi: 10.1249/MSS.0b013e31815d9670. PMID: 18379200. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18379200
Boon M, Meyts I, Warnier G, . Exhaled Nitric Oxide: Offline Tidal Breathing Measurements Are Feasible in Children and Correlate with Online Single Breath Measurements. Pediatric Allergy Immunology and Pulmonology. 2010 01 Sep;23(3):201–6. doi: 10.1089/ped.2010.0037. PMID: WOS:000284242600008. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Boot JD, de Kam ML, Mascelli MA, . Nasal nitric oxide: longitudinal reproducibility and the effects of a nasal allergen challenge in patients with allergic rhinitis. Allergy. 2007 Apr;62(4):378–84. doi: 10.1111/j.1398-9995.2007.01328.x. PMID: 17362248. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)17362248
Boot JD, de Haas S, Tarasevych S, . Effect of an NK1/NK2 receptor antagonist on airway responses and inflammation to allergen in asthma. Am J Respir Crit Care Med. 2007 Mar 01;175(5):450–7. doi: 10.1164/rccm.200608-1186OC. PMID: 17170385. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17170385
Borrill Z, Clough D, Truman N, . A comparison of exhaled nitric oxide measurements performed using three different analysers. Respir Med. 2006 Aug;100(8):1392–6. doi: 10.1016/j.rmed.2005.11.018. PMID: 16431095. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16431095
Bossley CJ, Saglani S, Kavanagh C, . Corticosteroid responsiveness and clinical characteristics in childhood difficult asthma. Eur Respir J. 2009 Nov;34(5):1052–9. doi: 10.1183/09031936.00186508. PMID: 19541710. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19541710
Boulet LP, Lemiere C, Gauvreau G, . Safety, pharmacodynamics and pharmacokinetics of TPI 1020 in smokers with asthma. Respir Med. 2009 Aug;103(8):1159–66. doi: 10.1016/j.rmed.2009.02.011. PMID: 19286361. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19286361
Boushey HA, Sorkness CA, King TS, . Daily versus as-needed corticosteroids for mild persistent asthma. N Engl J Med. 2005 Apr 14;352(15):1519–28. doi: 10.1056/NEJMoa042552. PMID: 15829533. Other reason15829533
Bouzigon E, Nadif R, Thompson EE, . A common variant in RAB27A gene is associated with fractional exhaled nitric oxide levels in adults. Clin Exp Allergy. 2015 Apr;45(4):797–806. doi: 10.1111/cea.12461. PMID: 25431337. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25431337
Boyle RJ, Pedroletti C, Wickman M, . Nocturnal temperature controlled laminar airflow for treating atopic asthma: a randomised controlled trial. Thorax. 2012 Mar;67(3):215–21. doi: 10.1136/thoraxjnl-2011-200665. PMID: 22131290. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22131290
Brand PL. [Nitrogen monoxide monitoring not useful in children with asthma]. Ned Tijdschr Geneeskd. 2010;154:A2746. PMID: 20977799. The study is not original (commentaries, letters, etc. should be excluded)20977799
Brasholt M, Baty F, Bisgaard H. Physical activity in young children is reduced with increasing bronchial responsiveness. J Allergy Clin Immunol. 2010 May;125(5):1007–12. doi: 10.1016/j.jaci.2010.02.002. PMID: 20392480. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20392480
Brindicci C, Ito K, Barnes PJ, . Differential flow analysis of exhaled nitric oxide in patients with asthma of differing severity. Chest. 2007 May;131(5):1353–62. doi: 10.1378/chest.06-2531. PMID: 17494785. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17494785
Brindicci C, Ito K, Barnes PJ, . Effect of an inducible nitric oxide synthase inhibitor on differential flow-exhaled nitric oxide in asthmatic patients and healthy volunteers. Chest. 2007 Aug;132(2):581–8. doi: 10.1378/chest.06-3046. PMID: 17550932. The study does not evaluate FeNO17550932
Brindicci C, Ito K, Torre O, . Effects of aminoguanidine, an inhibitor of inducible nitric oxide synthase, on nitric oxide production and its metabolites in healthy control subjects, healthy smokers, and COPD patients. Chest. 2009 Feb;135(2):353–67. doi: 10.1378/chest.08-0964. PMID: 18719059. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18719059
Brody DJ, Zhang X, Kit BK, . Reference values and factors associated with exhaled nitric oxide: U.S. youth and adults. Respir Med. 2013 Nov;107(11):1682–91. doi: 10.1016/j.rmed.2013.07.006. PMID: 24041745. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)24041745
Broekema M, ten Hacken NH, Volbeda F, . Airway epithelial changes in smokers but not in ex-smokers with asthma. Am J Respir Crit Care Med. 2009 Dec 15;180(12):1170–8. doi: 10.1164/rccm.200906-0828OC. PMID: 19797761. The study does not evaluate FeNO19797761
Bruce CT, Zhao D, Yates DH, . AMP challenge induces a decrease in FE(NO) in asthmatic subjects modulated by nedocromil. Eur J Clin Invest. 2006 Dec;36(12):899–905. doi: 10.1111/j.1365-2362.2006.01736.x. PMID: 17087785. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17087785
Bruce CT, Zhao D, Yates DH, . L-arginine reverses cigarette-induced reduction of fractional exhaled nitric oxide in asthmatic smokers. Inflammopharmacology. 2010 Feb;18(1):9–16. doi: 10.1007/s10787-009-0017-9. PMID: 19838638. The study does not have a comparison group (studies must have a comparison group or pre/post design)19838638
Bruce C, Thomas PS. The effect of marimastat, a metalloprotease inhibitor, on allergen-induced asthmatic hyper-reactivity. Toxicol Appl Pharmacol. 2005 Jun 01;205(2):126–32. doi: 10.1016/j.taap.2004.10.005. PMID: 15893540. The study does not evaluate FeNO15893540
Buonanno G, Marks GB, Morawska L. Health effects of daily airborne particle dose in children: Direct association between personal dose and respiratory health effects. Environmental Pollution. 2013 Sep;180:246–50. doi: 10.1016/j.envpol.2013.05.039. PMID: WOS:000322425300033. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23792384
Burgess L, McCaffery K, Powell H, . The influence of asthma control on psychosocial outcomes for pregnant women with asthma. J Asthma. 2015;52(10):1013–9. doi: 10.3109/02770903.2015.1038833. PMID: 26313124. Other reason26313124
Caffey, L F, Raissy, . A crossover comparison of fluticasone propionate and montelukast on inflammatory indices in children with asthma. Pediatric Asthma, Allergy and Immunology. 2005;18(3):123–30. doi: 10.1089/pai.2005.18.123. PMID: 2005421662. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Cahn A, Boyce M, Mistry S, . Randomized trial of allergen-induced asthmatic response in smokers and non-smokers: effects of inhaled corticosteroids. Clin Exp Allergy. 2015 Oct;45(10):1531–41. doi: 10.1111/cea.12610. PMID: 26251958. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26251958
Campbell CP, Jackson AS, Johnson AR, . Occupational sensitization to lupin in the workplace: occupational asthma, rhinitis, and work-aggravated asthma. J Allergy Clin Immunol. 2007 May;119(5):1133–9. doi: 10.1016/j.jaci.2007.01.032. PMID: 17379286. The study does not evaluate FeNO17379286
Carpio C, Villasante C, Galera R, . Systemic inflammation and higher perception of dyspnea mimicking asthma in obese subjects. J Allergy Clin Immunol. 2016 Mar;137(3):718–26 e4. doi: 10.1016/j.jaci.2015.11.010. PMID: 26768410. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26768410
Carraro S, Cogo PE, Isak I, . EIA and GC/MS analysis of 8-isoprostane in EBC of children with problematic asthma. Eur Respir J. 2010 Jun;35(6):1364–9. doi: 10.1183/09031936.00074909. PMID: 19897556. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19897556
Carraro S, Folesani G, Corradi M, . Acid-base equilibrium in exhaled breath condensate of allergic asthmatic children. Allergy. 2005 Apr;60(4):476–81. doi: 10.1111/j.1398-9995.2005.00718.x. PMID: 15727579. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15727579
Carraro S, Giordano G, Reniero F, . Asthma severity in childhood and metabolomic profiling of breath condensate. Allergy. 2013 Jan;68(1):110–7. doi: 10.1111/all.12063. PMID: 23157191. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23157191
Carraro S, Rezzi S, Reniero F, . Metabolomics applied to exhaled breath condensate in childhood asthma. Am J Respir Crit Care Med. 2007 May 15;175(10):986–90. doi: 10.1164/rccm.200606-769OC. PMID: 17303796. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17303796
Carraro S, Piacentini G, Lusiani M, . Exhaled air temperature in children with bronchopulmonary dysplasia. Pediatr Pulmonol. 2010 Dec;45(12):1240–5. doi: 10.1002/ppul.21317. PMID: 20717936. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)20717936
Caspersen C, Stang J, Thorsen E, . Exhaled nitric oxide concentration upon acute exposure to moderate altitude. Scand J Med Sci Sports. 2013 Mar;23(2):e102–7. doi: 10.1111/sms.12018. PMID: 23157566. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23157566
Cerovic S, Zivkovic Z, Milenkovic B, . The Serbian version of the pediatric asthma quality of life questionnaire in daily practice. J Asthma. 2009 Nov;46(9):936–9. doi: 10.3109/02770900903265812. PMID: 19905922. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19905922
Cetta, F, Sala, . Prospective study in schoolchildren of Milan of health effects (respiratory damage and airway inflammation) from traffic related air pollution. GIMT - Giornale Italiano delle Malattie del Torace. 2009;63(6):447–55. PMID: 2011299124. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)
Chambers DC, Ayres JG. Effect of nebulised L- and D-arginine on exhaled nitric oxide in steroid naive asthma. Thorax. 2001 Aug;56(8):602–6. doi: 10.1136/thorax.56.8.602. PMID: 11462061. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11462061
Chatkin, J M, Ansarin, . Non-invasive assessment of airways inflammation in chronic cough: Exhaled nitric oxide. Chest. 1998;114(4 SUPPL.). Aan abstract without full text
Chauhan BF, Chartrand C, Ducharme FM. Intermittent versus daily inhaled corticosteroids for persistent asthma in children and adults. Cochrane Database Syst Rev. 2013 Feb 28;2(2):CD009611. doi: 10.1002/14651858.CD009611.pub3. PMID: 23450606. This is a systematic review/meta-analysis/guideline23450606
Chawes BL, Bischoff AL, Kreiner-Moller E, . DENND1B gene variants associate with elevated exhaled nitric oxide in healthy high-risk neonates. Pediatr Pulmonol. 2015 Feb;50(2):109–17. doi: 10.1002/ppul.22958. PMID: 24347560. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24347560
Chen, C W, Chu, . Methacholine-induced bronchial constriction reduces exhaled nitric oxide in patients with airway hyper-responsiveness. Journal of Medical Sciences. 2005 October;25(5):237–41. PMID: 2005476654. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Chen E, Strunk RC, Bacharier LB, . Socioeconomic status associated with exhaled nitric oxide responses to acute stress in children with asthma. Brain Behav Immun. 2010 Mar;24(3):444–50. doi: 10.1016/j.bbi.2009.11.017. PMID: 19961922. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19961922
Chinellato I, Piazza M, Peroni D, . Bronchial and alveolar nitric oxide in exercise-induced bronchoconstriction in asthmatic children. Clin Exp Allergy. 2012 Aug;42(8):1190–6. doi: 10.1111/j.1365-2222.2012.03973.x. PMID: 22805466. The study does not have a comparison group (studies must have a comparison group or pre/post design)22805466
Chiron R, Vachier I, Khanbabaee G, . Impact of rhinitis on asthma control in children: association with FeNO. J Asthma. 2010 Aug;47(6):604–8. doi: 10.3109/02770901003759402. PMID: 20626309. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20626309
Chladkova J, Chladek J, Senkerik M. Relationship of flow-independent parameters of exhaled nitric oxide (eNO) to clinical assessment of asthma control in children with persistent atopic asthma. Allergy. 2014 Sep;69:221–2. PMID: WOS:000341139400547. Aan abstract without full text
Chladkova, J, Havlinova, . Methodological issues related to exhaled nitric oxide measurement in children. [Czech]. Alergie. 2008;10(4):262–8. doi: 10.1002/ppul.20249. PMID: 2009012846. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Chládková, J, Havlínová, . Methodological issues related to exhaled nitric oxide measurement in children. Alergie. 2008;10(4):262–8. doi: 10.1002/ppul.20249. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Chladkova J, Havlinova Z, Chyba T, . Analysis of single-breath profiles of exhaled nitric oxide in children with allergy and asthma: guideline-derived plateau concentrations compared to results of automatic evaluation by two analyzers. J Asthma. 2008 Nov;45(9):820–6. doi: 10.1080/02770900802312582. PMID: 18972302. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)18972302
Chng SY, Van Bever HP, Lian D, . Relationship between exhaled nitric oxide and atopy in Asian young adults. Respirology. 2005 Jan;10(1):40–5. doi: 10.1111/j.1440-1843.2005.00628.x. PMID: 15691237. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15691237
Chow JS, Leung AS, Li WW, . Airway inflammatory and spirometric measurements in obese children. Hong Kong Med J. 2009 Oct;15(5):346–52. PMID: 19801691. Other reason19801691
Cibella F, Cuttitta G, La Grutta S, . A cross-sectional study assessing the relationship between BMI, asthma, atopy, and eNO among schoolchildren. Annals of Allergy Asthma & Immunology. 2011 Oct;107(4):330–6. doi: 10.1016/j.anai.2011.08.001. PMID: WOS:000296270100007. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Cibella F, Cuttitta G, La Grutta S, . Factors that influence exhaled nitric oxide in Italian schoolchildren. Annals of Allergy Asthma & Immunology. 2008 Oct;101(4):407–12. doi: 10.1016/S1081-1206(10)60318-3. PMID: WOS:000259979300012. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Ciebiada M, Cichocki P, Kasztalska K, . Orally exhaled nitric oxide in patients with seasonal allergic rhinitis during natural pollen season. Am J Rhinol Allergy. 2012 Jan–Feb;26(1):e32–6. doi: 10.2500/ajra.2012.26.3720. PMID: 22391078. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22391078
Ciolkowski J, Mazurek H, Stasiowska B. Evaluation of step-down therapy from an inhaled steroid to montelukast in childhood asthma. Allergol Immunopathol (Madr). 2014 Jul–Aug;42(4):282–8. doi: 10.1016/j.aller.2013.01.005. PMID: 23684855. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23684855
Ciprandi, G, Schiavetti, . Symptom perception and asthma control. Postgraduate Medicine. 2015 01 Jan;127(7):738–43. PMID: 20160290931. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26216491
Ciprandi, G, Tosca, . Exhaled nitric oxide in children with allergic rhinitis andor asthma: A relationship with bronchial hyperreactivity. Journal of Asthma. 2010 December;47(10):1142–7. doi: 10.3109/02770903.2010.527026. PMID: 2010641216. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20950134
Ciprandi G, Tosca MA, Castellazzi AM, . FEF(25–75) might be a predictive factor for bronchial inflammation and bronchial hyperreactivity in adolescents with allergic rhinitis. Int J Immunopathol Pharmacol. 2011 Oct;24(4 Suppl):17–20. doi: 10.1177/03946320110240S404. PMID: 22032781. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22032781
Ciprandi, G, Tosca, . FEF(25–75) Might Be a Predictive Factor for Bronchial Inflammation and Bronchial Hyperreactivity in Adolescents with Allergic Rhinitis. International Journal of Immunopathology and Pharmacology. 2011 01 Oct;24:17–20. doi: 10.1177/03946320110240S404. PMID: 20160144683.. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Ciprandi G, Ricciardolo FL, Schiavetti I, . Allergic rhinitis phenotypes based on bronchial hyperreactivity to methacholine. Am J Rhinol Allergy. 2014 Nov–Dec;28(6):214–8. doi: 10.2500/ajra.2014.28.4124. PMID: 25514477. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)25514477
Ciprandi G, Ricciardolo FL, Signori A, . Increased body mass index and bronchial impairment in allergic rhinitis. Am J Rhinol Allergy. 2013 Nov–Dec;27(6):e195–201. doi: 10.2500/ajra.2013.27.3979. PMID: 24274214. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)24274214
Ciprandi G, Schiavetti I, Bellezza Fontana R, . Overweight and obesity as risk factors for impaired lung function in patients with asthma: A real-life experience. Allergy Asthma Proc. 2014 Jul–Aug;35(4):e62–71. doi: 10.2500/aap.2014.35.3773. PMID: 24992544. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24992544
Cirillo I, Ricciardolo FLM, Medusei G, . Exhaled Nitric Oxide May Predict Bronchial Hyperreactivity in Patients with Allergic Rhinitis. International Archives of Allergy and Immunology. 2013;160(3):322–8. doi: 10.1159/000341675. PMID: WOS:000311489200013. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23052027
Clearie KL, Jackson CM, Fardon TC, . Supervised step-down of inhaled corticosteroids in the community--an observational study. Respir Med. 2011 Apr;105(4):558–65. doi: 10.1016/j.rmed.2010.10.004. PMID: 21144723. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21144723
Cohen J, Douma WR, ten Hacken NH, . Ciclesonide improves measures of small airway involvement in asthma. Eur Respir J. 2008 Jun;31(6):1213–20. doi: 10.1183/09031936.00082407. PMID: 18287130. Other reason18287130
Cohen J, Douma WR, Ten Hacken NH, . Physiology of the small airways: A gender difference? Respir Med. 2008 Sep;102(9):1264–71. doi: 10.1016/j.rmed.2008.04.007. PMID: 18617383. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18617383
Collins SA, Pike KC, Inskip HM, . Validation of novel wheeze phenotypes using longitudinal airway function and atopic sensitization data in the first 6 years of life: evidence from the Southampton Women’s survey. Pediatr Pulmonol. 2013 Jul;48(7):683–92. doi: 10.1002/ppul.22766. PMID: 23401430. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23401430
Colon-Semidey AJ, Marshik P, Crowley M, . Correlation between reversibility of airway obstruction and exhaled nitric oxide levels in children with stable bronchial asthma. Pediatr Pulmonol. 2000 Nov;30(5):385–92. doi: 10.1002/1099-0496(200011)30:5<385::AID-PPUL4>3.0.CO;2-#. PMID: 11064429. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11064429
Columbo M, Wong B, Panettieri RA, Jr., . Asthma in the elderly: the role of exhaled nitric oxide measurements. Respir Med. 2013 May;107(5):785–7. doi: 10.1016/j.rmed.2013.01.018. PMID: 23481173. The study does not have a comparison group (studies must have a comparison group or pre/post design)23481173
Contoli M, Baraldo S, Marku B, . Fixed airflow obstruction due to asthma or chronic obstructive pulmonary disease: 5-year follow-up. J Allergy Clin Immunol. 2010 Apr;125(4):830–7. doi: 10.1016/j.jaci.2010.01.003. PMID: 20227753. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20227753
Corcuera-Elosegui P, Sardon-Prado O, Aldasoro-Ruiz A, . Inflammatory patterns in asthmatic children based on alveolar nitric oxide determination. Arch Bronconeumol. 2015 Jun;51(6):279–84. doi: 10.1016/j.arbres.2014.07.005. PMID: 25311845. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25311845
Couto M, Stang J, Horta L, . Two distinct phenotypes of asthma in elite athletes identified by latent class analysis. J Asthma. 2015;52(9):897–904. doi: 10.3109/02770903.2015.1067321. PMID: 26377281. Other reason26377281
Couto, Mariana, Stang, . Two distinct phenotypes of asthma in elite athletes identified by latent class analysis. Journal of Asthma. 2015;52(9):897–904. PMID: 26377281. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26377281
Craig, T J, King, . Aeroallergen sensitization correlates with PC<inf>20</inf> and exhaled nitric oxide in subjects with mild-to-moderate asthma. Journal of Allergy and Clinical Immunology. 2008 March;121(3):671–7. doi: 10.1016/j.jaci.2007.12.1153. PMID: 2008112521. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18234311
Crane J, Lampshire P, Wickens K, . Asthma, atopy and exhaled nitric oxide in a cohort of 6-yr-old New Zealand children. Pediatr Allergy Immunol. 2012 Feb;23(1):59–64. doi: 10.1111/j.1399-3038.2011.01227.x. PMID: 22104032. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22104032
Crespo Lessmann A, Giner J, Torrego A, . Usefulness of the Exhaled Breath Temperature Plateau in Asthma Patients. Respiration. 2015;90(2):111–7. doi: 10.1159/000431259. PMID: 26113222. The study does not evaluate FeNO26113222
Daham K, Song WL, Lawson JA, . Effects of celecoxib on major prostaglandins in asthma. Clin Exp Allergy. 2011 Jan;41(1):36–45. doi: 10.1111/j.1365-2222.2010.03617.x. PMID: 20880055. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20880055
Dahlen B, Lantz AS, Ihre E, . Effect of formoterol with or without budesonide in repeated low-dose allergen challenge. Eur Respir J. 2009 Apr;33(4):747–53. doi: 10.1183/09031936.00095508. PMID: 19129280. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19129280
Davis BE, Amakye DO, Cockcroft DW. Airway responsiveness to mannitol 24 h after allergen challenge in atopic asthmatics. Allergy. 2015 Jun;70(6):682–8. doi: 10.1111/all.12601. PMID: 25727851. The study does not have a comparison group (studies must have a comparison group or pre/post design)25727851
Davis BE, Stewart SL, Martin AL, . Low levels of fractional exhaled nitric oxide and deep inhalation bronchoprotection are associated with mannitol non-responsiveness in asthma. Respir Med. 2014 Jun;108(6):859–64. doi: 10.1016/j.rmed.2014.03.005. PMID: 24702886. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24702886
de Andrade WC, Lasmar LM, Ricci Cde A, . Phenotypes of severe asthma among children and adolescents in Brazil: a prospective study. BMC Pulm Med. 2015 Apr 17;15:36. doi: 10.1186/s12890-015-0029-8. PMID: 25912047. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25912047
de Gouw HW, Hendriks J, Woltman AM, . Exhaled nitric oxide (NO) is reduced shortly after bronchoconstriction to direct and indirect stimuli in asthma. Am J Respir Crit Care Med. 1998 Jul;158(1):315–9. doi: 10.1164/ajrccm.158.1.9703005. PMID: 9655746. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9655746
de Kluijver J, Evertse CE, Sont JK, . Are rhinovirus-induced airway responses in asthma aggravated by chronic allergen exposure? Am J Respir Crit Care Med. 2003 Nov 15;168(10):1174–80. doi: 10.1164/rccm.200212-1520OC. PMID: 12893645. The study does not have a comparison group (studies must have a comparison group or pre/post design)12893645
de Kluijver J, Evertse CE, Schrumpf JA, . Asymptomatic worsening of airway inflammation during low-dose allergen exposure in asthma: protection by inhaled steroids. Am J Respir Crit Care Med. 2002 Aug 01;166(3):294–300. doi: 10.1164/rccm.2112097. PMID: 12153960. The study does not have a comparison group (studies must have a comparison group or pre/post design)12153960
De Prins S, Marcucci F, Sensi L, . Exhaled nitric oxide and nasal tryptase are associated with wheeze, rhinitis and nasal allergy in primary school children. Biomarkers. 2014 Sep;19(6):481–7. doi: 10.3109/1354750x.2014.937362. PMID: WOS:000340768500007. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)25019424
de la Riva-Velasco E, Krishnan S, Dozor AJ. Relationship between exhaled nitric oxide and exposure to low-level environmental tobacco smoke in children with asthma on inhaled corticosteroids. J Asthma. 2012 Sep;49(7):673–8. doi: 10.3109/02770903.2012.701363. PMID: 22799435. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22799435
De Prins S, Marcucci F, Sensi L, . Exhaled nitric oxide and nasal tryptase are associated with wheeze, rhinitis and nasal allergy in primary school children. Biomarkers. 2014 Sep;19(6):481–7. doi: 10.3109/1354750x.2014.937362. PMID: WOS:000340768500007. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25019424
Debley J, Stamey D, Cochrane E, . Exhaled Nitric Oxide Predicts Persistence Of Wheezing, Exacerbations, And Decline In Lung Function In Wheezy Infants And Toddlers. American Journal of Respiratory and Critical Care Medicine. 2011;183(1 MeetingAbstracts) PMID: 70845422. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Debley JS, Stamey DC, Cochrane ES, . Exhaled nitric oxide, lung function, and exacerbations in wheezy infants and toddlers. J Allergy Clin Immunol. 2010 Jun;125(6):1228–34 e13. doi: 10.1016/j.jaci.2010.03.023. PMID: 20462633. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)20462633
Decimo F, Capristo C, Amelio R, . Evaluation of bronchial hyperreactivity with mannitol dry powder challenge test in a paediatric population with intermittent allergic asthma or allergic rhinitis. Int J Immunopathol Pharmacol. 2011 Oct–Dec;24(4):1069–74. doi: 10.1177/039463201102400424. PMID: 22230412. The study does not have a comparison group (studies must have a comparison group or pre/post design)22230412
Delen FM, Sippel JM, Osborne ML, . Increased exhaled nitric oxide in chronic bronchitis: comparison with asthma and COPD. Chest. 2000 Mar;117(3):695–701. doi: 10.1378/chest.117.3.695. PMID: 10712993. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10712993
Demange V, Bohadana A, Massin N, . Exhaled nitric oxide and airway hyperresponsiveness in workers: a preliminary study in lifeguards. BMC Pulm Med. 2009 Dec 31;9(53):53. doi: 10.1186/1471-2466-9-53. PMID: 20043846. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)20043846
Demange V, Wild P, Zmirou-Navier D, . Associations of airway inflammation and responsiveness markers in non asthmatic subjects at start of apprenticeship. Bmc Pulmonary Medicine. 2010 06 Jul;10(37)doi: 10.1186/1471-2466-10-37. PMID: 2010429875. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Dennis JA, Cates CJ. Alexander technique for chronic asthma. Cochrane Database Syst Rev. 2012 Sep 12(9):CD000995. doi: 10.1002/14651858.CD000995.pub2. PMID: 22972048. The study is not original (commentaries, letters, etc should be excluded)22972048
Depner M, Fuchs O, Genuneit J, . Clinical and epidemiologic phenotypes of childhood asthma. Am J Respir Crit Care Med. 2014 Jan 15;189(2):129–38. doi: 10.1164/rccm.201307-1198OC. PMID: 24283801. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24283801
Devereux G, Tagiyeva N, Turner SW, . Early-life residential exposure to soil components in rural areas and childhood respiratory health and allergy. Sci Total Environ. 2014 Jan 01;466–467:338–44. doi: 10.1016/j.scitotenv.2013.06.115. PMID: 23921365. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23921365
Diamant Z, Kuperus J, Baan R, . Effect of a very late antigen-4 receptor antagonist on allergen-induced airway responses and inflammation in asthma. Clin Exp Allergy. 2005 Aug;35(8):1080–7. doi: 10.1111/j.1365-2222.2005.02296.x. PMID: 16120091. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16120091
Dichiaro CA, Baptist AP. Exhaled Nitric Oxide Levels in African American Children. Annals of Allergy Asthma & Immunology. 2009 Nov;103(5):A71–A. PMID: WOS:000271913500205. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Dietz J, Kaercher T, Schneider AT, . Early respiratory and ocular involvement in X-linked hypohidrotic ectodermal dysplasia. Eur J Pediatr. 2013 Aug;172(8):1023–31. doi: 10.1007/s00431-013-1985-8. PMID: 23553579. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23553579
Divjan, A, Rosa, . IgE and symptoms by age 2 years predict FENO at age 5–7 years in a low-income urban New York City population. Journal of Allergy and Clinical Immunology. 2009 February;1):S19. doi: 10.1016/j.jaci.2008.12.085. PMID: 70105176. Other reason19647132
Dixon AE, Subramanian M, DeSarno M, . A pilot randomized controlled trial of pioglitazone for the treatment of poorly controlled asthma in obesity. Respir Res. 2015 Nov 26;16:143. doi: 10.1186/s12931-015-0303-6. PMID: 26610598. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26610598
Donohue JF, Herje N, Crater G, . Characterization of airway inflammation in patients with COPD using fractional exhaled nitric oxide levels: a pilot study. Int J Chron Obstruct Pulmon Dis. 2014;9:745–51. doi: 10.2147/COPD.S44552. PMID: 25053884. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)25053884
Downie SR, Salome CM, Verbanck S, . Ventilation heterogeneity is a major determinant of airway hyperresponsiveness in asthma, independent of airway inflammation. Thorax. 2007 Aug;62(8):684–9. doi: 10.1136/thx.2006.069682. PMID: 17311839. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17311839
Dressel H, Gross C, de la Motte D, . Educational intervention decreases exhaled nitric oxide in farmers with occupational asthma. Eur Respir J. 2007 Sep;30(3):545–8. doi: 10.1183/09031936.00023807. PMID: 17766632. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17766632
Dressel H, Gross C, de la Motte D, . Educational intervention in farmers with occupational asthma: long-term effect on exhaled nitric oxide. J Investig Allergol Clin Immunol. 2009;19(1):49–53. doi: 10.3410/f.1161657.623228. PMID: 19274929. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19274929
Dressel H, Muller F, Fischer R, . Independent information of nonspecific biomarkers in exhaled breath condensate. Respiration. 2010;80(5):401–9. doi: 10.1159/000319945. PMID: 20699611. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20699611
Duijts L, Granell R, Sterne JA, . Childhood wheezing phenotypes influence asthma, lung function and exhaled nitric oxide fraction in adolescence. Eur Respir J. 2016 Feb;47(2):510–9. doi: 10.1183/13993003.00718-2015. PMID: 26647439. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)26647439
Duong M, Cockcroft D, Boulet LP, . The effect of IVX-0142, a heparin-derived hypersulfated disaccharide, on the allergic airway responses in asthma. Allergy. 2008 Sep;63(9):1195–201. doi: 10.1111/j.1398-9995.2008.01707.x. PMID: 18699936. Other reason18699936
Duong M, Gauvreau G, Watson R, . The effects of inhaled budesonide and formoterol in combination and alone when given directly after allergen challenge. J Allergy Clin Immunol. 2007 Feb;119(2):322–7. doi: 10.1016/j.jaci.2006.10.018. PMID: 17141859. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17141859
Dzinovic A. The fractional concentracion of exaled nitric oxide in controlling children’s asthma. Healthmed. 2012;6(5):1870–4. PMID: 2012379731. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Eckel SP, Linn WS, Salam MT, . Spirometry effects on conventional and multiple flow exhaled nitric oxide in children. J Asthma. 2015 Mar;52(2):198–204. doi: 10.3109/02770903.2014.954292. PMID: 25134783. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25134783
Ek A, Middelveld RJ, Bertilsson H, . Chronic rhinosinusitis in asthma is a negative predictor of quality of life: results from the Swedish GA(2)LEN survey. Allergy. 2013 Oct;68(10):1314–21. doi: 10.1111/all.12222. PMID: 24107218. Other reason24107218
Ekroos H, Karjalainen J, Sarna S, . Short-term variability of exhaled nitric oxide in young male patients with mild asthma and in healthy subjects. Respir Med. 2002 Nov;96(11):895–900. doi: 10.1053/rmed.2002.1378. PMID: 12418587. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12418587
Ekroos H, Rouhos A, Pallasaho P, . Equally elevated concentrations of exhaled nitric oxide in nonatopic and low-sensitized atopic asthmatics. Respir Med. 2009 Jan;103(1):152–8. doi: 10.1016/j.rmed.2008.03.021. PMID: 18951776. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18951776
Ekstrand Y, Ternesten-Hasseus E, Arvidsson M, . Sensitivity to environmental irritants and capsaicin cough reaction in patients with a positive methacholine provocation test before and after treatment with inhaled corticosteroids. J Asthma. 2011 Jun;48(5):482–9. doi: 10.3109/02770903.2011.570405. PMID: 21486197. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21486197
ElHalawani SM, Ly NT, Mahon RT, . Exhaled nitric oxide as a predictor of exercise-induced bronchoconstriction. Chest. 2003 Aug;124(2):639–43. doi: 10.1378/chest.124.2.639. PMID: 12907554. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)12907554
Enderby B, Smith D, Carroll W, . Hydrogen cyanide as a biomarker for Pseudomonas aeruginosa in the breath of children with cystic fibrosis. Pediatr Pulmonol. 2009 Feb;44(2):142–7. doi: 10.1002/ppul.20963. PMID: 19148935. Other reason19148935
Evjenth B, Hansen TE, Holt J. Exhaled nitric oxide decreases during exercise in non-asthmatic children. Clin Respir J. 2013 Apr;7(2):121–7. doi: 10.1111/j.1752-699X.2012.00292.x. PMID: 22521142. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22521142
Farah CS, Kermode JA, Downie SR, . Obesity Is a Determinant of Asthma Control Independent of Inflammation and Lung Mechanics. Chest. 2011 Sep;140(3):659–66. doi: 10.1378/chest.11-0027. PMID: 2011507459. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21415135
Farah CS, King GG, Brown NJ, . Ventilation heterogeneity predicts asthma control in adults following inhaled corticosteroid dose titration. J Allergy Clin Immunol. 2012 Jul;130(1):61–8. doi: 10.1016/j.jaci.2012.02.015. PMID: 22460065. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22460065
Farah CS, King GG, Brown NJ, . The role of the small airways in the clinical expression of asthma in adults. J Allergy Clin Immunol. 2012 Feb;129(2):381–7, 7 e1. doi: 10.1016/j.jaci.2011.11.017. PMID: 22188824. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22188824
Fardon T, Haggart K, Lee DK, . A proof of concept study to evaluate stepping down the dose of fluticasone in combination with salmeterol and tiotropium in severe persistent asthma. Respir Med. 2007 Jun;101(6):1218–28. doi: 10.1016/j.rmed.2006.11.001. PMID: 17178217. Other reason17178217
Feitosa LA, Dornelas de Andrade A, Reinaux CM, . Diagnostic accuracy of exhaled nitric oxide in exercise-induced bronchospasm: Systematic review. Rev Port Pneumol. 2012 Jul–Aug;18(4):198–204. doi: 10.1016/j.rppneu.2012.01.008. PMID: 22560771. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22560771
Fernandez R, Ariza M, Iscar M, . Impact of environmental air pollutants on disease control in asmathic patients. Lung. 2015 Apr;193(2):195–8. doi: 10.1007/s00408-015-9695-9. PMID: 25687770. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25687770
Fitzpatrick AM, Brown LA, Holguin F, . Levels of nitric oxide oxidation products are increased in the epithelial lining fluid of children with persistent asthma. J Allergy Clin Immunol. 2009 Nov;124(5):990–6 e1–9. doi: 10.1016/j.jaci.2009.08.039. PMID: 19895987. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19895987
Fitzpatrick AM, Gaston BM, Erzurum SC, . Features of severe asthma in school-age children: Atopy and increased exhaled nitric oxide. J Allergy Clin Immunol. 2006 Dec;118(6):1218–25. doi: 10.1016/j.jaci.2006.08.019. PMID: 17157650. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17157650
Fortuna AM, Feixas T, Casan P. [Measurement of fraction of exhaled nitric oxide with the portable NIOX-MINO monitor in healthy adults]. Arch Bronconeumol. 2007 Mar;43(3):176–9. PMID: 17386196. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)17386196
Foschino B, M P, Lacedonia, . Dyspnea perception in asthma: Role of airways inflammation, age and emotional status. Respiratory Medicine. 2011 February;105(2):195–203. doi: 10.1016/j.rmed.2010.09.013. PMID: 2011032038. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20965711
Fritscher LG, Rodrigues MT, Zamel N, . The effect of montelukast on exhaled nitric oxide of alveolar and bronchial origin in inhaled corticosteroid-treated asthma. Respir Med. 2009 Feb;103(2):296–300. doi: 10.1016/j.rmed.2008.08.007. PMID: 18805684. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18805684
Fujimoto K, Yamaguchi S, Urushibata K, . Characteristics of asthma resistant to moderate dose inhaled corticosteroid treatment on bronchial hyperresponsiveness. Intern Med. 2006 15 Aug;45(14):843–9. doi: 10.2169/internalmedicine.45.1749. PMID: 16908940. Other reason16908940
Fujisawa T, Yasui H, Akamatsu T, . Alveolar nitric oxide concentration reflects peripheral airway obstruction in stable asthma. Respirology. 2013 Apr;18(3):522–7. doi: 10.1111/resp.12031. PMID: 23240824. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23240824
Gabriele C, Jaddoe VW, van Mastrigt E, . Exhaled nitric oxide and the risk of wheezing in infancy: the Generation R Study. Eur Respir J. 2012 Mar;39(3):567–72. doi: 10.1183/09031936.00151010. PMID: 21920894. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21920894
Gagliardo R, La Grutta S, Chanez P, . Non-invasive markers of airway inflammation and remodeling in childhood asthma. Pediatr Allergy Immunol. 2009 Dec;20(8):780–90. doi: 10.1111/j.1399-3038.2009.00945.x. PMID: 19788537. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19788537
Garcia-Marcos PW, Soriano-Perez MJ, Perez-Fernandez V, . Exhaled nitric oxide in school children: Searching for the lost variability. Allergologia Et Immunopathologia. 2016 May–Jun;44(3):206–13. doi: 10.1016/j.aller.2015.06.002. PMID: WOS:000376333200004. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26674385
Garcia-Rio F, Ramirez M, Mediano O, . Exhaled nitric oxide and airway caliber during exercise-induced bronchoconstriction. International Journal of Sports Medicine. 2006 Nov;27(11):905–10. doi: 10.1055/s-2006-923775. PMID: 2006563958. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17120347
Garnier P, Fajac I, Dessanges JF, . Exhaled nitric oxide during acute changes of airways calibre in asthma. Eur Respir J. 1996 Jun;9(6):1134–8. PMID: 8804928. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)8804928
Gastaldi AC, Paredi P, Talwar A, . Oscillating Positive Expiratory Pressure on Respiratory Resistance in Chronic Obstructive Pulmonary Disease With a Small Amount of Secretion: A Randomized Clinical Trial. Medicine (Baltimore). 2015 Oct;94(42):e1845. doi: 10.1097/MD.0000000000001845. PMID: 26496331. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)26496331
Gelb, A F, Taylor, . Role of add-on zileuton on total exhaled, large airway, and small airway/alveolar nitric oxide in moderate-severe persistent adult asthmatics on fluticasone 250 mug/Salmeterol 50 mug. Pulmonary Pharmacology and Therapeutics. 2009 December;22(6):516–21. doi: 10.1016/j.pupt.2009.05.003. PMID: 2009622866. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19467341
Gelb AF, George SC, Silkoff PE, . Central and peripheral airway/alveolar sites of exhaled nitric oxide in acute asthma. Thorax. 2010 Jul;65(7):619–25. doi: 10.1136/thx.2009.132696. PMID: 20627920. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20627920
Gelb AF, Taylor CF, Nussbaum E, . Alveolar and airway sites of nitric oxide inflammation in treated asthma. Am J Respir Crit Care Med. 2004 Oct 01;170(7):737–41. doi: 10.1164/rccm.200403-408OC. PMID: 15229098. Other reason15229098
Georges G, Bartelson BB, Martin RJ, . Circadian variation in exhaled nitric oxide in nocturnal asthma. J Asthma. 1999 Aug;36(5):467–73. doi: 10.3109/02770909909087289. PMID: 10461936. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10461936
Ghdifan S, Verin E, Couderc L, . Exhaled nitric oxide fractions are well correlated with clinical control in recurrent infantile wheeze treated with inhaled corticosteroids. Pediatr Allergy Immunol. 2010 Nov;21(7):1015–20. doi: 10.1111/j.1399-3038.2010.01076.x. PMID: 20977500. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20977500
Gill R, Krishnan S, Dozor AJ. Low-level environmental tobacco smoke exposure and inflammatory biomarkers in children with asthma. J Asthma. 2014 May;51(4):355–9. doi: 10.3109/02770903.2013.823446. PMID: 24580138. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24580138
Gillissen, A. Measurement of exhaled nitric oxide for the redefinition of a severe asthma subtype: Results of a study in the framework of the Severe Asthma Research Program. Medizinische Klinik. 2010;105(3):189–90. The study is not original (commentaries, letters, etc. should be excluded)
Giroux M, Bremont F, Ferrieres J, . Exhaled NO in asthmatic children in unpolluted and urban environments. Environ Int. 2001 Oct;27(4):335–40. doi: 10.1016/S0160-4120(01)00065-4. PMID: 11686645. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11686645
Gjurow P, D, Majak, . Fractional exhaled nitric oxide correlates with FEV1 in bronchial reversibility test in children with asthma. [Polish]. Alergia Astma Immunologia. 2010 December;15(4):203–7. doi: 10.4103/0970-2113.201322. PMID: 2011075538. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)
Gjurow P, D, Majak, . Fractional exhaled nitric oxide correlates with FEV_1_ in bronchial reversibility test in children with asthma. Alergia Astma Immunologia. 2010;15(4):203–7. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Gjurow P, D, Majak, . Fractional exhaled nitric oxide correlates with FEV1 in bronchial reversibility test in children with asthma. Alergia Astma Immunologia. 2010;15(4):203–7. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Godinho N, A. C M, Dos R, . Fraction of exhaled nitric oxide measurements in the diagnoses of asthma in elderly patients. Clinical Interventions in Aging. 2016 12 May;11:623–9. doi: 10.2147/CIA.S94741. PMID: 20160373250. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)27274212
Gomersal T, Harnan S, Essat M, . A systematic review of fractional exhaled nitric oxide in the routine management of childhood asthma. Pediatr Pulmonol. 2016 Mar;51(3):316–28. doi: 10.1002/ppul.23371. PMID: 26829581. This is a systematic review/meta-analysis/guideline26829581
Gomes EL, Carvalho CR, Peixoto-Souza FS, . Active Video Game Exercise Training Improves the Clinical Control of Asthma in Children: Randomized Controlled Trial. PLoS One. 2015;10(8):e0135433. doi: 10.1371/journal.pone.0135433. PMID: 26301706. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26301706
Gomez FP, Martinez Palli G, Barbera JA, . [Measurement of exhaled nitric oxide in healthy subjects]. Med Clin (Barc). 1998 Jun 13;111(1):1–5. PMID: 9666427. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9666427
Gordon IO, Husain AN, Charbeneau J, . Endobronchial biopsy: a guide for asthma therapy selection in the era of bronchial thermoplasty. J Asthma. 2013 Aug;50(6):634–41. doi: 10.3109/02770903.2013.794239. PMID: 23621125. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23621125
Grarup PA, Janner JH, Ulrik CS. Passive smoking is associated with poor asthma control during pregnancy: a prospective study of 500 pregnancies. PLoS One. 2014;9(11):e112435. doi: 10.1371/journal.pone.0112435. PMID: 25409513. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25409513
Gratziou C, Rovina N, Lignos M, . Exhaled nitric oxide in seasonal allergic rhinitis: influence of pollen season and therapy. Clin Exp Allergy. 2001 Mar;31(3):409–16. doi: 10.1046/j.1365-2222.2001.01001.x. PMID: 11260152. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)11260152
Green RJ, Klein M, Becker P, . Disagreement among common measures of asthma control in children. Chest. 2013 Jan;143(1):117–22. doi: 10.1378/chest.12-1070. PMID: 22878380. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22878380
Grob NM, Laskowski D, Dweik RA. A technical report on exhaled nitric oxide measurement: asthma monitoring in athletes. J Breath Res. 2008 Sep;2(3):37027. doi: 10.1088/1752-7155/2/3/037027. PMID: 20622980. The study does not have a comparison group (studies must have a comparison group or pre/post design)20622980
Gronke L, Kanniess F, Holz O, . The relationship between airway hyper-responsiveness, markers of inflammation and lung function depends on the duration of the asthmatic disease. Clinical and Experimental Allergy. 2002 Jan;32(1):57–63. doi: DOI 10.1046/j.0022-0477.2001.01297.x. PMID: WOS:000174061300010. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12002738
Grzelewski T, Stelmach W, Stelmach R, . Spirometry-Adjusted Fraction of Exhaled Nitric Oxide Allows Asthma Diagnosis in Children, Adolescents, and Young Adults. Respir Care. 2016 Feb;61(2):162–72. doi: 10.4187/respcare.04092. PMID: 26628565. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26628565
Guan WJ, Shi X, Jiang CY, . Responsiveness to methacholine, but not leukotriene D-4, correlates with fractional exhaled nitric oxide in asthma. Clinical Respiratory Journal. 2016 Mar;10(2):176–80. doi: 10.1111/crj.12199. PMID: WOS:000372001600006. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25103494
Guan WJ, Shi X, Zheng JP, . Leukotriene D4 inhalation challenge for predicting short-term efficacy of montelukast: a pilot study. Clin Respir J. 2015 Jan;9(1):111–20. doi: 10.1111/crj.12117. PMID: 24506412. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24506412
Guida G, Rolla G, Badiu I, . Determinants of exhaled nitric oxide in chronic rhinosinusitis. Chest. 2010 Mar;137(3):658–64. doi: 10.1378/chest.09-0667. PMID: 19837820. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)19837820
Gyllfors P, Dahlen SE, Kumlin M, . Bronchial responsiveness to leukotriene D4 is resistant to inhaled fluticasone propionate. J Allergy Clin Immunol. 2006 Jul;118(1):78–83. doi: 10.1016/j.jaci.2006.03.040. PMID: 16815141. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16815141
Haccuria A, Michils A, Michiels S, . Exhaled nitric oxide: a biomarker integrating both lung function and airway inflammation changes. J Allergy Clin Immunol. 2014 Sep;134(3):554–9. doi: 10.1016/j.jaci.2013.12.1070. PMID: 24522091. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24522091
Hafkamp-de Groen E, van der Valk RJ, Mohangoo AD, . Evaluation of systematic assessment of asthma-like symptoms and tobacco smoke exposure in early childhood by well-child professionals: a randomised trial. PLoS One. 2014;9(3):e90982. doi: 10.1371/journal.pone.0090982. PMID: 24626147. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24626147
Hamill, L, Ferris, . Exhaled breath temperature measurement and asthma control in children prescribed inhaled corticosteroids: A cross sectional study. Pediatric Pulmonology. 2015 doi: 10.1002/ppul.23204. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Hamill L, Ferris K, Kapande K, . Exhaled breath temperature measurement and asthma control in children prescribed inhaled corticosteroids: A cross sectional study. Pediatr Pulmonol. 2016 Jan;51(1):13–21. doi: 10.1002/ppul.23204. PMID: 25917297. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25917297
Han YY, Forno E, Celedon JC. Adiposity, fractional exhaled nitric oxide, and asthma in U.S. children. Am J Respir Crit Care Med. 2014 Jul 01;190(1):32–9. doi: 10.1164/rccm.201403-0565OC. PMID: 24922361. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24922361
Hanazawa T, Kharitonov SA, Barnes PJ. Increased nitrotyrosine in exhaled breath condensate of patients with asthma. Am J Respir Crit Care Med. 2000 Oct;162(4 Pt 1):1273–6. doi: 10.1164/ajrccm.162.4.9912064. PMID: 11029330. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11029330
Harada S, Harada N, Itoigawa Y, . Evaluation of switching low-dose inhaled corticosteroid to pranlukast for step-down therapy in well-controlled patients with mild persistent asthma. J Asthma. 2016 07 Feb;53(2):207–12. doi: 10.3109/02770903.2015.1087556. PMID: 26325232. Other reason26325232
Hardaker KM, Downie SR, Kermode JA, . Predictors of Airway Hyperresponsiveness Differ Between Old and Young Patients With Asthma. Chest. 2011 Jun;139(6):1395–401. doi: 10.1378/chest.10-1839. PMID: WOS:000291511100023. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21454398
Hardaker, K M, Downie, . Ventilation heterogeneity is associated with airway responsiveness in asthma but not COPD. Respiratory Physiology and Neurobiology. 2013 01 Oct;189(1):106–11. doi: 10.1016/j.resp.2013.07.009. PMID: 2013511805. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23876741
Harnan SE, Tappenden P, Essat M, . Measurement of exhaled nitric oxide concentration in asthma: a systematic review and economic evaluation of NIOX MINO, NIOX VERO and NObreath. Health Technol Assess. 2015 Oct;19(82):1–330. doi: 10.3310/hta19820. PMID: 26484874. Other reason26484874
Hasegawa H, Inui N, Fujisawa T, . Once-daily inhaled glucocorticosteroid administration in controlled asthma patients. Pulm Pharmacol Ther. 2008 Aug;21(4):663–7. doi: 10.1016/j.pupt.2008.03.001. PMID: 18479954. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18479954
Hazucha MJ, Ginsberg JF, McDonnell WF, . Effects of 0.1 ppm nitrogen dioxide on airways of normal and asthmatic subjects. J Appl Physiol Respir Environ Exerc Physiol. 1983 Mar;54(3):730–9. PMID: 6341338. The study does not evaluate FeNO6341338
Heffler E, Pizzimenti S, Badiu I, . Nasal nitric oxide is a marker of poor asthma control. J Breath Res. 2013 Jun;7(2):026009. doi: 10.1088/1752-7155/7/2/026009. PMID: 23665726. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23665726
Helenius I, Lumme A, Ounap J, . No effect of montelukast on asthma-like symptoms in elite ice hockey players. Allergy. 2004 Jan;59(1):39–44. doi: 10.1046/j.1398-9995.2003.00353.x. PMID: 14674932. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)14674932
Henriksen AH, Holmen TL, Bjermer L. Gender differences in asthma prevalence may depend on how asthma is defined. Respir Med. 2003 May;97(5):491–7. doi: 10.1053/rmed.2002.1470. PMID: 12735665. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12735665
Henriksen AH, Holmen TL, Bjermer L. Sensitization and exposure to pet allergens in asthmatics versus non-asthmatics with allergic rhinitis. Respir Med. 2001 Feb;95(2):122–9. doi: 10.1053/rmed.2000.1004. PMID: 11217908. The study does not have a comparison group (studies must have a comparison group or pre/post design)11217908
Henriksen AH, Sue-Chu M, Holmen TL, . Exhaled and nasal NO levels in allergic rhinitis: relation to sensitization, pollen season and bronchial hyperresponsiveness. European Respiratory Journal. 1999 Feb;13(2):301–6. doi: DOI 10.1034/j.1399-3003.1999.13b14.x. PMID: WOS:000078776000014. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10065672
Henriksen AH, Tveit KH, Holmen TL, . A study of the association between exercise-induced wheeze and exercise versus methacholine-induced bronchoconstriction in adolescents. Pediatric Allergy and Immunology. 2002 Jun;13(3):203–8. doi: DOI 10.1034/j.1399-3038.2002.01034.x. PMID: WOS:000177149000010. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12144643
Henriksen AH, Sue-Chu M, Holmen TL, . Exhaled and nasal NO levels in allergic rhinitis: relation to sensitization, pollen season and bronchial hyperresponsiveness. European Respiratory Journal. 1999 Feb;13(2):301–6. doi: DOI 10.1034/j.1399-3003.1999.13b14.x. PMID: WOS:000078776000014. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)10065672
Hervas D, Milan JM, Garde J. Differences in exhaled nitric oxide in atopic children. Allergol Immunopathol (Madr). 2008 Nov–Dec;36(6):331–5. doi: 10.1016/S0301-0546(08)75865–8. PMID: 19150032. The study does not have a comparison group (studies must have a comparison group or pre/post design)19150032
Hillas G, Kostikas K, Mantzouranis K, . Exhaled nitric oxide and exhaled breath condensate pH as predictors of sputum cell counts in optimally treated asthmatic smokers. Respirology. 2011 Jul;16(5):811–8. doi: 10.1111/j.1440-1843.2011.01984.x. PMID: 21545371. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)21545371
Ho LP, Wood FT, Robson A, . The current single exhalation method of measuring exhales nitric oxide is affected by airway calibre. Eur Respir J. 2000 Jun;15(6):1009–13. doi: 10.1034/j.1399-3003.2000.01506.x. PMID: 10885417. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10885417
Hodgson D, Anderson J, Reynolds C, . A randomised controlled trial of small particle inhaled steroids in refractory eosinophilic asthma (SPIRA). Thorax. 2015 Jun;70(6):559–65. doi: 10.1136/thoraxjnl-2014-206481. PMID: 25858909. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25858909
Hogman M, Ludviksdottir D, Anderson SD, . Inhaled mannitol shifts exhaled nitric oxide in opposite directions in asthmatics and healthy subjects. Respir Physiol. 2001 Jan;124(2):141–50. doi: 10.1016/S0034-5687(00)00195-X. PMID: 11164205. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11164205
Hogman M, Malinovschi A, Norback D, . Added value with extended NO analysis in atopy and asthma. Clinical Physiology and Functional Imaging. 2011 Jul;31(4):294–9. doi: 10.1111/j.1475-097X.2011.01017.x. PMID: WOS:000292361700007. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21672137
Hojo M, Shirai T, Hirashima J, . Comparison of the clinical effects of combined salmeterol/fluticasone delivered by dry powder or pressurized metered dose inhaler. Pulm Pharmacol Ther. 2016 Apr;37:43–8. doi: 10.1016/j.pupt.2016.02.004. PMID: 26898348. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26898348
Hojo M, Mizutani T, Iikura M, . [Clinical study concerning anti-inflammatory effect of fixed dose therapy by budesonide/formoterol combination inhaler for moderate persistent asthmatics]. Arerugi. 2011 May;60(5):575–85. doi: 10.15036/arerugi.60.575. PMID: 21617360. The study does not have a comparison group (studies must have a comparison group or pre/post design)21617360
Holguin F, Flores S, Ross Z, . Traffic-related exposures, airway function, inflammation, and respiratory symptoms in children. Am J Respir Crit Care Med. 2007 Dec 15;176(12):1236–42. doi: 10.1164/rccm.200611-1616OC. PMID: 17641154. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17641154
Honkoop PJ, Loymans RJ, Termeer EH, . Asthma control cost-utility randomized trial evaluation (ACCURATE): the goals of asthma treatment. BMC Pulm Med. 2011 Nov 24;11:53. doi: 10.1186/1471-2466-11-53. PMID: 22114896. The study is not original (commentaries, letters, etc. should be excluded)22114896
Horiuchi K, Kasahara K, Kuroda Y, . Step-down therapy in well-controlled asthmatic patients using salmeterol xinafoate/fluticasone propionate combination therapy. Journal of Asthma and Allergy. 2016 18 Mar;9:65–70. doi: 10.2147/Jaa.S93782. PMID: WOS:000383540400001. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)27051309
Hovland V, Riiser A, Mowinckel P, . Asthma with allergic comorbidities in adolescence is associated with bronchial responsiveness and airways inflammation. Pediatr Allergy Immunol. 2014 Jun;25(4):351–9. doi: 10.1111/pai.12241. PMID: 24953295. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24953295
Hozawa S, Terada M, Haruta Y, . Comparison of early effects of budesonide/formoterol maintenance and reliever therapy with fluticasone furoate/vilanterol for asthma patients requiring step-up from inhaled corticosteroid monotherapy. Pulm Pharmacol Ther. 2016 Apr;37:15–23. doi: 10.1016/j.pupt.2016.01.005. PMID: 26850307. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26850307
Hozawa S, Terada M, Hozawa M. Comparison of budesonide/formoterol Turbuhaler with fluticasone/salmeterol Diskus for treatment effects on small airway impairment and airway inflammation in patients with asthma. Pulm Pharmacol Ther. 2011 Oct;24(5):571–6. doi: 10.1016/j.pupt.2011.05.004. PMID: 21624490. The study does not have a comparison group (studies must have a comparison group or pre/post design)21624490
Hsu JY, Wang CY, Cheng YW, . Optimal value of fractional exhaled nitric oxide in inhaled corticosteroid treatment for patients with chronic cough of unknown cause. J Chin Med Assoc. 2013 Jan;76(1):15–9. doi: 10.1016/j.jcma.2012.08.010. PMID: 23331776. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23331776
Hughes JL, Brown T, Edgar JD, . Peanut allergy and allergic airways inflammation. Pediatr Allergy Immunol. 2010 Dec;21(8):1107–13. doi: 10.1111/j.1399-3038.2010.01071.x. PMID: 20561237. Other reason20561237
Hung, C H, Lee, . Exhaled Nitric Oxide in Airway Diseases of Children. Pediatric Asthma, Allergy and Immunology. 2004;17(1):37–44. doi: 10.1089/088318704322994921. PMID: 2004160984. The study does not have a comparison group (studies must have a comparison group or pre/post design)
Hung CH, Hua YM, Hsu WT, . Montelukast decreased exhaled nitric oxide in children with perennial allergic rhinitis. Pediatr Int. 2007 Jun;49(3):322–7. doi: 10.1111/j.1442-200X.2007.02375.x. PMID: 17532829. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17532829
Hung CH, Lee MY, Tsai YG, . Hyposensitization therapy reduced exhaled nitric oxide in asthmatic children with corticosteroid dependency. Acta Paediatr Taiwan. 2004 Mar–Apr;45(2):89–93. PMID: 15335118. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15335118
Hussain S, Laumbach R, Coleman J, . Controlled Exposure to Diesel Exhaust Causes Increased Nitrite in Exhaled Breath Condensate Among Subjects With Asthma. Journal of Occupational and Environmental Medicine. 2012 Oct;54(10):1186–91. doi: 10.1097/JOM.0b013e31826bb64c. PMID: WOS:000309794200005. Other reason23001278
Huszar E, Vass G, Vizi E, . Adenosine in exhaled breath condensate in healthy volunteers and in patients with asthma. Eur Respir J. 2002 Dec;20(6):1393–8. doi: 10.1183/09031936.02.00005002. PMID: 12503694. The study does not have a comparison group (studies must have a comparison group or pre/post design)12503694
Ihre E, Gyllfors P, Gustafsson LE, . Early rise in exhaled nitric oxide and mast cell activation in repeated low-dose allergen challenge. Eur Respir J. 2006 Jun;27(6):1152–9. doi: 10.1183/09031936.06.00142905. PMID: 16510451. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16510451
Ioannides SJ, Williams M, Jefferies S, . Randomised placebo-controlled study of the effect of paracetamol on asthma severity in adults. BMJ Open. 2014 Feb 12;4(2):e004324. doi: 10.1136/bmjopen-2013-004324. PMID: 24525393. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24525393
Ishizuka T, Hisada T, Kamide Y, . The effects of concomitant GERD, dyspepsia, and rhinosinusitis on asthma symptoms and FeNO in asthmatic patients taking controller medications. J Asthma Allergy. 2014;7:131–9. doi: 10.2147/JAA.S67062. PMID: 25228816. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25228816
Ito J, Tsuburai T, Atsuta R, . [Comparison of exhaled nitric oxide levels measured by two offline methods and the NO breath(R) method in Japan]. Arerugi. 2014 Nov;63(9):1241–9. PMID: 25492879. The study does not have a comparison group (studies must have a comparison group or pre/post design)25492879
Ito Y, Adachi Y, Itazawa T, . Association between the results of the childhood asthma control test and objective parameters in asthmatic children. J Asthma. 2011 Dec;48(10):1076–80. doi: 10.3109/02770903.2011.629356. PMID: 22047529. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22047529
Jaen C, Dalton P. Asthma and odors: the role of risk perception in asthma exacerbation. J Psychosom Res. 2014 Oct;77(4):302–8. doi: 10.1016/j.jpsychores.2014.07.002. PMID: 25280827. The study does not evaluate FeNO25280827
James AL, Knuiman MW, Divitini ML, . Risk factors for respiratory symptoms in adults: the Busselton Health Study. Respirology. 2013 Nov;18(8):1256–60. doi: 10.1111/resp.12147. PMID: 23796074. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23796074
Jatakanon A, Lim S, Chung KF, . An inhaled steroid improves markers of airway inflammation in patients with mild asthma. Eur Respir J. 1998 Nov;12(5):1084–8. doi: 10.1183/09031936.98.12051084. PMID: 9864001. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9864001
Jensen ME, Gibson PG, Collins CE, . Diet-induced weight loss in obese children with asthma: a randomized controlled trial. Clin Exp Allergy. 2013 Jul;43(7):775–84. doi: 10.1111/cea.12115. PMID: 23786284. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23786284
Jentzsch NS, le Bourgeois M, de Blic J, . Nitric oxide in children with persistent asthma. J Pediatr (Rio J). 2006 May–Jun;82(3):193–6. doi: doi:10.2223/JPED.1472. PMID: 16683051. The study does not have a comparison group (studies must have a comparison group or pre/post design)16683051
Jo EJ, Song WJ, Kim TW, . Reference ranges and determinant factors for exhaled nitric oxide in a healthy korean elderly population. Allergy Asthma Immunol Res. 2014 Nov;6(6):504–10. doi: 10.4168/aair.2014.6.6.504. PMID: 25374749. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)25374749
Jobsis Q, Raatgeep HC, Hop WC, . Controlled low flow off line sampling of exhaled nitric oxide in children. Thorax. 2001 Apr;56(4):285–9. doi: 10.1136/thorax.56.4.285. PMID: 11254819. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)11254819
Jobsis Q, Schellekens SL, Kroesbergen A, . Off-line sampling of exhaled air for nitric oxide measurement in children: methodological aspects. Eur Respir J. 2001 May;17(5):898–903. PMID: 11488323. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)11488323
Johansson H, Norlander K, Alving K, . Exercise test using dry air in random adolescents: Temporal profile and predictors of bronchoconstriction. Respirology. 2016 Feb;21(2):289–96. doi: 10.1111/resp.12682. PMID: WOS:000373127300011. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26588807
Jouaville LF, Annesi-Maesano I, Nguyen LT, . Interrelationships among asthma, atopy, rhinitis and exhaled nitric oxide in a population-based sample of children. Clinical and Experimental Allergy. 2003 Nov;33(11):1506–11. doi: DOI 10.1046/j.1365-2222.2003.01800.x. PMID: WOS:000186435400007. The study does not have a comparison group (studies must have a comparison group or pre/post design)14616861
Just, J, Saint P, . Childhood allergic asthma is not a single phenotype. Journal of Pediatrics. 2014 April;164(4):815–20. doi: 10.1016/j.jpeds.2013.11.037. PMID: 2014197167. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24412137
Juusela M, Pallasaho P, Ronmark E, . Dose-dependent association of smoking and bronchial hyperresponsiveness. Eur Respir J. 2013 Dec;42(6):1503–12. doi: 10.1183/09031936.00073712. PMID: 23722612. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23722612
Kalicki, B. Usefulness of exhalted air condensate examination in monitoring children with asthma. Pediatria i Medycyna Rodzinna. 2007;3(2):91–4. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Kaljanac MD. The impact of fraction of exhaled nitric oxide measurements in patients with asthma exacerbation. Zdravniski Vestnik-Slovenian Medical Journal. 2011 Oct;80(10):748–57. PMID: WOS:000296286900005. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Kalliola S, Malmberg P, Rito T, . Can we use portable nitric oxide analyzer in young children? Pediatr Pulmonol. 2011 Jul;46(7):627–31. doi: 10.1002/ppul.21390. PMID: 21634029. The study does not have a comparison group (studies must have a comparison group or pre/post design)21634029
Kałuzińska P, I, Majak, . Sublingual immunotherapy is effective and safe in children. Alergia Astma Immunologia. 2011;16(3):139–44. The study does not evaluate FeNO
Kaminsky DA, Rice AA, Bissonette M, . Exhaled nitric oxide decreases in association with attendance at an asthma summer cAMP. J Asthma. 2008 Jun;45(5):415–9. doi: 10.1080/02770900801971842. PMID: 18569236. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18569236
Kanazawa H, Kyoh S, Asai K, . Validity of measurement of two specific biomarkers for the assessment of small airways inflammation in asthma. J Asthma. 2010 May;47(4):400–6. doi: 10.3109/02770901003759394. PMID: 20528593. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20528593
Kanniess F, Diamant Z, Lomax M. Effects of low- versus high-dose fluticasone propionate/formoterol fumarate combination therapy on AMP challenge in asthmatic patients: A double-blind, randomised clinical trial. Pulm Pharmacol Ther. 2016 Apr;37:65–72. doi: 10.1016/j.pupt.2016.02.003. PMID: 26912209. The study does not evaluate FeNO26912209
Kanniess F, Richter K, Janicki S, . Dose reduction of inhaled corticosteroids under concomitant medication with montelukast in patients with asthma. Eur Respir J. 2002 Nov;20(5):1080–7. doi: 10.1183/09031936.02.00304202. PMID: 12449158. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12449158
Kanniess F, Richter K, Bohme S, . Effect of inhaled ciclesonide on airway responsiveness to inhaled AMP, the composition of induced sputum and exhaled nitric oxide in patients with mild asthma. Pulm Pharmacol Ther. 2001;14(2):141–7. doi: 10.1006/pupt.2001.0288. PMID: 11273796. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11273796
Kanniess F, Richter K, Bohme S, . Montelukast versus fluticasone: effects on lung function, airway responsiveness and inflammation in moderate asthma. Eur Respir J. 2002 Oct;20(4):853–8. doi: 10.1183/09031936.02.00244602. PMID: 12412675. The study does not have a comparison group (studies must have a comparison group or pre/post design)12412675
Kappelle L, Brand PL. Severe episodic viral wheeze in preschool children: High risk of asthma at age 5–10 years. Eur J Pediatr. 2012 Jun;171(6):947–54. doi: 10.1007/s00431-011-1663-7. PMID: 22234479. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22234479
Katial RK, Strand M, Prasertsuntarasai T, . The effect of aspirin desensitization on novel biomarkers in aspirin-exacerbated respiratory diseases. J Allergy Clin Immunol. 2010 Oct;126(4):738–44. doi: 10.1016/j.jaci.2010.06.036. PMID: 20728206. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20728206
Keen C, Olin AC, Wennergren G, . Small airway function, exhaled NO and airway hyper-responsiveness in paediatric asthma. Respir Med. 2011 Oct;105(10):1476–84. doi: 10.1016/j.rmed.2011.04.004. PMID: 21570274. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21570274
Kerckx Y, Michils A, Van Muylem A. Airway contribution to alveolar nitric oxide in healthy subjects and stable asthma patients. J Appl Physiol (1985). 2008 Apr;104(4):918–24. doi: 10.1152/japplphysiol.01032.2007. PMID: 18218917. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18218917
Kersten ET, van Leeuwen JC, Brand PL, . Effect of an intranasal corticosteroid on exercise induced bronchoconstriction in asthmatic children. Pediatr Pulmonol. 2012 Jan;47(1):27–35. doi: 10.1002/ppul.21511. PMID: 22170807. The study does not have a comparison group (studies must have a comparison group or pre/post design)22170807
Ketai L, Harkins M, Fiato KL, . Exhaled nitric oxide and bronchial wall thickening in asthmatics during and after acute exacerbation: evidence of bronchial wall remodeling. J Asthma. 2005 Oct;42(8):667–71. doi: 10.1080/02770900500264978. PMID: 16266958. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16266958
Khalili B, Boggs PB, Shi R, . Discrepancy between clinical asthma control assessment tools and fractional exhaled nitric oxide. Annals of Allergy Asthma & Immunology. 2008 Aug;101(2):124–9. doi: 10.1016/S1081-1206(10)60199-8. PMID: WOS:000258366100003. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Khalili B, Boggs PB, Bahna SL. Reliability of a new hand-held device for the measurement of exhaled nitric oxide. Allergy. 2007 Oct;62(10):1171–4. doi: 10.1111/j.1398-9995.2007.01475.x. PMID: 17845587. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17845587
Khan FI, Reddy RC, Baptist AP. Pediatric Dyspnea Scale for use in hospitalized patients with asthma. J Allergy Clin Immunol. 2009 Mar;123(3):660–4. doi: 10.1016/j.jaci.2008.12.018. PMID: 19181371. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19181371
Kharitonov SA, Rajakulasingam K, OConnor B, . Nasal nitric oxide is increased in patients with asthma and allergic rhinitis and may be modulated by nasal glucocorticoids. Journal of Allergy and Clinical Immunology. 1997 Jan;99(1):58–64. doi: 10.1016/S0091-6749(97)70301-4. PMID: WOS:A1997WD06100009. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9003212
Kharitonov, S A, Sapienza, . Prostaglandins E<inf>2</inf> and F(<inf>2</inf>alpha) reduce exhaled nitric oxide in normal and asthmatic subjects irrespective of airway caliber changes. American Journal of Respiratory and Critical Care Medicine. 1998;158(5 I):1374–8. doi: 10.1164/ajrccm.158.5.9707076. PMID: 1998399810. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9817681
Kharitonov SA, Yates DH, Chung KF, . Changes in the dose of inhaled steroid affect exhaled nitric oxide levels in asthmatic patients. Eur Respir J. 1996 Feb;9(2):196–201. doi: 10.1183/09031936.96.09020196. PMID: 8777950. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)8777950
Khatri SB, Hammel J, Kavuru MS, . Temporal association of nitric oxide levels and airflow in asthma after whole lung allergen challenge. J Appl Physiol (1985). 2003 Jul;95(1):436–40; discussion 5. doi: 10.1152/japplphysiol.01127.2002. PMID: 12576414. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12576414
Kielbasa B, Moeller A, Sanak M, . Eicosanoids in exhaled breath condensates in the assessment of childhood asthma. Pediatr Allergy Immunol. 2008 Nov;19(7):660–9. doi: 10.1111/j.1399-3038.2008.00770.x. PMID: 18643946. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18643946
Kim SH, Kim TH, Sohn JW, . Reference values and determinants of exhaled nitric oxide in healthy Korean adults. J Asthma. 2010 Jun;47(5):563–7. doi: 10.3109/02770901003702840. PMID: 20536283. Other reason20536283
Kim YH, Park HB, Kim MJ, . Fractional exhaled nitric oxide and impulse oscillometry in children with allergic rhinitis. Allergy Asthma Immunol Res. 2014 Jan;6(1):27–32. doi: 10.4168/aair.2014.6.1.27. PMID: 24404390. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24404390
Kissoon N, Duckworth LJ, Blake KV, . Effect of beta2-agonist treatment and spirometry on exhaled nitric oxide in healthy children and children with asthma. Pediatr Pulmonol. 2002 Sep;34(3):203–8. doi: 10.1002/ppul.10154. PMID: 12203849. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12203849
Ko FW, Leung TF, Hui DS, . Asthma Control Test correlates well with the treatment decisions made by asthma specialists. Respirology. 2009 May;14(4):559–66. doi: 10.1111/j.1440-1843.2009.01514.x. PMID: 19383110. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19383110
Kobayashi D, Tochino Y, Kanazawa H, . Comparison of alveolar nitric oxide concentrations using two different methods for assessing small airways obstruction in asthma. Respirology. 2011 Jul;16(5):862–8. doi: 10.1111/j.1440-1843.2011.01989.x. PMID: WOS:000292162700019. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21564400
Kobayashi Y, Asako M, Ooka H, . Residual exhaled nitric oxide elevation in asthmatics is associated with eosinophilic chronic rhinosinusitis. Journal of Asthma. 2015 Nov 26;52(10):1060–4. doi: 10.3109/02770903.2015.1054404. PMID: WOS:000366245800012. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)26288109
Koek GH, Verleden GM, Evenepoel P, . Activity related increase of exhaled nitric oxide in Crohn’s disease and ulcerative colitis: a manifestation of systemic involvement? Respir Med. 2002 Jul;96(7):530–5. doi: 10.1053/rmed.2002.1312. PMID: 12194639. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)12194639
Koenig JQ, Jansen K, Mar TF, . Measurement of offline exhaled nitric oxide in a study of community exposure to air pollution. Environ Health Perspect. 2003 Oct;111(13):1625–9. PMID: 14527842. Other reason14527842
Konstantellou E, Papaioannou AI, Loukides S, . Persistent airflow obstruction in patients with asthma: Characteristics of a distinct clinical phenotype. Respir Med. 2015 Nov;109(11):1404–9. doi: 10.1016/j.rmed.2015.09.009. PMID: 26412805. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26412805
Konstantinou GN, Xepapadaki P, Manousakis E, . Assessment of airflow limitation, airway inflammation, and symptoms during virus-induced wheezing episodes in 4- to 6-year-old children. J Allergy Clin Immunol. 2013 Jan;131(1):87–93 e1–5. doi: 10.1016/j.jaci.2012.10.033. PMID: 23199600. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23199600
Koo S, Gupta A, Fainardi V, . Ethnic Variation in Response to IM Triamcinolone in Children With Severe Therapy-Resistant Asthma. Chest. 2016 Jan;149(1):98–105. doi: 10.1378/chest.14-3241. PMID: 26378892. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26378892
Korhonen, K, Purokivi, . Exhaled nitric oxide as a marker of atopic asthma. Allergology International. 2002;51(1):47–53. doi: 10.1046/j.1440-1592.2002.00247.x. PMID: 2002122127. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Korn S, Telke I, Kornmann O, . Measurement of exhaled nitric oxide: comparison of different analysers. Respirology. 2010 Nov;15(8):1203–8. doi: 10.1111/j.1440-1843.2010.01847.x. PMID: 20920124. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20920124
Koskela HO, Purokivi MK, Kontra KM, . Hypertonic saline cough provocation test with salbutamol pre-treatment: evidence for sensorineural dysfunction in asthma. Clin Exp Allergy. 2008 Jul;38(7):1100–7. doi: 10.1111/j.1365-2222.2008.02996.x. PMID: 18462452. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18462452
Kostikas, K, Minas, . Exhaled nitric oxide in asthma in adults: The end is the beginning? Current Medicinal Chemistry. 2011 April;18(10):1423–31. doi: 10.2174/092986711795328436. PMID: 2011219039. This is a systematic review/meta-analysis/guideline21434851
Kostrzon M, Czarnobilski K, Czarnobilska E. The influence of pulmonary rehabilitation in the Wieliczka Salt Mine on asthma control--preliminary results. Przegl Lek. 2015;72(12):716–20. PMID: 27024946. The study does not evaluate FeNO27024946
Kotaru C, Coreno A, Skowronski M, . Exhaled nitric oxide and thermally induced asthma. Am J Respir Crit Care Med. 2001 Feb;163(2):383–8. doi: 10.1164/ajrccm.163.2.2003138. PMID: 11179111. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11179111
Kroesbergen A, Jobsis Q, Bel EH, . Flow-dependency of exhaled nitric oxide in children with asthma and cystic fibrosis. Eur Respir J. 1999 Oct;14(4):871–5. doi: 10.1034/j.1399-3003.1999.14d24.x. PMID: 10573235. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10573235
Kullowatz A, Rosenfield D, Dahme B, . Stress effects on lung function in asthma are mediated by changes in airway inflammation. Psychosom Med. 2008 May;70(4):468–75. doi: 10.1097/PSY.0b013e31816f9c2f. PMID: 18480192. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18480192
Kurashima K, Kagiyama N, Takayanagi N, . Comparison of high-dose salmeterol/fluticasone and moderate-dose salmeterol/fluticasone plus low-dose mometasone in patients with severe persistent asthma. Respirology. 2011 Jul;16(5):784–9. doi: 10.1111/j.1440-1843.2011.01967.x. PMID: 21382132. The study does not have a comparison group (studies must have a comparison group or pre/post design)21382132
Kurukulaaratchy RJ, Zhang HM, Patil V, . Identifying the heterogeneity of young adult rhinitis through cluster analysis in the Isle of Wight birth cohort. Journal of Allergy and Clinical Immunology. 2015 Jan;135(1):143–U225. doi: 10.1016/j.jaci.2014.06.017. PMID: WOS:000347298200017. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)25085342
Labor M, Popovic-Grle S, Labor S, . Asthma control in obesity-associated asthma phenotype in East Croatia. Med Glas (Zenica). 2014 Feb;11(1):49–57. PMID: 24496341. Other reason24496341
Lang A, Carlsen KH, Haaland G, . Severe asthma in childhood: assessed in 10 year olds in a birth cohort study. Allergy. 2008 Aug;63(8):1054–60. doi: 10.1111/j.1398-9995.2008.01672.x. PMID: 18691307. The study does not have a comparison group (studies must have a comparison group or pre/post design)18691307
Lang, A, Konradsen, . Identifying problematic severe asthma in the individual child - Does lung function matter? Acta Paediatrica, International Journal of Paediatrics. 2010 March;99(3):404–10. doi: 10.1111/j.1651-2227.2009.01625.x. PMID: 2010127901. The study does not have a comparison group (studies must have a comparison group or pre/post design)
Lang A, Mowinckel P, Sachs-Olsen C, . Asthma severity in childhood, untangling clinical phenotypes. Pediatr Allergy Immunol. 2010 Sep;21(6):945–53. doi: 10.1111/j.1399-3038.2010.01072.x. PMID: 20718926. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20718926
Lang JE, Hossain MJ, Lima JJ. Overweight children report qualitatively distinct asthma symptoms: analysis of validated symptom measures. J Allergy Clin Immunol. 2015 Apr;135(4):886–93 e3. doi: 10.1016/j.jaci.2014.08.029. PMID: 25441640. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25441640
Langley EW, Gebretsadik T, Hartert TV, . Exhaled nitric oxide is associated with severity of pediatric acute asthma exacerbations. Journal of Allergy and Clinical Immunology-in Practice. 2014 Sep–Oct;2(5):618-+. doi: 10.1016/j.jaip.2014.04.004. PMID: WOS:000354205300019. The study does not have a comparison group (studies must have a comparison group or pre/post design)
Langley SJ, Goldthorpe S, Craven M, . Relationship between exposure to domestic allergens and bronchial hyperresponsiveness in non-sensitised, atopic asthmatic subjects. Thorax. 2005 Jan;60(1):17–21. doi: 10.1136/thx.2004.027839. PMID: WOS:000225960100007. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15618577
Langley SJ, Goldthorpe S, Craven M, . Exposure and sensitization to indoor allergens: association with lung function, bronchial reactivity, and exhaled nitric oxide measures in asthma. J Allergy Clin Immunol. 2003 Aug;112(2):362–8. doi: 10.1067/mai.2003.1654. PMID: 12897743. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12897743
Langley SJ, Goldthorpe S, Custovic A, . Relationship among pulmonary function, bronchial reactivity, and exhaled nitric oxide in a large group of asthmatic patients. Ann Allergy Asthma Immunol. 2003 Oct;91(4):398–404. doi: 10.1016/S1081-1206(10)61688-2. PMID: 14582820. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)14582820
Lanphear BP, Hornung RW, Khoury J, . Effects of HEPA air cleaners on unscheduled asthma visits and asthma symptoms for children exposed to secondhand tobacco smoke. Pediatrics. 2011 Jan;127(1):93–101. doi: 10.1542/peds.2009-2312. PMID: 21149427. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21149427
Lanz MJ, Eisenlohr C, Llabre MM, . The effect of low-dose inhaled fluticasone propionate on exhaled nitric oxide in asthmatic patients and comparison with oral zafirlukast. Ann Allergy Asthma Immunol. 2001 Oct;87(4):283–8. doi: 10.1016/S1081-1206(10)62241-7. PMID: 11686419. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11686419
Lanz MJ, Leung DY, White CW. Comparison of exhaled nitric oxide to spirometry during emergency treatment of asthma exacerbations with glucocorticoids in children. Ann Allergy Asthma Immunol. 1999 Feb;82(2):161–4. doi: 10.1016/S1081-1206(10)62591-4. PMID: 10071519. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10071519
Larstad M, Soderling AS, Caidahl K, . Selective quantification of free 3-nitrotyrosine in exhaled breath condensate in asthma using gas chromatography/tandem mass spectrometry. Nitric Oxide. 2005 Sep;13(2):134–44. doi: 10.1016/j.niox.2005.05.009. PMID: 16006156. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16006156
Lazar Z, Cervenak L, Orosz M, . Adenosine triphosphate concentration of exhaled breath condensate in asthma. Chest. 2010 Sep;138(3):536–42. doi: 10.1378/chest.10–0085. PMID: 20382721. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20382721
Leaker BR, Barnes PJ, O’Connor BJ, . The effects of the novel SHIP1 activator AQX-1125 on allergen-induced responses in mild-to-moderate asthma. Clin Exp Allergy. 2014 Sep;44(9):1146–53. doi: 10.1111/cea.12370. PMID: 25040039. The study does not evaluate FeNO25040039
Leblanc, A, de C, . Evolution and asthma control in pregnant women followed in an immunoallergy department. Revista Portuguesa de Imunoalergologia. 2013;21(2):117–24. PMID: 2013516526. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Lee BJ, Jeung YJ, Lee JY, . Increased S-nitrosothiol levels in nonasthmatic eosinophilic bronchitis compared with cough variant asthma. Int Arch Allergy Immunol. 2011 August;156(1):99–103. doi: 10.1159/000321919. PMID: 21447965. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21447965
Lee Lee DK, Haggart K, Currie GP, . Effects of hydrofluoroalkane formulations of ciclesonide 400 microg once daily vs fluticasone 250 microg twice daily on methacholine hyper-responsiveness in mild-to-moderate persistent asthma. Br J Clin Pharmacol. 2004 Jul;58(1):26–33. doi: 10.1111/j.1365-2125.2004.02108.x. PMID: 15206989. Other reason15206989
Lee MY, Lai YS, Yang KD, . Effects of montelukast on symptoms and eNO in children with mild to moderate asthma. Pediatr Int. 2005 Dec;47(6):622–6. doi: 10.1111/j.1442-200x.2005.02142.x. PMID: 16354213. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16354213
Lee MY, Tsai YG, Yang KD, . Comparison of the effects of nebulized terbutaline with or without intravenous betamethasone on exhaled nitric oxide in children with acute asthma attack. J Microbiol Immunol Infect. 2006 Feb;39(1):33–8. PMID: 16440121. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16440121
Lehtimaki L, Kankaanranta H, Saarelainen S, . Increased alveolar nitric oxide concentration in asthmatic patients with nocturnal symptoms. Eur Respir J. 2002 Oct;20(4):841–5. doi: 10.1183/09031936.02.00202002. PMID: 12412673. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12412673
Leung TF, Ko FW, Sy HY, . Identifying uncontrolled asthma in young children: clinical scores or objective variables? J Asthma. 2009 Mar;46(2):130–5. doi: 10.1080/02770900802468533. PMID: 19253117. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19253117
Leung TF, Wong YS, Chan IH, . Domestic exposure to aeroallergens in Hong Kong families with asthmatic children. Pediatr Pulmonol. 2011 Jul;46(7):632–9. doi: 10.1002/ppul.21391. PMID: 21634030. Other reason21634030
Leung TF, Wong YS, Chan IH, . Indoor determinants of endotoxin and dust mite exposures in Hong Kong homes with asthmatic children. Int Arch Allergy Immunol. 2010 June;152(3):279–87. doi: 10.1159/000283039. PMID: 20150746. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20150746
Leung TF, Ko FW, Wong GW, . Predicting changes in clinical status of young asthmatics: clinical scores or objective parameters? Pediatr Pulmonol. 2009 May;44(5):442–9. doi: 10.1002/ppul.20977. PMID: 19382219. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19382219
Leung TF, To MY, Yeung AC, . Multiplex molecular detection of respiratory pathogens in children with asthma exacerbation. Chest. 2010 Feb;137(2):348–54. doi: 10.1378/chest.09-1250. PMID: 19749009. The study does not have a comparison group (studies must have a comparison group or pre/post design)19749009
Leuppi JD, Downs SH, Downie SR, . Exhaled nitric oxide levels in atopic children: relation to specific allergic sensitisation, AHR, and respiratory symptoms. Thorax. 2002 Jun;57(6):518–23. doi: 10.1136/thorax.57.6.518. PMID: 12037227. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)12037227
Lex C, Ferreira F, Zacharasiewicz A, . Airway eosinophilia in children with severe asthma: predictive values of noninvasive tests. Am J Respir Crit Care Med. 2006 Dec 15;174(12):1286–91. doi: 10.1164/rccm.200603-352OC. PMID: 16973985. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16973985
Lex C, Payne DN, Zacharasiewicz A, . Is a two-week trial of oral prednisolone predictive of target lung function in pediatric asthma? Pediatr Pulmonol. 2005 Jun;39(6):521–7. doi: 10.1002/ppul.20189. PMID: 15765544. The study does not evaluate FeNO15765544
Li AM, Tsang TW, Chan DF, . Cough frequency in children with mild asthma correlates with sputum neutrophil count. Thorax. 2006 Sep;61(9):747–50. doi: 10.1136/thx.2005.050815. PMID: 16670174. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16670174
Li AM, Tsang TW, Chan DF, . Sputum induction in children with asthma: a tertiary-center experience. Pediatr Pulmonol. 2006 Aug;41(8):720–5. doi: 10.1002/ppul.20371. PMID: 16779847. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16779847
Li AM, Tsang TW, Chan K, . Once-daily fluticasone propionate in stable asthma: study on airway inflammation. J Asthma. 2006 Mar;43(2):107–11. doi: 10.1080/02770900500497990. PMID: 16517426. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16517426
Li S, Lou XS, Ma Y, . [Exhaled nitric oxide levels in school children of Beijing]. Zhonghua Er Ke Za Zhi. 2010 Feb;48(2):148–52. PMID: 20426942. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20426942
Lim AY, Chambers DC, Ayres JG, . Exhaled nitric oxide in cystic fibrosis patients with allergic bronchopulmonary aspergillosis. Respir Med. 2003 Apr;97(4):331–6. doi: 10.1053/rmed.2002.1430. PMID: 12693794. Other reason12693794
Lim S, Jatakanon A, Meah S, . Relationship between exhaled nitric oxide and mucosal eosinophilic inflammation in mild to moderately severe asthma. Thorax. 2000 Mar;55(3):184–8. doi: DOI 10.1136/thorax.55.3.184. PMID: WOS:000085616400003. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10679535
Lin CH, Hsu JY, Hsiao YH, . Budesonide/formoterol maintenance and reliever therapy in asthma control: acute, dose-related effects and real-life effectiveness. Respirology. 2015 Feb;20(2):264–72. doi: 10.1111/resp.12425. PMID: 25366969. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25366969
Lingner H, Ernst S, Grobetahennig A, . Asthma control and health-related quality of life one year after inpatient pulmonary rehabilitation: the ProKAR Study. J Asthma. 2015;52(6):614–21. doi: 10.3109/02770903.2014.996650. PMID: 25494552. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25494552
Linkosalo L, Lehtimaki L, Holm K, . Relation of bronchial and alveolar nitric oxide to exercise-induced bronchoconstriction in atopic children and adolescents. Pediatr Allergy Immunol. 2012 Jun;23(4):360–6. doi: 10.1111/j.1399-3038.2011.01223.x. PMID: 22145648. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22145648
Linnane SJ, Keatings VM, Costello CM, . Total sputum nitrate plus nitrite is raised during acute pulmonary infection in cystic fibrosis. Am J Respir Crit Care Med. 1998 Jul;158(1):207–12. doi: 10.1164/ajrccm.158.1.9707096. PMID: 9655731. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)9655731
Lipworth BJ, Short PM, Williamson PA, . A randomized primary care trial of steroid titration against mannitol in persistent asthma: STAMINA trial. Chest. 2012 Mar;141(3):607–15. doi: 10.1378/chest.11-1748. PMID: 21998259. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21998259
Liu C, Flexeder C, Fuertes E, . Effects of air pollution on exhaled nitric oxide in children: results from the GINIplus and LISAplus studies. Int J Hyg Environ Health. 2014 Apr–May;217(4–5):483–91. doi: 10.1016/j.ijheh.2013.09.006. PMID: 24210257. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24210257
Liu L, Poon R, Chen L, . Acute effects of air pollution on pulmonary function, airway inflammation, and oxidative stress in asthmatic children. Environ Health Perspect. 2009 Apr;117(4):668–74. doi: 10.1289/ehp11813. PMID: 19440509. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19440509
Liu L, Teague WG, Erzurum S, . Determinants of exhaled breath condensate pH in a large population with asthma. Chest. 2011 Feb;139(2):328–36. doi: 10.1378/chest.10-0163. PMID: 20966042. The study does not evaluate FeNO20966042
Liu S, Gong CH, Fu Z. [Significance of exhaled nitric oxide measurement in remitting childhood asthma with concurrent remitting rhinitis]. Zhongguo Dang Dai Er Ke Za Zhi. 2014 Feb;16(2):161–4. doi: 10.7499/j.issn.1008-8830.2014.02.013. PMID: 24568910. The study does not have a comparison group (studies must have a comparison group or pre/post design)24568910
Lloris Bayo A, Perpina Tordera M, Martinez Perez E, . [Contribution of exhaled nitric oxide measurements to abbreviated bronchial challenge test protocols]. Arch Bronconeumol. 2008 Aug;44(8):402–7. doi: 10.1016/S1579-2129(08)60071-3. PMID: 18775250. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18775250
Louhelainen N, Rytila P, Haahtela T, . Persistence of oxidant and protease burden in the airways after smoking cessation. BMC Pulm Med. 2009 May 27;9(25):25. doi: 10.1186/1471-2466-9-25. PMID: 19473482. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19473482
Louhelainen N, Rytila P, Obase Y, . The value of sputum 8-isoprostane in detecting oxidative stress in mild asthma. J Asthma. 2008 Mar;45(2):149–54. doi: 10.1080/02770900701840261. PMID: 18350407. The study does not have a comparison group (studies must have a comparison group or pre/post design)18350407
Louis I, Goh D, Shek L, . Effects of cold drinks on childhood asthma. Allergy. 2010 Jun;65:687-. PMID: WOS:000329462103435. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Lovstrom, L, Emtner, . High levels of physical activity are associated with poorer asthma control in young females but not in males. Respirology. 2016 01 Jan;21(1):79–87. doi: 10.1111/resp.12671. PMID: 2015526832. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26581686
Lozano J, Cruz MJ, Piquer M, . Assessing the efficacy of immunotherapy with a glutaraldehyde-modified house dust mite extract in children by monitoring changes in clinical parameters and inflammatory markers in exhaled breath. Int Arch Allergy Immunol. 2014;165(2):140–7. doi: 10.1159/000368832. PMID: 25471080. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25471080
Lu M, Wu B, Che D, . FeNO and asthma treatment in children: a systematic review and meta-analysis. Medicine (Baltimore). 2015 Jan;94(4):e347. doi: 10.1097/MD.0000000000000347. PMID: 25634163. This is a systematic review/meta-analysis/guideline25634163
Ludviksdottir D, Janson C, Hogman M, . Exhaled nitric oxide and its relationship to airway responsiveness and atopy in asthma. BHR-Study Group. Respir Med. 1999 Aug;93(8):552–6. doi: 10.1016/S0954-6111(99)90154-3. PMID: 10542988. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10542988
Luijk B, Kempsford RD, Wright AM, . Duration of effect of single-dose inhaled fluticasone propionate on AMP-induced bronchoconstriction. Eur Respir J. 2004 Apr;23(4):559–64. doi: 10.1183/09031936.04.00043504. PMID: 15083754. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15083754
LuLund MB, Kongerud J, Nystad W, . Genetic and environmental effects on exhaled nitric oxide and airway responsiveness in a population-based sample of twins. Eur Respir J. 2007 Feb;29(2):292–8. doi: 10.1183/09031936.00044805. PMID: 17079261. Other reason17079261
Lund MB, Oksne PI, Hamre R, . Increased nitric oxide in exhaled air: an early marker of asthma in non-smoking aluminium potroom workers? Occup Environ Med. 2000 Apr;57(4):274–8. doi: 10.1136/oem.57.4.274. PMID: 10810115. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)10810115
Lundberg JO, Nordvall SL, Weitzberg E, . Exhaled nitric oxide in paediatric asthma and cystic fibrosis. Arch Dis Child. 1996 Oct;75(4):323–6. doi: 10.1136/adc.75.4.323. PMID: 8984919. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)8984919
Macleod KA, Horsley AR, Bell NJ, . Ventilation heterogeneity in children with well controlled asthma with normal spirometry indicates residual airways disease. Thorax. 2009 Jan;64(1):33–7. doi: 10.1136/thx.2007.095018. PMID: 18678703. The study does not evaluate FeNO18678703
Madureira, J, Paciencia, . Childrens health and indoor air quality in primary schools and homes in Portugal - Study design. Journal of Toxicology and Environmental Health - Part A: Current Issues. 2015 18 Jul;78(13–14):915–30. doi: 10.1080/15287394.2015.1048926. PMID: 2015422174. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Mahut, B, Bokov, . Physiological characteristics associated with previous control in asthmatic children. [French]. Revue des Maladies Respiratoires. 2011 November;28(9):1131–7. doi: 10.1016/j.rmr.2011.09.005. PMID: 2011703955. The study does not have a comparison group (studies must have a comparison group or pre/post design)22123139
Mahut B, Peiffer C, Thibaudon M, . What does a single exhaled nitric oxide measurement tell us in asthmatic children? J Asthma. 2009 Oct;46(8):810–4. doi: 10.1080/02770900903114580. PMID: 19863285. Other reason19863285
Mainardi TR, Mellins RB, Miller RL, . Exercise-induced wheeze, urgent medical visits, and neighborhood asthma prevalence. Pediatrics. 2013 Jan;131(1):e127–35. doi: 10.1542/peds.2012-1072. PMID: 23248227. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23248227
Majak P, Jerzynska J, Bojo M, . Cytokine profiling in exhaled breath condensate after exercise challenge in asthmatic children with post-exercise symptoms. Arch Med Sci. 2016 Aug 01;12(4):778–84. doi: 10.5114/aoms.2015.48547. PMID: 27478459. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)27478459
Makris MP, Gratziou C, Aggelides XS, . Exhaled nitric oxide, bronchial hyperresponsiveness and spirometric parameters in patients with allergic rhinitis during pollen season. Iran J Allergy Asthma Immunol. 2011 Dec;10(4):251–60. PMID: 22184267. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22184267
Malerba M, Damiani G, Carpagnano GE, . Values in Elderly People for Exhaled Nitric Oxide Study. Rejuvenation Res. 2016 Jun;19(3):233–8. doi: 10.1089/rej.2015.1706. PMID: 26414479. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26414479
Malerba M, Radaeli A, Olivini A, . Association of FEF25–75% Impairment with Bronchial Hyperresponsiveness and Airway Inflammation in Subjects with Asthma-Like Symptoms. Respiration. 2016;91(3):206–14. doi: 10.1159/000443797. PMID: 26855322. The study does not have a comparison group (studies must have a comparison group or pre/post design)26855322
Malinovschi, A, Janson, . Both allergic and nonallergic asthma are associated with increased FE <inf>NO</inf> levels, but only in never-smokers. Allergy: European Journal of Allergy and Clinical Immunology. 2009 January;64(1):55–61. doi: 10.1111/j.1398-9995.2008.01835.x. PMID: 2009005766. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19076545
Malka J, Covar R, Faino A, . The Effect of Viral Infection on Exhaled Nitric Oxide in Children with Acute Asthma Exacerbations. J Allergy Clin Immunol Pract. 2015 Nov–Dec;3(6):913–9. doi: 10.1016/j.jaip.2015.05.029. PMID: 26216254. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26216254
Mallol J, Aguirre V, Gallardo A, . Effect of once-daily generic ciclesonide on exhaled nitric oxide in atopic children with persistent asthma. Allergol Immunopathol (Madr). 2016 Mar–Apr;44(2):106–12. doi: 10.1016/j.aller.2015.01.011. PMID: 26001339. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26001339
Malmberg, L P, Pelkonen, . Exhaled nitric oxide rather than lung function distinguishes preschool children with probable asthma. Thorax. 2003 Jun;58(6):494–9. doi: 10.1136/thorax.58.6.494. PMID: 12775859. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12775859
Malmberg LP, Pelkonen AS, Malmstrom K, . Very low birth weight and respiratory outcome: association between airway inflammation and hyperresponsiveness. Annals of Allergy Asthma & Immunology. 2013 Aug;111(2):96–101. doi: 10.1016/j.anai.2013.06.004. PMID: WOS:000322932000005. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Malmberg LP, Saarinen KM, Pelkonen AS, . Cow’s milk allergy as a predictor of bronchial hyperresponsiveness and airway inflammation at school age. Clinical and Experimental Allergy. 2010 Oct;40(10):1491–7. doi: 10.1111/j.1365-2222.2010.03567.x. PMID: WOS:000281636000008. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)20618346
Malmberg LP, Turpeinen H, Rytila P, . Determinants of increased exhaled nitric oxide in patients with suspected asthma. Allergy. 2005 Apr;60(4):464–8. doi: 10.1111/j.1398-9995.2005.00740.x. PMID: 15727577. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15727577
Malmstrom K, Lohi J, Lindahl H, . Longitudinal follow-up of bronchial inflammation, respiratory symptoms, and pulmonary function in adolescents after repair of esophageal atresia with tracheoesophageal fistula. J Pediatr. 2008 Sep;153(3):396–401. doi: 10.1016/j.jpeds.2008.03.034. PMID: 18534205. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)18534205
Mandhane PJ, Hanna SE, Inman MD, . Changes in exhaled nitric oxide related to estrogen and progesterone during the menstrual cycle. Chest. 2009 Nov;136(5):1301–7. doi: 10.1378/chest.09-0604. PMID: 19617403. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19617403
Maniscalco M, Faraone S, Sofia M, . Extended analysis of exhaled and nasal nitric oxide for the evaluation of chronic cough. Respir Med. 2015 Aug;109(8):970–4. doi: 10.1016/j.rmed.2015.05.016. PMID: 26048083. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)26048083
Manoharan A, Lipworth BJ, Craig E, . The potential role of direct and indirect bronchial challenge testing to identify overtreatment of community managed asthma. Clin Exp Allergy. 2014 Oct;44(10):1240–5. doi: 10.1111/cea.12352. PMID: 24912796. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24912796
Manso L, Madero MF, Ruiz-Garcia M, . Comparison of bronchial hyperresponsiveness to methacholine and adenosine and airway inflammation markers in patients with suspected asthma. J Asthma. 2011 May;48(4):335–40. doi: 10.3109/02770903.2011.565850. PMID: 21504347. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21504347
Mappa L, Cardinale F, Camodeca R, . Exaled nitric oxide and air trapping correlation in asthmatic children. Allergy. 2005 Nov;60(11):1436–9. doi: 10.1111/j.1398-9995.2005.00905.x. PMID: 16197478. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16197478
Mar TF, Jansen K, Shepherd K, . Exhaled nitric oxide in children with asthma and short-term PM2.5 exposure in Seattle. Environ Health Perspect. 2005 Dec;113(12):1791–4. doi: 10.1289/ehp.7883. PMID: 16330366. The study does not have a comparison group (studies must have a comparison group or pre/post design)16330366
Marchand, D, Tayara, . Atopic dermatitis aggrevates the allergic airways inflammation in acute viral bronchiolitis. [French]. Revue des Maladies Respiratoires. 2008 November;25(9):1087–93. doi: 10.1016/S0761-8425(08)74978–7. PMID: 2009005783. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)19106904
Marsden PA, Satia I, Ibrahim B, . Objective Cough Frequency, Airway Inflammation, and Disease Control in Asthma. Chest. 2016 Jun;149(6):1460–6. doi: 10.1016/j.chest.2016.02.676. PMID: 26973014. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26973014
Martin N, Lindley MR, Hargadon B, . Airway dysfunction and inflammation in pool- and non-pool-based elite athletes. Med Sci Sports Exerc. 2012 Aug;44(8):1433–9. doi: 10.1249/MSS.0b013e31824c823c. PMID: 22297809. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22297809
Martineau AR, MacLaughlin BD, Hooper RL, . Double-blind randomised placebo-controlled trial of bolus-dose vitamin D3 supplementation in adults with asthma (ViDiAs). Thorax. 2015 May;70(5):451–7. doi: 10.1136/thoraxjnl-2014-206449. PMID: 25724847. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25724847
Martini A, Sbardella D, Bertini L, . Airway inflammation in professional divers: FeNO as a marker. Undersea Hyperb Med. 2012 Sep–Oct;39(5):901–7. PMID: 23045918. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23045918
Mascia K, Borish L, Patrie J, . Chronic hyperplastic eosinophilic sinusitis as a predictor of aspirin-exacerbated respiratory disease. Ann Allergy Asthma Immunol. 2005 Jun;94(6):652–7. doi: 10.1016/S1081-1206(10)61323-3. PMID: 15984597. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15984597
Massaro AF, Gaston B, Kita D, . Expired nitric oxide levels during treatment of acute asthma. Am J Respir Crit Care Med. 1995 Aug;152(2):800–3. doi: 10.1164/ajrccm.152.2.7633745. PMID: 7633745. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)7633745
Massimo T, Blank C, Strasser B, . Does climate therapy at moderate altitudes improve pulmonary function in asthma patients? A systematic review. Sleep Breath. 2014 Mar;18(1):195–206. doi: 10.1007/s11325-013-0870-z. PMID: 23775828. The study does not evaluate FeNO23775828
Matsumoto H, Niimi A, Jinnai M, . Association of alveolar nitric oxide levels with pulmonary function and its reversibility in stable asthma. Respiration. 2011 March;81(4):311–7. doi: 10.1159/000319566. PMID: 20938160. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20938160
Mattes J, Gravesande KS, Reining U, . NO in exhaled air is correlated with markers of eosinophilic airway inflammation in corticosteroid-dependent childhood asthma. European Respiratory Journal. 1999 Jun;13(6):1391–5. doi: Doi 10.1183/09031936.99.13613969. PMID: WOS:000081775800026. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10445617
Mattes J, Storm van’s Gravesande K, Moeller C, . Circadian variation of exhaled nitric oxide and urinary eosinophil protein X in asthmatic and healthy children. Pediatr Res. 2002 Feb;51(2):190–4. doi: 10.1203/00006450-200202000-00011. PMID: 11809913. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11809913
McDonald VM, Simpson JL, McElduff P, . Older peoples’ perception of tests used in the assessment and management of COPD and asthma. Clin Respir J. 2013 Oct;7(4):367–74. doi: 10.1111/crj.12017. PMID: 23509896. The study does not evaluate FeNO23509896
McGill C, Malik G, Turner SW. Validation of a hand-held exhaled nitric oxide analyzer for use in children. Pediatr Pulmonol. 2006 Nov;41(11):1053–7. doi: 10.1002/ppul.20491. PMID: 16871592. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16871592
McLachlan CR, Poulton R, Car G, . Adiposity, asthma, and airway inflammation. J Allergy Clin Immunol. 2007 Mar;119(3):634–9. doi: 10.1016/j.jaci.2006.10.029. PMID: 17141852. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17141852
McSharry CP, McKay IC, Chaudhuri R, . Short and long-term effects of cigarette smoking independently influence exhaled nitric oxide concentration in asthma. J Allergy Clin Immunol. 2005 Jul;116(1):88–93. doi: 10.1016/j.jaci.2005.03.025. PMID: 15990779. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15990779
Meena RK, Raj D, Lodha R, . Fractional Exhaled Nitric Oxide for Identification of Uncontrolled Asthma in Children. Indian Pediatr. 2016 Apr;53(4):307–10. doi: 10.1007/s13312-016-0842-z. PMID: 27156543. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)27156543
Mehta V, Stokes JR, Berro A, . Time-dependent effects of inhaled corticosteroids on lung function, bronchial hyperresponsiveness, and airway inflammation in asthma. Ann Allergy Asthma Immunol. 2009 Jul;103(1):31–7. doi: 10.1016/S1081-1206(10)60140-8. PMID: 19663124. The study does not have a comparison group (studies must have a comparison group or pre/post design)19663124
Melosini L, Dente FL, Bacci E, . Asthma control test (ACT): comparison with clinical, functional, and biological markers of asthma control. J Asthma. 2012 Apr;49(3):317–23. doi: 10.3109/02770903.2012.661008. PMID: 22401649. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22401649
Meltzer LJ, Faino A, Szefler SJ, . Experimentally manipulated sleep duration in adolescents with asthma: Feasibility and preliminary findings. Pediatr Pulmonol. 2015 Dec;50(12):1360–7. doi: 10.1002/ppul.23179. PMID: 25872769. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25872769
Michils, A, Malinovschi, . Different patterns of exhaled nitric oxide response to beta<inf>2</inf>-agonists in asthmatic patients according to the site of bronchodilation. Journal of Allergy and Clinical Immunology. 2016 01 Mar;137(3):806–12. doi: 10.1016/j.jaci.2015.09.054. PMID: 20151043078. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26688519
Miedinger D, Chhajed PN, Stolz D, . Reliability and validity of a German asthma quality of life questionnaire. Swiss Med Wkly. 2006 Feb 04;136(5–6):89–95. PMID: 16633952. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16633952
Mierzejewska, A, Jodlowska, . Usefulness of determining exhaled nitric oxide levels for the assessment of asthma severity in children. Pediatria i Medycyna Rodzinna. 2015;11(2):186–96. PMID: 2015287700. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Mikalsen, I B, Halvorsen, . Exhaled nitric oxide is related to atopy, but not asthma in adolescents with bronchiolitis in infancy. BMC Pulmonary Medicine. 2013 17 Nov;13 (1) (no pagination)(66)doi: 10.1186/1471-2466-13-66. PMID: 2013735187. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24237793
Millward D, Paul S, Brown M, . The diagnosis of asthma and exercise-induced bronchospasm in division I athletes. Clin J Sport Med. 2009 Nov;19(6):482–6. doi: 10.1097/JSM.0b013e3181bcde2c. PMID: 19898076. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)19898076
Mirabelli MC, Golan R, Greenwald R, . Modification of Traffic-related Respiratory Response by Asthma Control in a Population of Car Commuters. Epidemiology. 2015 Jul;26(4):546–55. doi: 10.1097/EDE.0000000000000296. PMID: 25901844. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25901844
Miraglia Del Giudice M, Decimo F, Maiello N, . Effectiveness of Ischia thermal water nasal aerosol in children with seasonal allergic rhinitis: a randomized and controlled study. Int J Immunopathol Pharmacol. 2011 Oct–Dec;24(4):1103–9. doi: 10.1177/039463201102400431. PMID: 22230419. The study does not evaluate FeNO22230419
Miraglia Del G, M, Maiello, . Airways allergic inflammation and L. reuterii treatment in asthmatic children. Journal of Biological Regulators and Homeostatic Agents. 2012;26(1 SUPPL):35S–40S. PMID: 2013111582. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23648197
Miric M, Turkalj M, Nogalo B, . Lung diffusion capacity in children with respiratory symptoms and untreated GERD. Med Sci Monit. 2014 May 12;20:774–81. doi: 10.12659/MSM.890336. PMID: 24816214. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)24816214
Mitsufuji H, Kobayashi H, Imasaki T, . Acute changes in bronchoconstriction influences exhaled nitric oxide level. Jpn J Physiol. 2001 Apr;51(2):151–7. doi: 10.2170/jjphysiol.51.151. PMID: 11405907. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11405907
Modig L, Dahgam S, Olsson D, . Short-term exposure to ozone and levels of exhaled nitric oxide. Epidemiology. 2014 Jan;25(1):79–87. doi: 10.1097/EDE.0000000000000002. PMID: 24213146. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24213146
Moeller A, Lehmann A, Knauer N, . Effects of montelukast on subjective and objective outcome measures in preschool asthmatic children. Pediatr Pulmonol. 2008 Feb;43(2):179–86. doi: 10.1002/ppul.20753. PMID: 18085698. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18085698
Mohsenin V. Airway responses to nitrogen dioxide in asthmatic subjects. J Toxicol Environ Health. 1987;22(4):371–80. doi: 10.1080/15287398709531080. PMID: 3320381. The study does not evaluate FeNO3320381
Mondino C, Ciabattoni G, Koch P, . Effects of inhaled corticosteroids on exhaled leukotrienes and prostanoids in asthmatic children. J Allergy Clin Immunol. 2004 Oct;114(4):761–7. doi: 10.1016/j.jaci.2004.06.054. PMID: 15480313. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15480313
Montuschi P, Santonico M, Mondino C, . Diagnostic performance of an electronic nose, fractional exhaled nitric oxide, and lung function testing in asthma. Chest. 2010 Apr;137(4):790–6. doi: 10.1378/chest.09-1836. PMID: 20081096. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20081096
Montuschi P, Martello S, Felli M, . Liquid chromatography/mass spectrometry analysis of exhaled leukotriene B4 in asthmatic children. Respir Res. 2005 Oct 19;6:119. doi: 10.1186/1465-9921-6-119. PMID: 16236169. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16236169
Montuschi P, Mondino C, Koch P, . Effects of a leukotriene receptor antagonist on exhaled leukotriene E4 and prostanoids in children with asthma. J Allergy Clin Immunol. 2006 Aug;118(2):347–53. doi: 10.1016/j.jaci.2006.04.010. PMID: 16890757. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16890757
Moreira A, Moreira P, Delgado L, . Pilot study of the effects of n-3 polyunsaturated fatty acids on exhaled nitric oxide in patients with stable asthma. J Investig Allergol Clin Immunol. 2007;17(5):309–13. PMID: 17982923. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17982923
Motomura C, Odajima H, Tezuka J, . Effect of age on relationship between exhaled nitric oxide and airway hyperresponsiveness in asthmatic children. Chest. 2009 Aug;136(2):519–25. doi: 10.1378/chest.08-2741. PMID: 19395581. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19395581
Munthe-Kaas MC, Lodrup Carlsen KC, Carlsen KH, . CFTR gene mutations and asthma in the Norwegian Environment and Childhood Asthma study. Respir Med. 2006 Dec;100(12):2121–8. doi: 10.1016/j.rmed.2006.03.026. PMID: 16678395. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16678395
Murphy VE, Jensen ME, Mattes J, . The Breathing for Life Trial: a randomised controlled trial of fractional exhaled nitric oxide (FENO)-based management of asthma during pregnancy and its impact on perinatal outcomes and infant and childhood respiratory health. BMC Pregnancy Childbirth. 2016 May 17;16(111):111. doi: 10.1186/s12884-016-0890-3. PMID: 27189595. The study is not original (commentaries, letters, etc. should be excluded)27189595
Murphy VE, Clifton VL, Gibson PG. The effect of cigarette smoking on asthma control during exacerbations in pregnant women. Thorax. 2010 Aug;65(8):739–44. doi: 10.1136/thx.2009.124941. PMID: 20627905. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20627905
Nadif R, Matran R, Maccario J, . Passive and active smoking and exhaled nitric oxide levels according to asthma and atopy in adults. Ann Allergy Asthma Immunol. 2010 May;104(5):385–93. doi: 10.1016/j.anai.2010.03.013. PMID: 20486328. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20486328
Nakano, C. Utility of MostGraph and fractional exhaled nitric oxide measurement in chronic cough. Journal of the Medical Society of Toho University. 2014;61(2):81–91. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)
Navratil M, Plavec D, Erceg D, . Urates in exhaled breath condensate as a biomarker of control in childhood asthma. Journal of Asthma. 2015 01 Jun;52(5):437–46. doi: 10.3109/02770903.2014.986740. PMID: WOS:000361339100001. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25387148
Ng SM, Li AM, Lou VW, . Incorporating family therapy into asthma group intervention: a randomized waitlist-controlled trial. Fam Process. 2008 Mar;47(1):115–30. doi: 10.1111/j.1545-5300.2008.00242.x. PMID: 18411833. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18411833
Nguyen TA, Woo-Park J, Hess M, . Assaying all of the nitrogen oxides in breath modifies the interpretation of exhaled nitric oxide. Vascul Pharmacol. 2005 Dec;43(6):379–84. doi: 10.1016/j.vph.2005.08.003. PMID: 16216561. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16216561
Nicolaou NC, Lowe LA, Murray CS, . Exhaled breath condensate pH and childhood asthma: unselected birth cohort study. Am J Respir Crit Care Med. 2006 Aug 01;174(3):254–9. doi: 10.1164/rccm.200601-140OC. PMID: 16675782. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16675782
Nicolini G, Chetta A, Simonazzi A, . Both bronchial and alveolar exhaled nitric oxide are reduced with extrafine beclomethasone dipropionate in asthma. Allergy and Asthma Proceedings. 2010 Sep–Oct;31(5):E85–E90. doi: 10.2500/aap.2010.31.3367. PMID: WOS:000209656400004. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Nightingale JA, Rogers DF, Barnes PJ. Effect of inhaled ozone on exhaled nitric oxide, pulmonary function, and induced sputum in normal and asthmatic subjects. Thorax. 1999 Dec;54(12):1061–9. doi: 10.1136/thx.54.12.1061. PMID: 10567624. Other reason10567624
Nikitina, L Y, Soodaeva, . The interaction between respiratory function and exhaled nitric oxide in exercise-induced bronchoconstriction in sportsmen. Sovremennye Tehnologii v Medicine. 2013;5(3):45–9. PMID: 2013656757. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)
Nordlund B, Konradsen JR, Pedroletti C, . The clinical benefit of evaluating health-related quality-of-life in children with problematic severe asthma. Acta Paediatr. 2011 Nov;100(11):1454–60. doi: 10.1111/j.1651-2227.2011.02359.x. PMID: 21595747. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21595747
Obata H, Dittrick M, Chan H, . Sputum eosinophils and exhaled nitric oxide during late asthmatic reaction in patients with western red cedar asthma. Eur Respir J. 1999 Mar;13(3):489–95. PMID: 10232414. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10232414
Oguma T, Niimi A, Hirai T, . Assessment of Small Airways with Computed Tomography: Mosaic Attenuation or Lung Density? Respiration. 2015;89(6):539–49. doi: 10.1159/000381553. PMID: 25924974. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25924974
Oh MA, Shim JY, Jung YH, . Fraction of exhaled nitric oxide and wheezing phenotypes in preschool children. Pediatr Pulmonol. 2013 Jun;48(6):563–70. doi: 10.1002/ppul.22705. PMID: 23129540. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23129540
Oh MJ, Lee JY, Lee BJ, . Exhaled nitric oxide measurement is useful for the exclusion of nonasthmatic eosinophilic bronchitis in patients with chronic cough. Chest. 2008 Nov;134(5):990–5. doi: 10.1378/chest.07-2541. PMID: 18583518. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)18583518
O’Hagan, A, Eid, . Loss ofasthmacontrol in pediatric patientsafter discontinuation of long-acting B-agonists. Annals of Allergy, Asthma and Immunology. 2011 November;1):A6. doi: 10.1155/2012/894063. PMID: 70579450. The study does not evaluate FeNO
Ohbayashi H, Setoguchi Y, Fukuchi Y, . Pharmacological effects of lysozyme on COPD and bronchial asthma with sputum: A randomized, placebo-controlled, small cohort, cross-over study. Pulm Pharmacol Ther. 2016 Apr;37:73–80. doi: 10.1016/j.pupt.2016.03.001. PMID: 26952317. Other reason26952317
Ohkura N, Fujimura M, Tokuda A, . Evaluation of airway hyperresponsiveness and exhaled nitric oxide as risk factors for airway remodeling in patients with stable asthma. Allergy Asthma Proc. 2009 Jul–Aug;30(4):419–23. doi: 10.2500/aap.2009.30.3253. PMID: 19772763. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19772763
Ojoo JC, Mulrennan SA, Kastelik JA, . Exhaled breath condensate pH and exhaled nitric oxide in allergic asthma and in cystic fibrosis. Thorax. 2005 Jan;60(1):22–6. doi: 10.1136/thx.2003.017327. PMID: 15618578. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15618578
Olin AC, Hellgren J, Karlsson G, . Nasal nitric oxide and its relationship to nasal symptoms, smoking and nasal nitrate. Rhinology. 1998 Sep;36(3):117–21. PMID: 9830675. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)9830675
Osthoff M, Michel F, Strupler M, . Bronchial hyperresponsiveness testing in athletes of the Swiss Paralympic team. BMC Sports Sci Med Rehabil. 2013 Apr 15;5(1):7. doi: 10.1186/2052-1847-5-7. PMID: 23845126. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23845126
Pacheco A, Faro V, Cobeta I, . Gastro-oesophageal reflux, eosinophilic airway inflammation and chronic cough. Respirology. 2011 Aug;16(6):994–9. doi: 10.1111/j.1440-1843.2011.02010.x. PMID: 21651646. Other reason21651646
Paiva, M, Martins, . Asthma control evaluation: Application of different methods. Revista Portuguesa de Imunoalergologia. 2010 May/June;18(3):227–41. PMID: 2011137942. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Pala G, Pignatti P, Moscato G. The use of fractional exhaled nitric oxide in investigation of work-related cough in a hairdresser. Am J Ind Med. 2011 Jul;54(7):565–8. doi: 10.1002/ajim.20948. PMID: 21394743. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)21394743
Panickar JR, Bhatnagar N, Grigg J. Exhaled nitric oxide after a single dose of intramuscular triamcinolone in children with difficult to control asthma. Pediatr Pulmonol. 2007 Jul;42(7):573–8. doi: 10.1002/ppul.20583. PMID: 17526005. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17526005
Paraskakis E, Brindicci C, Fleming L, . Measurement of bronchial and alveolar nitric oxide production in normal children and children with asthma. Am J Respir Crit Care Med. 2006 Aug 01;174(3):260–7. doi: 10.1164/rccm.200506-962OC. PMID: 16627868. The study does not have a comparison group (studies must have a comparison group or pre/post design)16627868
Paredi P, Kharitonov SA, Barnes PJ. Elevation of exhaled ethane concentration in asthma. Am J Respir Crit Care Med. 2000 Oct;162(4 Pt 1):1450–4. doi: 10.1164/ajrccm.162.4.2003064. PMID: 11029360. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11029360
Paredi P, Kharitonov SA, Loukides S, . Exhaled nitric oxide is increased in active fibrosing alveolitis. Chest. 1999 May;115(5):1352–6. doi: 10.1378/chest.115.5.1352. PMID: 10334152. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10334152
Paredi P, Loukides S, Ward S, . Exhalation flow and pressure-controlled reservoir collection of exhaled nitric oxide for remote and delayed analysis. Thorax. 1998 Sep;53(9):775–9. doi: 10.1136/thx.53.9.775. PMID: 10319060. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10319060
Pasha MA, Jourd’heuil D, Jourd’heuil F, . The effect of omalizumab on small airway inflammation as measured by exhaled nitric oxide in moderate-to-severe asthmatic patients. Allergy Asthma Proc. 2014 May–Jun;35(3):241–9. doi: 10.2500/aap.2014.35.3741. PMID: 24801467. The study does not evaluate FeNO24801467
Pasha MA, Smith TC, Feustel PJ, . Effects of low-dose fluticasone propionate/salmeterol combination therapy on exhaled nitric oxide and nitrite/nitrate in breath condensates from patients with mild persistent asthma. J Asthma. 2013 Feb;50(1):64–70. doi: 10.3109/02770903.2012.733467. PMID: 23098359. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23098359
Patelis A, Gunnbjornsdottir M, Alving K, . Allergen extract vs. component sensitization and airway inflammation, responsiveness and new-onset respiratory disease. Clin Exp Allergy. 2016 May;46(5):730–40. doi: 10.1111/cea.12607. PMID: 26243058. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26243058
Patelis A, Gunnbjornsdottir M, Malinovschi A, . Population-based study of multiplexed IgE sensitization in relation to asthma, exhaled nitric oxide, and bronchial responsiveness. J Allergy Clin Immunol. 2012 Aug;130(2):397–402 e2. doi: 10.1016/j.jaci.2012.03.046. PMID: 22633327. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22633327
Pavord ID, Jeffery PK, Qiu Y, . Airway inflammation in patients with asthma with high-fixed or low-fixed plus as-needed budesonide/formoterol. J Allergy Clin Immunol. 2009 May;123(5):1083–9, 9 e1–7. doi: 10.1016/j.jaci.2009.02.034. PMID: 19368965. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19368965
Payne DNR, Adcock IM, Wilson NM, . Relationship between exhaled nitric oxide and mucosal eosinophilic inflammation in children with difficult asthma, after treatment with oral prednisolone. American Journal of Respiratory and Critical Care Medicine. 2001 Oct 15;164(8):1376–81. doi: 10.1164/ajrccm.164.8.2101145. PMID: WOS:000172309700011. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11704581
Pedersen F, Holz O, Kanniess F, . Longitudinal measurement of airway inflammation over one year in children and adults with intermittent asthma. BMC Res Notes. 2014 Dec 17;7:925. doi: 10.1186/1756-0500-7-925. PMID: 25515668. The study does not evaluate FeNO25515668
Pedersen L, Lund TK, Barnes PJ, . Airway responsiveness and inflammation in adolescent elite swimmers. J Allergy Clin Immunol. 2008 Aug;122(2):322–7, 7 e1. doi: 10.1016/j.jaci.2008.04.041. PMID: 18554704. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)18554704
Pedroletti C, Millinger E, Dahlen B, . Clinical effects of purified air administered to the breathing zone in allergic asthma: A double-blind randomized cross-over trial. Respir Med. 2009 Sep;103(9):1313–9. doi: 10.1016/j.rmed.2009.03.020. PMID: 19443189. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19443189
Pedroletti C, Zetterquist W, Nordvall L, . Evaluation of exhaled nitric oxide in schoolchildren at different exhalation flow rates. Pediatric Research. 2002 Sep;52(3):393–8. doi: 10.1203/01.Pdr.0000025653.83839.77. PMID: WOS:000177577000015. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12193674
Pedrosa M, Barranco P, Lopez-Carrasco V, . Changes in exhaled nitric oxide levels after bronchial allergen challenge. Lung. 2012 Apr;190(2):209–14. doi: 10.1007/s00408-011-9358-4. PMID: 22228508. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22228508
Pelicaric, D, Petanjek, . Relationship between the exhaled nitric oxide and airway hyperresponsiveness in patients with asthma. [German]. Atemwegs- und Lungenkrankheiten. 2008 July;34(7):261–5. PMID: 2008387307. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Perez De L, L A, Carballada G, . Relationship between comorbidity and asthma control. [Spanish]. Archivos de Bronconeumologia. 2010 October;46(10):508–13. doi: 10.1016/S1579-2129(11)60003–7. PMID: 2010562365. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20638762
Peroni DG, Bodini A, Loiacono A, . Bioimpedance monitoring of airway inflammation in asthmatic allergic children. Allergol Immunopathol (Madr). 2009 Jan–Feb;37(1):3–6. doi: 10.1016/S0301-0546(09)70243–5. PMID: 19268053. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19268053
Peroni D, Bodini A, Miraglia Del Giudice M, . Effect of budesonide and montelukast in asthmatic children exposed to relevant allergens. Allergy. 2005 Feb;60(2):206–10. doi: 10.1111/j.1398-9995.2005.00670.x. PMID: 15647042. Other reason15647042
Peroni DG, Piacentini GL, Bodini A, . Montelukast versus formoterol as second-line therapy in asthmatic children exposed to relevant allergens. Allergy Asthma Proc. 2005 Jul–Aug;26(4):283–6. PMID: 16270721. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16270721
Perzanowski, M S, Divjan, . Pediatric - Exhaled NO among inner-city children in New York City. Journal of Asthma. 2010 November;47(9):1015–21. doi: 10.3109/02770903.2010.513075. PMID: 2010618213. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20936992
Petrovic, S, Zivanovic, . Influence of Atopy and diff Erent treatments of asthma on fractional concentration of exhaled nitric oxide in children. Paediatria Croatica. 2013 July–September;57(3):221–6. PMID: 2013664910. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Petsky HL, Cates CJ, Li A, . Tailored interventions based on exhaled nitric oxide versus clinical symptoms for asthma in children and adults. Cochrane Database Syst Rev. 2009 Oct 07(4):CD006340. doi: 10.1002/14651858.CD006340.pub3. PMID: 19821360. This is a systematic review/meta-analysis/guideline19821360
Piacentini GL, Bodini A, Costella S, . Exhaled nitric oxide in asthmatic children exposed to relevant allergens: effect of flunisolide. Eur Respir J. 2000 Apr;15(4):730–4. doi: 10.1034/j.1399-3003.2000.15d17.x. PMID: 10780766. The study does not evaluate FeNO10780766
Piacentini GL, Bodini A, Peroni DG, . Reduction in exhaled nitric oxide immediately after methacholine challenge in asthmatic children. Thorax. 2002 Sep;57(9):771–3. doi: 10.1136/thorax.57.9.771. PMID: 12200520. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12200520
Piacentini GL, Peroni DG, Bodini A, . Childhood Asthma Control Test and airway inflammation evaluation in asthmatic children. Allergy. 2009 Dec;64(12):1753–7. doi: 10.1111/j.1398-9995.2009.02068.x. PMID: 19712122. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19712122
Pietropaoli AP, Frampton MW, Hyde RW, . Pulmonary function, diffusing capacity, and inflammation in healthy and asthmatic subjects exposed to ultrafine particles. Inhal Toxicol. 2004;16 Suppl 1:59–72. doi: 10.1080/08958370490443079. PMID: 15204794. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15204794
Pifferi M, Bush A, Pioggia G, . Monitoring asthma control in children with allergies by soft computing of lung function and exhaled nitric oxide. Chest. 2011 Feb;139(2):319–27. doi: 10.1378/chest.10-0992. PMID: 20930008. The study does not evaluate FeNO20930008
Piipari R, Piirila P, Keskinen H, . Exhaled nitric oxide in specific challenge tests to assess occupational asthma. Eur Respir J. 2002 Dec;20(6):1532–7. doi: 10.1183/09031936.02.00041802. PMID: 12503715. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12503715
Pijnenburg MW, Floor SE, Hop WC, . Daily ambulatory exhaled nitric oxide measurements in asthma. Pediatr Allergy Immunol. 2006 May;17(3):189–93. doi: 10.1111/j.1399-3038.2006.00394.x. PMID: 16672005. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16672005
Pike KC, Inskip HM, Robinson SM, . The relationship between maternal adiposity and infant weight gain, and childhood wheeze and atopy. Thorax. 2013 Apr;68(4):372–9. doi: 10.1136/thoraxjnl-2012-202556. PMID: WOS:000315950400013. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23291350
Pisi R, Aiello M, Tzani P, . Measurement of fractional exhaled nitric oxide by a new portable device: comparison with the standard technique. J Asthma. 2010 Sep;47(7):805–9. doi: 10.3109/02770903.2010.485667. PMID: 20670207. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20670207
Pisi R, Aiello M, Tzani P, . Overweight is associated with airflow obstruction and poor disease control but not with exhaled nitric oxide change in an asthmatic population. Respiration. 2012;84(5):416–22. doi: 10.1159/000340038. PMID: 22986286. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22986286
Pizzimenti S, Bugiani M, Piccioni P, . Exhaled nitric oxide measurements: correction equation to compare hand-held device to stationary analyzer. Respir Med. 2008 Sep;102(9):1272–5. doi: 10.1016/j.rmed.2008.04.006. PMID: 18586480. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18586480
Polychronakis I, Thanasias E, Raulf-Heimsoth M, . Occupational non-immediate type allergic asthma due to ammonium persulfate. Adv Exp Med Biol. 2013;755:79–84. doi: 10.1007/978-94-007-4546-9_10. PMID: 22826052. The study does not have a comparison group (studies must have a comparison group or pre/post design)22826052
Poorisrisak P, Halkjaer LB, Thomsen SF, . Causal direction between respiratory syncytial virus bronchiolitis and asthma studied in monozygotic twins. Chest. 2010 Aug;138(2):338–44. doi: 10.1378/chest.10-0365. PMID: 20435661. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)20435661
Porsbjerg C, Sverrild A, Stensen L, . The level of specialist assessment of adult asthma is influenced by patient age. Respir Med. 2014 Oct;108(10):1453–9. doi: 10.1016/j.rmed.2014.07.005. PMID: 25087903. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25087903
Porsbjerg C, Sverrild A, Backer V. Combining the Mannitol Test and FeNO in the Assessment of Poorly Controlled Asthma. J Allergy Clin Immunol Pract. 2015 Jul–Aug;3(4):553–9. doi: 10.1016/j.jaip.2015.02.005. PMID: 25824441. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25824441
Powell H, McCaffery K, Murphy VE, . Psychosocial variables are related to future exacerbation risk and perinatal outcomes in pregnant women with asthma. J Asthma. 2013 May;50(4):383–9. doi: 10.3109/02770903.2012.757777. PMID: 23368420. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23368420
Powell H, Murphy VE, Hensley MJ, . Rhinitis in pregnant women with asthma is associated with poorer asthma control and quality of life. J Asthma. 2015;52(10):1023–30. doi: 10.3109/02770903.2015.1054403. PMID: 26365758. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26365758
Prasad A, Langford B, Stradling JR, . Exhaled nitric oxide as a screening tool for asthma in school children. Respiratory Medicine. 2006 Jan;100(1):167–73. doi: 10.1016/j.rmed.2005.03.039. PMID: WOS:000234588400023. The study does not have a comparison group (studies must have a comparison group or pre/post design)15885997
Prieto L, Gutierrez V, Uixera S, . Concentrations of exhaled nitric oxide in asthmatics and subjects with allergic rhinitis sensitized to the same pollen allergen. Clin Exp Allergy. 2002 Dec;32(12):1728–33. doi: 10.1046/j.1365-2222.2002.01546.x. PMID: 12653163. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12653163
Prieto L, Palop J, Llusar R, . Effects of cigarette smoke on methacholine- and AMP-induced air trapping in asthmatics. J Asthma. 2015 Feb;52(1):26–33. doi: 10.3109/02770903.2014.944981. PMID: 25019351. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25019351
Prieto L, Seijas T, Gutierrez V, . Exhaled nitric oxide levels and airway responsiveness to adenosine 5′-monophosphate in subjects with nasal polyposis. Int Arch Allergy Immunol. 2004 Aug;134(4):303–9. doi: 10.1159/000079168. PMID: 15205562. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15205562
Prieto L, Esnal S, Lopez V, . Maximal response plateau to adenosine 5′-monophosphate in asthma. Relationship with the response to methacholine, exhaled nitric oxide, and exhaled breath condensate pH. Chest. 2009 Jun;135(6):1521–6. doi: 10.1378/chest.08-2392. PMID: 19225062. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19225062
Prieto L, Gutierrez V, Perez-Frances C, . Effect of fluticasone propionate-salmeterol therapy on seasonal changes in airway responsiveness and exhaled nitric oxide levels in patients with pollen-induced asthma. Ann Allergy Asthma Immunol. 2005 Nov;95(5):452–61. doi: 10.1016/S1081-1206(10)61171-4. PMID: 16312168. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16312168
Prieto L, Gutierrez V, Torres V, . Effect of salmeterol on seasonal changes in airway responsiveness and exhaled nitric oxide in pollen-sensitive asthmatic subjects. Chest. 2002 Sep;122(3):798–805. doi: 10.1378/chest.122.3.798. PMID: 12226016. Other reason12226016
Prieto L, Gutierrez V, Uixera S. Exhaled nitric oxide and bronchial responsiveness to adenosine 5′-monophosphate in subjects with allergic rhinitis. Chest. 2002 Jun;121(6):1853–9. doi: 10.1378/chest.121.6.1853. PMID: 12065349. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)12065349
Prieto L, Ruiz-Jimenez L, Marin J. The effect of spirometry on bronchial and alveolar nitric oxide in subjects with asthma. J Asthma. 2013 Aug;50(6):623–8. doi: 10.3109/02770903.2013.790418. PMID: 23544793. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23544793
Puckett JL, Taylor RW, Leu SY, . An elevated bronchodilator response predicts large airway inflammation in mild asthma. Pediatr Pulmonol. 2010 Feb;45(2):174–81. doi: 10.1002/ppul.21172. PMID: 20082343. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20082343
Puckett JL, Taylor RW, Leu SY, . Clinical patterns in asthma based on proximal and distal airway nitric oxide categories. Respir Res. 2010 Apr 28;11:47. doi: 10.1186/1465-9921-11-47. PMID: 20426813. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20426813
Puckett JL, Taylor RW, Galant SP, . Impact of analysis interval on the multiple exhalation flow technique to partition exhaled nitric oxide. Pediatr Pulmonol. 2010 Feb;45(2):182–91. doi: 10.1002/ppul.21182. PMID: 20082344. The study does not have a comparison group (studies must have a comparison group or pre/post design)20082344
Purokivi M, Koskela H, Kontra K. Determinants of asthma control and quality of life in stable asthma: evaluation of two new cough provocation tests. Clin Respir J. 2013 Jul;7(3):253–60. doi: 10.1111/j.1752-699X.2012.00313.x. PMID: 22822927. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22822927
Pyle RC, Divekar R, May SM, . Asthma-associated comorbidities in children with and without secondhand smoke exposure. Ann Allergy Asthma Immunol. 2015 Sep;115(3):205–10. doi: 10.1016/j.anai.2015.06.027. PMID: 26208757. The study does not evaluate FeNO26208757
Rabinovitch N, Reisdorph N, Silveira L, . Urinary leukotriene E(4) levels identify children with tobacco smoke exposure at risk for asthma exacerbation. J Allergy Clin Immunol. 2011 Aug;128(2):323–7. doi: 10.1016/j.jaci.2011.05.035. PMID: 21807251. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21807251
Rabinovitch N, Strand M, Stuhlman K, . Exposure to tobacco smoke increases leukotriene E4-related albuterol usage and response to montelukast. J Allergy Clin Immunol. 2008 Jun;121(6):1365–71. doi: 10.1016/j.jaci.2008.03.016. PMID: 18439662. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18439662
Radulovic M, Schilero GJ, Wecht JM, . Exhaled nitric oxide levels are elevated in persons with tetraplegia and comparable to that in mild asthmatics. Lung. 2010 Jun;188(3):259–62. doi: 10.1007/s00408-009-9207-x. PMID: 20012982. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20012982
Ragab S, Scadding GK, Lund VJ, . Treatment of chronic rhinosinusitis and its effects on asthma. Eur Respir J. 2006 Jul;28(1):68–74. doi: 10.1183/09031936.06.00043305. PMID: 16510462. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16510462
Raissy HH, Harkins M, Esparham A, . Comparison of the dose response to levalbuterol with and without pretreatment with S-albuterol after methacholine-induced bronchoconstriction. Pharmacotherapy. 2007 Sep;27(9):1231–6. doi: 10.1592/phco.27.9.1231. PMID: 17723076. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17723076
Raj D, Lodha R, Pandey A, . Aeroallergen sensitization in childhood asthmatics in northern India. Indian Pediatr. 2013 Dec;50(12):1113–8. doi: 10.1007/s13312-013-0304-9. PMID: 23999673. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23999673
Ratnawati, Morton J, Henry RL, . Exhaled breath condensate nitrite/nitrate and pH in relation to pediatric asthma control and exhaled nitric oxide. Pediatr Pulmonol. 2006 Oct;41(10):929–36. doi: 10.1002/ppul.20469. PMID: 16871619. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16871619
Raulf-Heimsoth M, van Kampen V, Heinze E, . Comparison of Different Non-invasive Methods for Detection of Allergic Asthma. Respiratory Regulation - Clinical Advances. 2013;755(755):55–63. doi: 10.1007/978-94-007-4546-9_7. PMID: WOS:000333329100008. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Ravensberg AJ, Luijk B, Westers P, . The effect of a single inhaled dose of a VLA-4 antagonist on allergen-induced airway responses and airway inflammation in patients with asthma. Allergy. 2006 Sep;61(9):1097–103. doi: 10.1111/j.1398-9995.2006.01146.x. PMID: 16918513. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16918513
Reddel HK, Belousova EG, Marks GB, . Does continuous use of inhaled corticosteroids improve outcomes in mild asthma? A double-blind randomised controlled trial. Prim Care Respir J. 2008 Mar;17(1):39–45. doi: 10.3132/pcrj.2008.00014. PMID: 18322633. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18322633
Riddervold IS, Bonlokke JH, Olin AC, . Effects of wood smoke particles from wood-burning stoves on the respiratory health of atopic humans. Part Fibre Toxicol. 2012 Apr 30;9(12):12. doi: 10.1186/1743-8977-9-12. PMID: 22546175. The study does not have patients of interest (suspected to have asthma, have wheezing, 0-4 years old who may develop asthma in the future)22546175
Ritz T, Kullowatz A, Bill MN, . Daily life negative mood and exhaled nitric oxide in asthma. Biol Psychol. 2016 Jul;118:176–83. doi: 10.1016/j.biopsycho.2016.06.001. PMID: 27283368. The study does not evaluate FeNO27283368
Ritz T, Rosenfield D, Steele AM, . Controlling asthma by training of Capnometry-Assisted Hypoventilation (CATCH) vs slow breathing: a randomized controlled trial. Chest. 2014 Nov;146(5):1237–47. doi: 10.1378/chest.14-0665. PMID: 25122497. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25122497
Ritz T, Trueba AF, Liu J, . Exhaled Nitric Oxide Decreases during Academic Examination Stress in Asthma. Ann Am Thorac Soc. 2015 Nov;12(11):1638–45. doi: 10.1513/AnnalsATS.201504-213OC. PMID: 26348209. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26348209
Ritz T, Trueba AF, Simon E, . Increases in exhaled nitric oxide after acute stress: association with measures of negative affect and depressive mood. Psychosom Med. 2014 Nov–Dec;76(9):716–25. doi: 10.1097/PSY.0000000000000118. PMID: 25353641. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25353641
Ritz T, Kullowatz A, Goldman MD, . Airway response to emotional stimuli in asthma: the role of the cholinergic pathway. J Appl Physiol (1985). 2010 Jun;108(6):1542–9. doi: 10.1152/japplphysiol.00818.2009. PMID: 20360438. The study does not evaluate FeNO20360438
Roberts G, Hurley C, Bush A, . Longitudinal study of grass pollen exposure, symptoms, and exhaled nitric oxide in childhood seasonal allergic asthma. Thorax. 2004 Sep;59(9):752–6. doi: 10.1136/thx.2003.008722. PMID: 15333850. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15333850
Roberts G, Hurley C, Turcanu V, . Grass pollen immunotherapy as an effective therapy for childhood seasonal allergic asthma. J Allergy Clin Immunol. 2006 Feb;117(2):263–8. doi: 10.1016/j.jaci.2005.09.054. PMID: 16461125. Other reason16461125
Robinson CL, Baumann LM, Romero K, . Effect of urbanisation on asthma, allergy and airways inflammation in a developing country setting. Thorax. 2011 Dec;66(12):1051–7. doi: 10.1136/thx.2011.158956. PMID: 21730351. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21730351
Robroeks CM, van Vliet D, Jobsis Q, . Prediction of asthma exacerbations in children: results of a one-year prospective study. Clin Exp Allergy. 2012 May;42(5):792–8. doi: 10.1111/j.1365-2222.2012.03992.x. PMID: 22515395. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22515395
Robroeks CM, van Vliet D, Hendriks HJ, . Feasibility of exhaled nitric oxide measurements at various flow rates in children with asthma. Pediatr Allergy Immunol. 2010 Feb;21(1 Pt 2):e222–8. doi: 10.1111/j.1399-3038.2009.00874.x. PMID: 21083853. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21083853
Rodrigo GJ, Castro-Rodriguez JA. Daily vs. intermittent inhaled corticosteroids for recurrent wheezing and mild persistent asthma: a systematic review with meta-analysis. Respir Med. 2013 Aug;107(8):1133–40. doi: 10.1016/j.rmed.2013.05.005. PMID: 23769720. The study does not have a comparison group (studies must have a comparison group or pre/post design)23769720
Rolla G, Guida G, Heffler E, . Diagnostic classification of persistent rhinitis and its relationship to exhaled nitric oxide and asthma: a clinical study of a consecutive series of patients. Chest. 2007 May;131(5):1345–52. doi: 10.1378/chest.06-2618. PMID: 17317733. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)17317733
Romberg K, Tufvesson E, Bjermer L. Asthma symptoms, mannitol reactivity and exercise-induced bronchoconstriction in young athletes. Allergy. 2015 Sep;70(no pagination):646-. doi: 10.1183/13993003.congress-2015.PA2284. PMID: WOS:000369950703325. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)
Rosa MJ, Divjan A, Hoepner L, . Fractional Exhaled Nitric Oxide Exchange Parameters Among 9-Year-Old Inner-City Children. Pediatric Pulmonology. 2011 Jan;46(1):83–91. doi: 10.1002/ppul.21328. PMID: WOS:000285846400010. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)20848585
Rosewich M, Rose MA, Eickmeier O, . Montelukast as add-on therapy to beta-agonists and late airway response. Eur Respir J. 2007 Jul;30(1):56–61. doi: 10.1183/09031936.00063106. PMID: 17301091. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17301091
Ross JA, Yang Y, Song PX, . Quality of life, health care utilization, and control in older adults with asthma. J Allergy Clin Immunol Pract. 2013 Mar;1(2):157–62. doi: 10.1016/j.jaip.2012.12.003. PMID: 24565454. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24565454
Rossall M, Cadden P, Kolsum U, . A comparison of the clinical and induced sputum characteristics of early- and late-onset asthma. Lung. 2012 Aug;190(4):459–62. doi: 10.1007/s00408-012-9383-y. PMID: 22484716. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22484716
Rouhos A, Ekroos H, Karjalainen J, . Exhaled nitric oxide and exercise-induced bronchoconstriction in young male conscripts: association only in atopics. Allergy. 2005 Dec;60(12):1493–8. doi: 10.1111/j.1398-9995.2005.00901.x. PMID: 16266380. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16266380
Rouhos A, Ekroos H, Karjalainen J, . Smoking attenuates increase in exhaled nitric oxide in atopic but not in nonatopic young adults with asthma. Int Arch Allergy Immunol. 2010;152(3):226–32. doi: 10.1159/000283029. PMID: 20150740. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20150740
Rouhos A, Kainu A, Karjalainen J, . Atopic sensitization to common allergens without symptoms or signs of airway disorders does not increase exhaled nitric oxide. Clin Respir J. 2008 Jul;2(3):141–8. doi: 10.1111/j.1752-699X.2007.00045.x. PMID: 20298322. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20298322
Rouhos A, Kainu A, Piirila P, . Repeatability of exhaled nitric oxide measurements in patients with COPD. Clin Physiol Funct Imaging. 2011 Jan;31(1):26–31. doi: 10.1111/j.1475-097X.2010.00975.x. PMID: 21143751. Other reason21143751
Rueda E, S, Nievas S, . Exhaled nitric oxide in asthmatic children treated with inhaled corticosteroids. Acta Pediatrica Espanola. 2005;63(3):105–10. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Rutgers SR, Meijer RJ, Kerstjens HA, . Nitric oxide measured with single-breath and tidal-breathing methods in asthma and COPD. Eur Respir J. 1998 Oct;12(4):816–9. doi: 10.1183/09031936.98.12040816. PMID: 9817151. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9817151
Sachs-Olsen C, Sanak M, Lang AM, . Eoxins: A new inflammatory pathway in childhood asthma. Journal of Allergy and Clinical Immunology. 2010 Oct;126(4):859–U304. doi: 10.1016/j.jaci.2010.07.015. PMID: WOS:000282510000026. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20920774
Saito J, Fukuhara A, Sato Y, . [Differences of fractional exhaled nitric oxide (FeNO) levels performed using two different analyzers]. Nihon Kokyuki Gakkai Zasshi. 2010 Jan;48(1):17–22. PMID: 20163016. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20163016
Saito J, Gibeon D, Macedo P, . Domiciliary diurnal variation of exhaled nitric oxide fraction for asthma control. Eur Respir J. 2014 Feb;43(2):474–84. doi: 10.1183/09031936.00048513. PMID: 23949962. The study does not have a comparison group (studies must have a comparison group or pre/post design)23949962
Saito J, Sato S, Fukuhara A, . Association of asthma education with asthma control evaluated by asthma control test, FEV1, and fractional exhaled nitric oxide. J Asthma. 2013 Feb;50(1):97–102. doi: 10.3109/02770903.2012.741638. PMID: 23163920. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23163920
Sakwari G, Mamuya SH, Bratveit M, . Respiratory symptoms, exhaled nitric oxide, and lung function among workers in Tanzanian coffee factories. J Occup Environ Med. 2013 May;55(5):544–51. doi: 10.1097/JOM.0b013e318285f453. PMID: 23618889. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23618889
Saleh D, Ernst P, Lim S, . Increased formation of the potent oxidant peroxynitrite in the airways of asthmatic patients is associated with induction of nitric oxide synthase: effect of inhaled glucocorticoid. FASEB J. 1998 Aug;12(11):929–37. PMID: 9707165. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9707165
Sandrini A, Ferreira IM, Jardim JR, . Effect of nasal triamcinolone acetonide on lower airway inflammatory markers in patients with allergic rhinitis. J Allergy Clin Immunol. 2003 Feb;111(2):313–20. doi: 10.1067/mai.2003.64. PMID: 12589351. The study does not have a comparison group (studies must have a comparison group or pre/post design)12589351
Santos, A, Faria, . Parameters for monitoring severe asthma - A prospective study. [Portuguese, English]. Revista Portuguesa de Imunoalergologia. 2009 March–April;17(2):135–53. PMID: 2010071285. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Sardon Prado O, Aldasoro Ruiz A, Korta Murua J, . [Agreement between two devices for measuring exhaled nitric oxide]. An Pediatr (Barc). 2007 Dec;67(6):572–7. doi: 10.1016/S1695-4033(07)70806-8. PMID: 18053523. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18053523
Sardon-Prado O, Korta-Murua J, Valverde-Molina J, . Association among lung function, exhaled nitric oxide, and the CAN questionnaire to assess asthma control in children. Pediatr Pulmonol. 2010 May;45(5):434–9. doi: 10.1002/ppul.21144. PMID: 20425850. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20425850
Sardon O, Corcuera P, Aldasoro A, . Alveolar nitric oxide and its role in pediatric asthma control assessment. BMC Pulm Med. 2014 Aug 04;14:126. doi: 10.1186/1471-2466-14-126. PMID: 25090994. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25090994
Sastre J, Costa C, del Garcia Potro M, . Changes in exhaled nitric oxide after inhalation challenge with occupational agents. J Investig Allergol Clin Immunol. 2013;23(6):421–7. PMID: 24459819. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24459819
Sastre J, Madero MF, Fernandez-Nieto M, . Airway response to chlorine inhalation (bleach) among cleaning workers with and without bronchial hyperresponsiveness. Am J Ind Med. 2011 Apr;54(4):293–9. doi: 10.1002/ajim.20912. PMID: 20957677. The study does not have a comparison group (studies must have a comparison group or pre/post design)20957677
Satouchi M, Maeda H, Yu Y, . Clinical significance of the increased peak levels of exhaled nitric oxide in patients with bronchial asthma. Intern Med. 1996 Apr;35(4):270–5. doi: 10.2169/internalmedicine.35.270. PMID: 8739780. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)8739780
Sayao LB, de Britto MCA, Burity E, . Exhaled nitric oxide as a diagnostic tool for wheezing in preschool children: A diagnostic accuracy study. Respiratory Medicine. 2016 Apr;113:15–21. doi: 10.1016/j.rmed.2016.02.008. PMID: WOS:000373085700003. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)27021575
Schatz M, Zeiger RS, Zhang F, . Development and preliminary validation of the Asthma Intensity Manifestations Score (AIMS) derived from Asthma Control Test, FEV(1), fractional exhaled nitric oxide, and step therapy assessments. J Asthma. 2012 Mar;49(2):172–7. doi: 10.3109/02770903.2011.654024. PMID: 22304003. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22304003
Schildge J. [Nitric oxide in exhaled breath of patients with interstitial lung diseases]. Pneumologie. 2011 Mar;65(3):143–8. doi: 10.1055/s-0030-1255958. PMID: 21117021. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)21117021
Schulze J, Reinmuller W, Herrmann E, . Bronchial allergen challenges in children - safety and predictors. Pediatr Allergy Immunol. 2013 Feb;24(1):19–27. doi: 10.1111/pai.12031. PMID: 23331526. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23331526
Schulze J, Rosewich M, Dressler M, . Bronchial allergen challenge using the Medicaid dosimeter. Int Arch Allergy Immunol. 2012;157(1):89–97. doi: 10.1159/000324473. PMID: 21912178. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)21912178
Schulze J, Voss S, Zissler U, . Airway responses and inflammation in subjects with asthma after four days of repeated high-single-dose allergen challenge. Respir Res. 2012 Sep 19;13:78. doi: 10.1186/1465-9921-13-78. PMID: 22989372. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22989372
Scichilone N, Battaglia S, Taormina S, . Alveolar nitric oxide and asthma control in mild untreated asthma. J Allergy Clin Immunol. 2013 Jun;131(6):1513–7. doi: 10.1016/j.jaci.2013.03.009. PMID: 23639306. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23639306
Scichilone N, Scalici V, Arrigo R, . Clinical and anti-inflammatory effects of ultra-short preseasonal vaccine to Parietaria in asthma. Ther Adv Respir Dis. 2013 Aug;7(4):207–15. doi: 10.1177/1753465813476564. PMID: 23423770. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23423770
Scott S, Currie J, Albert P, . Risk of misdiagnosis, health-related quality of life, and BMI in patients who are overweight with doctor-diagnosed asthma. Chest. 2012 Mar;141(3):616–24. doi: 10.1378/chest.11-0948. PMID: 21868466. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21868466
Sekiya K, Taniguchi M, Fukutomi Y, . Actual control state of intermittent asthma classified on the basis of subjective symptoms. Intern Med. 2011;50(15):1545–51. doi: 10.2169/internalmedicine.50.5003. PMID: 21804279. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21804279
Sekkal S, Haddam N, Scheers H, . Occupational exposure to petroleum products and respiratory health: a cross-sectional study from Algeria. J Occup Environ Med. 2012 Nov;54(11):1382–8. doi: 10.1097/JOM.0b013e31825fa6c9. PMID: 23047657. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23047657
Selby A, Clayton B, Grundy J, . Are exhaled nitric oxide measurements using the portable NIOX MINO repeatable? Respir Res. 2010 Apr 23;11:43. doi: 10.1186/1465-9921-11-43. PMID: 20416092. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20416092
Senkerik, M, Chladkova, . Noninvasive monitoring of airway inflammation in children with allergic rhinitis and asthma: Validation of two methods for measurement of the alveolar concentration and bronchial flux of nitric oxide. [Czech]. Alergie. 2011;13(1):25–30. PMID: 2011230565. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Šenkeřík, M, Chládková, . Noninvasive monitoring of airway inflammation in children with allergic rhinitis and asthma: Validation of two methods for measurement of the alveolar concentration and bronchial flux of nitric oxide. Alergie. 2011;13(1):25–30. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Serrano CD, Valero A, Bartra J, . Nasal and Bronchial Inflammation After Nasal Allergen Challenge: Assessment Using Noninvasive Methods. Journal of Investigational Allergology and Clinical Immunology. 2012;22(5):351–6. PMID: WOS:000309617800005. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23101310
Sethi JM, White AM, Patel SA, . Bronchoprovocation testing in asthma: effect on exhaled monoxides. J Breath Res. 2010 Dec;4(4):047104. doi: 10.1088/1752-7155/4/4/047104. PMID: 21383491. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21383491
Sexton P, Black P, Wu L, . Chronic obstructive pulmonary disease in non-smokers: a case-comparison study. COPD. 2014 Feb;11(1):2–9. doi: 10.3109/15412555.2013.800853. PMID: 23844977. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23844977
Sexton P, Black P, Wu L, . Fixed airflow obstruction among nonsmokers with asthma:a case-comparison study. J Asthma. 2013 Aug;50(6):606–12. doi: 10.3109/02770903.2013.793706. PMID: 23574362. The study does not have a comparison group (studies must have a comparison group or pre/post design)23574362
Sfaxi I, Ben Saad H, Rouatbi S. Fraction of exhaled nitric oxide in healthy elderly Tunisian subjects. Nitric Oxide. 2015 Sep 05;50:88–97. doi: 10.1016/j.niox.2015.08.008. PMID: 26344327. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26344327
Shahid SK, Kharitonov SA, Wilson NM, . Exhaled 8-isoprostane in childhood asthma. Respir Res. 2005 Jul 21;6:79. doi: 10.1186/1465-9921-6-79. PMID: 16042771. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16042771
Shimizu H, Obase Y, Ikeda M, . Stability of sealed-bag samples for off-line measurement of fractional exhaled nitric oxide. Ann Allergy Asthma Immunol. 2011 May;106(5):378–80. doi: 10.1016/j.anai.2011.01.010. PMID: 21530868. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21530868
Shimoda, T, Obase, . A study of the usefulness of anti-inflammatory treatment for mild intermittent asthma (step 1): Budesonide vs. Montelukast. Allergology International. 2005;54(1):123–30. doi: 10.2332/allergolint.54.123. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Shin HW, Rose-Gottron CM, Cooper DM, . Airway diffusing capacity of nitric oxide and steroid therapy in asthma. J Appl Physiol (1985). 2004 Jan;96(1):65–75. doi: 10.1152/japplphysiol.00575.2003. PMID: 12959957. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)12959957
Shin HW, Schwindt CD, Aledia AS, . Exercise-induced bronchoconstriction alters airway nitric oxide exchange in a pattern distinct from spirometry. Am J Physiol Regul Integr Comp Physiol. 2006 Dec;291(6):R1741–8. doi: 10.1152/ajpregu.00178.2006. PMID: 16840654. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16840654
Shirai T, Mori K, Mikamo M, . Respiratory mechanics and peripheral airway inflammation and dysfunction in asthma. Clin Exp Allergy. 2013 May;43(5):521–6. doi: 10.1111/cea.12083. PMID: 23600542. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23600542
Shiryaeva O, Aasmoe L, Straume B, . An analysis of the respiratory health status among seafarers in the Russian trawler and merchant fleets. Am J Ind Med. 2011 Dec;54(12):971–9. doi: 10.1002/ajim.20978. PMID: 21692095. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)21692095
Short PM, Lipworth SIW, Lipworth BJ. Relationships Between Airway Hyperresponsiveness, Inflammation, and Calibre in Asthma. Lung. 2011 Dec;189(6):493–7. doi: 10.1007/s00408-011-9328-x. PMID: WOS:000297350000008. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21984113
Shorter JH, Nelson DD, McManus JB, . Clinical study of multiple breath biomarkers of asthma and COPD (NO, CO(2), CO and N(2)O) by infrared laser spectroscopy. J Breath Res. 2011 Sep;5(3):037108. doi: 10.1088/1752-7155/5/3/037108. PMID: 21757803. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21757803
Silkoff PE, McClean PA, Slutsky AS, . Exhaled nitric oxide and bronchial reactivity during and after inhaled beclomethasone in mild asthma. J Asthma. 1998;35(6):473–9. doi: 10.3109/02770909809071000. PMID: 9751064. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9751064
Silkoff PE, Wakita S, Chatkin J, . Exhaled nitric oxide after beta2-agonist inhalation and spirometry in asthma. Am J Respir Crit Care Med. 1999 Mar;159(3):940–4. doi: 10.1164/ajrccm.159.3.9805044. PMID: 10051277. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10051277
Silkoff PE, Bates CA, Meiser JB, . Single-breath exhaled nitric oxide in preschool children facilitated by a servo-controlled device maintaining constant flow. Pediatr Pulmonol. 2004 Jun;37(6):554–8. doi: 10.1002/ppul.20033. PMID: 15114557. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15114557
Silkoff PE, Lent AM, Busacker AA, . Exhaled nitric oxide identifies the persistent eosinophilic phenotype in severe refractory asthma. J Allergy Clin Immunol. 2005 Dec;116(6):1249–55. doi: 10.1016/j.jaci.2005.09.029. PMID: 16337453. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16337453
Silvestri M, Spallarossa D, Battistini E, . Dissociation between exhaled nitric oxide and hyperresponsiveness in children with mild intermittent asthma. Thorax. 2000 Jun;55(6):484–8. doi: DOI 10.1136/thorax.55.6.484. PMID: WOS:000087367100011. The study does not have a comparison group (studies must have a comparison group or pre/post design)10817797
Silvestri M, Spallarossa D, Battistini E, . e-NO peak versus e-NO plateau values in evaluating e-NO production in steroid-naive and in steroid-treated asthmatic children and in detecting response to inhaled steroid treatment. Pediatr Pulmonol. 2001 Jan;31(1):37–43. doi: 10.1002/1099-0496(200101)31:1<37::AID-PPUL1005>3.0.CO;2-Y. PMID: 11180673. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11180673
Silvestri M, Spallarossa D, Battistini E, . How can we best read exhaled nitric oxide flow curves in asthmatic children? Monaldi Arch Chest Dis. 2001 Oct;56(5):384–9. PMID: 11887494. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11887494
Simon, M R, Chinchilli, . Forced expiratory flow between 25% and 75% of vital capacity and FEV <inf>1</inf>/forced vital capacity ratio in relation to clinical and physiological parameters in asthmatic children with normal FEV<inf>1</inf> values. Journal of Allergy and Clinical Immunology. 2010 September;126(3):527–34.e1–e8. doi: 10.1016/j.jaci.2010.05.016. PMID: 2010485577. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Simon MR, Chinchilli VM, Phillips BR, . Forced expiratory flow between 25% and 75% of vital capacity and FEV1/forced vital capacity ratio in relation to clinical and physiological parameters in asthmatic children with normal FEV1 values. J Allergy Clin Immunol. 2010 Sep;126(3):527–34 e1–8. doi: 10.1016/j.jaci.2010.05.016. PMID: 20638110. The study does not evaluate FeNO20638110
Singer F, Horak F, Jr., Friesenbichler W, . Cysteinyl-leukotrienes in nasal lavage fluid in children with asthma. Pediatr Allergy Immunol. 2008 May;19(3):227–32. doi: 10.1111/j.1399-3038.2007.00614.x. PMID: 18397406. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18397406
Singh D, Richards D, Knowles RG, . Selective inducible nitric oxide synthase inhibition has no effect on allergen challenge in asthma. Am J Respir Crit Care Med. 2007 Nov 15;176(10):988–93. doi: 10.1164/rccm.200704-588OC. PMID: 17717202. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17717202
Sippel JM, Holden WE, Tilles SA, . Exhaled nitric oxide levels correlate with measures of disease control in asthma. J Allergy Clin Immunol. 2000 Oct;106(4):645–50. doi: 10.1067/mai.2000.109618. PMID: 11031334. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11031334
Sistonen S, Malmberg P, Malmstrom K, . Repaired oesophageal atresia: respiratory morbidity and pulmonary function in adults. Eur Respir J. 2010 Nov;36(5):1106–12. doi: 10.1183/09031936.00153209. PMID: 20351029. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)20351029
Slats AM, Sont JK, van Klink RH, . Improvement in bronchodilation following deep inspiration after a course of high-dose oral prednisone in asthma. Chest. 2006 Jul;130(1):58–65. doi: 10.1378/chest.130.1.58. PMID: 16840383. Other reason16840383
Smith AD, Cowan JO, Taylor DR. Exhaled nitric oxide levels in asthma: Personal best versus reference values. J Allergy Clin Immunol. 2009 Oct;124(4):714–8 e4. doi: 10.1016/j.jaci.2009.07.020. PMID: 19767074. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19767074
Smith AM, Villareal M, Bernstein DI, . Asthma in the elderly: risk factors and impact on physical function. Ann Allergy Asthma Immunol. 2012 May;108(5):305–10. doi: 10.1016/j.anai.2012.02.022. PMID: 22541399. The study does not have a comparison group (studies must have a comparison group or pre/post design)22541399
Soferman R, Tsivion A, Farber M, . The effect of a single dose of acetaminophen on airways response in children with asthma. Clin Pediatr (Phila). 2013 Jan;52(1):42–8. doi: 10.1177/0009922812462764. PMID: 23047989. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23047989
Song GW, Ban GY, Nam YH, . Case report of occupational asthma induced by polyvinyl chloride and nickel. J Korean Med Sci. 2013 Oct;28(10):1540–2. doi: 10.3346/jkms.2013.28.10.1540. PMID: 24133363. The study does not have a comparison group (studies must have a comparison group or pre/post design)24133363
Sonnappa S, Bastardo CM, Saglani S, . Relationship between past airway pathology and current lung function in preschool wheezers. Eur Respir J. 2011 Dec;38(6):1431–6. doi: 10.1183/09031936.00164910. PMID: 21778162. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21778162
Sorkness CA, Lemanske RF, Jr., Mauger DT, . Long-term comparison of 3 controller regimens for mild-moderate persistent childhood asthma: the Pediatric Asthma Controller Trial. J Allergy Clin Immunol. 2007 Jan;119(1):64–72. doi: 10.1016/j.jaci.2006.09.042. PMID: 17140647. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17140647
Sorkness CA, Lemanske RF, Jr., Mauger DT, . Long-term comparison of 3 controller regimens for mild-moderate persistent childhood asthma: the Pediatric Asthma Controller Trial. J Allergy Clin Immunol. 2007 Jan;119(1):64–72. doi: 10.1016/j.jaci.2006.09.042. PMID: 17140647. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17140647
Soto-Ramos M, Castro-Rodriguez JA, Hinojos-Gallardo LC, . Fractional exhaled nitric oxide has a good correlation with asthma control and lung function in latino children with asthma. J Asthma. 2013 Aug;50(6):590–4. doi: 10.3109/02770903.2013.792349. PMID: 23617392. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23617392
Spallarossa D, Battistini E, Silvestri M, . Steroid-naive adolescents with mild intermittent allergic asthma have airway hyperresponsiveness and elevated exhaled nitric oxide levels. J Asthma. 2003 May;40(3):301–10. doi: 10.1081/JAS-120018629. PMID: 12807174. Other reason12807174
Spanier AJ, Fiorino EK, Trasande L. Bisphenol A Exposure Is Associated with Decreased Lung Function. Journal of Pediatrics. 2014 Jun;164(6):1403-+. doi: 10.1016/j.jpeds.2014.02.026. PMID: WOS:000336503200034. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24657123
Spears M, Weir CJ, Smith AD, . Bronchial nitric oxide flux (J’aw) is sensitive to oral corticosteroids in smokers with asthma. Respir Med. 2011 Dec;105(12):1823–30. doi: 10.1016/j.rmed.2011.06.014. PMID: 21840187. The study does not have a comparison group (studies must have a comparison group or pre/post design)21840187
Spergel JM, Fogg MI, Bokszczanin-Knosala A. Correlation of exhaled nitric oxide, spirometry and asthma symptoms. J Asthma. 2005 Dec;42(10):879–83. doi: 10.1080/02770900500371344. PMID: 16393728. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16393728
Stanciulescu C, Chiru M, Oprea A, . The role of FENO and spirometry in the evaluation of obstruction in pediatric asthma. Pneumologia. 2015 Jul–Sep;64(3):40–4. PMID: 26738370. The study does not have a comparison group (studies must have a comparison group or pre/post design)26738370
Steiss JO, Rudloff S, Landmann E, . Effect of inhaled corticosteroid treatment on exhaled breath condensate leukotriene E(4) in children with mild asthma. Allergy Asthma Proc. 2008 Jul–Aug;29(4):371–5. doi: 10.2500/aap.2008.29.3135. PMID: 18702883. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18702883
Stelmach I, Podlecka D, Majak P, . Validity of the Pediatric Asthma Quality of Life Questionnaire in Polish children. Pediatr Allergy Immunol. 2011 Nov;22(7):660–6. doi: 10.1111/j.1399-3038.2011.01162.x. PMID: 21950677. The study does not evaluate FeNO21950677
Storm Van’s Gravesande K, Mattes J, Endlicher A, . [Effect of two doses of budesonide on exhaled nitric oxide and urinary EPX excretion in asthmatic children]. Pneumologie. 2004 Jul;58(7):483–8. doi: 10.1055/s-2004-818466. PMID: 15257469. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15257469
Strandbygaard U, Thomsen SF, Backer V. A daily SMS reminder increases adherence to asthma treatment: a three-month follow-up study. Respir Med. 2010 Feb;104(2):166–71. doi: 10.1016/j.rmed.2009.10.003. PMID: 19854632. The study does not have a comparison group (studies must have a comparison group or pre/post design)19854632
Straub DA, Minocchieri S, Moeller A, . The effect of montelukast on exhaled nitric oxide and lung function in asthmatic children 2 to 5 years old. Chest. 2005 Feb;127(2):509–14. doi: 10.1378/chest.127.2.509. PMID: 15705989. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15705989
Sue-Chu M, Henriksen AH, Bjermer L. Non-invasive evaluation of lower airway inflammation in hyper-responsive elite cross-country skiers and asthmatics. Respir Med. 1999 Oct;93(10):719–25. doi: 10.1016/S0954-6111(99)90039-2. PMID: 10581661. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10581661
Sugiura H, Komaki Y, Koarai A, . Nitrative stress in refractory asthma. J Allergy Clin Immunol. 2008 Feb;121(2):355–60. doi: 10.1016/j.jaci.2007.11.009. PMID: 18158173. Other reason18158173
Sutherland ER, Goleva E, King TS, . Cluster analysis of obesity and asthma phenotypes. PLoS One. 2012;7(5):e36631. doi: 10.1371/journal.pone.0036631. PMID: 22606276. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22606276
Sutherland ER, Lehman EB, Teodorescu M, . Body mass index and phenotype in subjects with mild-to-moderate persistent asthma. J Allergy Clin Immunol. 2009 Jun;123(6):1328–34 e1. doi: 10.1016/j.jaci.2009.04.005. PMID: 19501235. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19501235
Svenningsen, S, Kirby, . What are ventilation defects in asthma? Thorax. 2014 January;69(1):63–71. doi: 10.1136/thoraxjnl-2013–203711. PMID: 2013794969. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23956019
Sverrild A, Malinovschi A, Porsbjerg C, . Predicting airway hyperreactivity to mannitol using exhaled nitric oxide in an unselected sample of adolescents and young adults. Respiratory Medicine. 2013 Jan;107(1):150–2. doi: 10.1016/j.rmed.2012.09.004. PMID: WOS:000314135600020. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23177390
Sverrild A, Porsbjerg C, Thomsen SF, . Diagnostic properties of inhaled mannitol in the diagnosis of asthma: a population study. J Allergy Clin Immunol. 2009 Nov;124(5):928–32 e1. doi: 10.1016/j.jaci.2009.06.028. PMID: 19665779. Other reason19665779
Swiebocka E, Siergiejko G, Siergiejko Z. Bronchial allergen challenge in allergic children: continuous increase of nitric oxide in exhaled air 72 hours after allergen inhalation independent of bronchial obstruction. J Aerosol Med Pulm Drug Deliv. 2011 Feb;24(1):17–24. doi: 10.1089/jamp.2010.0833. PMID: 21166583. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)21166583
Tadaki H, Mochizuki H, Muramastu R, . Effect of bronchoconstriction on exhaled nitric oxide levels in healthy and asthmatic children. Ann Allergy Asthma Immunol. 2009 Jun;102(6):469–74. doi: 10.1016/S1081-1206(10)60119-6. PMID: 19558004. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19558004
Tafuro F, Ridolo E, Goldoni M, . Work-related allergies to storage mites in Parma (Italy) ham workers. BMJ Open. 2015 May 19;5(5):e007502. doi: 10.1136/bmjopen-2014-007502. PMID: 25991455. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)25991455
Takeno S, Noda N, Hirakawa K. Measurements of nasal fractional exhaled nitric oxide with a hand-held device in patients with allergic rhinitis: relation to cedar pollen dispersion and laser surgery. Allergol Int. 2012 Mar;61(1):93–100. doi: 10.2332/allergolint.11-OA-0318. PMID: 22015565. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22015565
Tamada T, Sugiura H, Takahashi T, . Biomarker-based detection of asthma-COPD overlap syndrome in COPD populations. Int J Chron Obstruct Pulmon Dis. 2015;10:2169–76. doi: 10.2147/COPD.S88274. PMID: 26491283. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)26491283
Tanaka, Y, Takanashi, . Impaired pulmonary function in the university students who had asthma in childhood. Hirosaki Medical Journal. 2014;65(2–4):128–37. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)
Tanou K, Koutsokera A, Kiropoulos TS, . Inflammatory and oxidative stress biomarkers in allergic rhinitis: the effect of smoking. Clin Exp Allergy. 2009 Mar;39(3):345–53. doi: 10.1111/j.1365-2222.2008.03149.x. PMID: 19187324. Other reason19187324
Taylor DA, McGrath JL, Orr LM, . Effect of endogenous nitric oxide inhibition on airway responsiveness to histamine and adenosine-5′-monophosphate in asthma. Thorax. 1998 Jun;53(6):483–9. doi: 10.1136/thx.53.6.483. PMID: 9713448. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9713448
Taylor DR, Mandhane P, Greene JM, . Factors affecting exhaled nitric oxide measurements: the effect of sex. Respir Res. 2007 Nov 15;8:82. doi: 10.1186/1465-9921-8-82. PMID: 18005450. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18005450
Teach SJ, Gergen PJ, Szefler SJ, . Seasonal risk factors for asthma exacerbations among inner-city children. Journal of Allergy and Clinical Immunology. 2015 Jun;135(6):1465–U116. doi: 10.1016/j.jaci.2014.12.1942. PMID: WOS:000355933400008. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25794658
Tee AK, Hui KP. Effect of spirometric maneuver, nasal clip, and submaximal inspiratory effort on measurement of exhaled nitric oxide levels in asthmatic patients. Chest. 2005 Jan;127(1):131–4. doi: 10.1378/chest.127.1.131. PMID: 15653973. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)15653973
ten Hacken NH, van der Vaart H, van der Mark TW, . Exhaled nitric oxide is higher both at day and night in subjects with nocturnal asthma. Am J Respir Crit Care Med. 1998 Sep;158(3):902–7. doi: 10.1164/ajrccm.158.3.9712021. PMID: 9731024. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)9731024
Thamrin C, Taylor DR, Jones SL, . Variability of lung function predicts loss of asthma control following withdrawal of inhaled corticosteroid treatment. Thorax. 2010 May;65(5):403–8. doi: 10.1136/thx.2009.129668. PMID: 20435861. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20435861
Thanasias E, Polychronakis I, van Kampen V, . Occupational immediate-type allergic asthma due to potassium tetrachloroplatinate in production of cytotoxic drugs. Adv Exp Med Biol. 2013;755:47–53. doi: 10.1007/978-94-007-4546-9_6. PMID: 22826048. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22826048
Thomas AO, Jackson DJ, Evans MD, . Sex-related differences in pulmonary physiologic outcome measures in a high-risk birth cohort. J Allergy Clin Immunol. 2015 Aug;136(2):282–7. doi: 10.1016/j.jaci.2014.12.1927. PMID: 25678088. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25678088
Thomas M, McKinley RK, Mellor S, . Breathing exercises for asthma: a randomised controlled trial. Thorax. 2009 Jan;64(1):55–61. doi: 10.1136/thx.2008.100867. PMID: 19052047. The study does not evaluate FeNO19052047
Thomas M, Gruffydd-Jones K, Stonham C, . Assessing asthma control in routine clinical practice: use of the Royal College of Physicians ‘3 questions’. Prim Care Respir J. 2009 Jun;18(2):83–8. doi: 10.3132/pcrj.2008.00045. PMID: 18698483. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18698483
Thomas PS, Heywood G. Effects of inhaled tumour necrosis factor alpha in subjects with mild asthma. Thorax. 2002 Sep;57(9):774–8. doi: 10.1136/thorax.57.9.774. PMID: 12200521. The study does not have a comparison group (studies must have a comparison group or pre/post design)12200521
Thomassen MJ, Raychaudhuri B, Dweik RA, . Nitric oxide regulation of asthmatic airway inflammation with segmental allergen challenge. J Allergy Clin Immunol. 1999 Dec;104(6):1174–82. doi: 10.1016/S0091-6749(99)70010-2. PMID: 10588998. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10588998
Thornadtsson A, Neerincx AH, Hogman M, . Extended nitric oxide analysis may improve personalized anti-inflammatory treatment in asthmatic children with intermediate F(E)NO50. J Breath Res. 2015 Dec 15;9(4):047114. doi: 10.1088/1752-7155/9/4/047114. PMID: 26670199. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26670199
Tibosch M, de Ridder J, Landstra A, . Four of a kind: asthma control, FEV1, FeNO, and psychosocial problems in adolescents. Pediatr Pulmonol. 2012 Oct;47(10):933–40. doi: 10.1002/ppul.22514. PMID: 22328345. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22328345
Torre, O, Olivieri, . Feasibility and interpretation of FE<inf>NO</inf> measurements in asthma patients in general practice. Respiratory Medicine. 2008 October;102(10):1417–24. doi: 10.1016/j.rmed.2008.04.004. PMID: 2008408128. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18619827
Toyran M, Bakirtas A, Dogruman-Al F, . Airway inflammation and bronchial hyperreactivity in steroid naive children with intermittent and mild persistent asthma. Pediatr Pulmonol. 2014 Feb;49(2):140–7. doi: 10.1002/ppul.22810. PMID: 23798479. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23798479
Tsang KW, Tan KC, Ho PL, . Exhaled nitric oxide in bronchiectasis: the effects of inhaled corticosteroid therapy. Int J Tuberc Lung Dis. 2004 Nov;8(11):1301–7. PMID: 15581196. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)15581196
Tsuburai, T, Suzuki, . Use of forced oscillation technique to detect airflow limitations in adult Japanese asthmatics. [Japanese]. Japanese Journal of Allergology. 2012;61(2):184–93. PMID: 2012302023. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22437728
Tsuburai T, Tsurikisawa N, Higashi N, . [Differences in fraction of exhaled nitric oxide values measured by two offline methods or NIOXmino in adult Japanese asthmatics]. Arerugi. 2010 Aug;59(8):956–64. PMID: 20820137. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20820137
Tsuburai, T, Tsurikisawa, . Relationship between exhaled nitric oxide measured by two offline methods and bronchial hyperresponsiveness in Japanese adults with asthma. Allergology International. 2008;57(3):223–9. PMID: 2008479033. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18493167
Tsuburai T, Mita H, Tsurikisawa N, . [Relationship between cysteinyl leukotriene in exhaled breath condensate and the severity of asthma in adult asthmatics in Japan]. Arerugi. 2008 Feb;57(2):121–9. PMID: 18349586. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18349586
Tsuburai T, Tsurikisawa N, Higashi N, . [The effect of inhaled corticosteroid on the fraction of exhaled nitric oxide (FeNO) with off-line method in adult Japanese asthmatics]. Arerugi. 2008 Dec;57(12):1293–301. PMID: 19169084. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19169084
Tsuburai T, Tsurikisawa N, Ishii T, . [The methodological aspects of nasal and exhaled nitric oxide levels in adult Japanese asthmatics]. Arerugi. 2008 Aug;57(8):1012–21. PMID: 18781106. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)18781106
Tsujino, I, Nishimura, . Exhaled nitric oxide - Is it really a good marker of airway inflammation in bronchial asthma? Respiration. 2000;67(6):645–51. doi: 10.1159/000056294. PMID: 2001006040. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11124647
Tsurikisawa N, Saito A, Oshikata C, . Encasing bedding in covers made of microfine fibers reduces exposure to house mite allergens and improves disease management in adult atopic asthmatics. Allergy Asthma and Clinical Immunology. 2013 Nov 11;9(1)doi: Artn 44 10.1186/1710-1492-9-44. PMID: WOS:000332414800001. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Tufvesson E, Aronsson D, Ankerst J, . Peripheral nitric oxide is increased in rhinitic patients with asthma compared to bronchial hyperresponsiveness. Respir Med. 2007 Nov;101(11):2321–6. doi: 10.1016/j.rmed.2007.06.015. PMID: 17686621. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17686621
Tunnicliffe WS, Harrison RM, Kelly FJ, . The effect of sulphurous air pollutant exposures on symptoms, lung function, exhaled nitric oxide, and nasal epithelial lining fluid antioxidant concentrations in normal and asthmatic adults. Occup Environ Med. 2003 Nov;60(11):e15. doi: 10.1136/oem.60.11.e15. PMID: 14573726. The study does not have a comparison group (studies must have a comparison group or pre/post design)14573726
Turktas, H, Levent, . Effects of inhaled budesnide and nedocromil sodium on exhaled nitric oxide levels in mild asthmatic patients. Gazi Medical Journal. 1998;9(4):167–71. PMID: 1999095758. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Turner S. The role of exhaled nitric oxide in the diagnosis, management and treatment of asthma. Mini Rev Med Chem. 2007 May;7(5):539–42. doi: 10.2174/138955707780619635. PMID: 17504190. The study is not original (commentaries, letters, etc. should be excluded)17504190
Tworek D, Bochenska-Marciniak M, Kupczyk M, . [Lack of correlation between exhaled nitric oxide (eNO) and clinical indicators of the disease activity and quality of life in mild and moderate asthmatics]. Pneumonol Alergol Pol. 2006;74(4):391–5. PMID: 17427148. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17427148
Uasuf CG, Jatakanon A, James A, . Exhaled carbon monoxide in childhood asthma. J Pediatr. 1999 Nov;135(5):569–74. doi: 10.1016/S0022-3476(99)70054-5. PMID: 10547244. Other reason10547244
Ulrik CS, Svenningsen C. High prevalence of asthma in Danish elite canoe- and kayak athletes. Dan Med J. 2012 Apr;59(4):A4405. PMID: 22459716. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22459716
Vahlkvist S, Sinding M, Skamstrup K, . Daily home measurements of exhaled nitric oxide in asthmatic children during natural birch pollen exposure. J Allergy Clin Immunol. 2006 Jun;117(6):1272–6. doi: 10.1016/j.jaci.2006.03.018. PMID: 16750986. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16750986
van Asch CJJ, Balemans WAF, Rovers MM, . Atopic disease and exhaled nitric oxide in an unselected population of young adults. Annals of Allergy Asthma & Immunology. 2008 Jan;100(1):59–65. doi: 10.1016/S1081-1206(10)60406-1. PMID: WOS:000252162100011. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)
van Amsterdam JGC, Zanen P, Somer S, . Flow dependency and off-line measurement of exhaled NO in children. Pediatric Allergy and Immunology. 2003 Aug;14(4):266–71. doi: 10.1034/j.1399-3038.2003.00035.x. PMID: WOS:000184732600005. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)12911503
van Bragt S, van den Bemt L, Thoonen B, . Validity, reliability and discriminative capacity of an electronic quality of life instrument (Pelican) for childhood asthma in the Netherlands. Qual Life Res. 2014 Apr;23(3):927–38. doi: 10.1007/s11136-013-0533-3. PMID: 24081870. The study does not evaluate FeNO24081870
van de Kant KD, Koers K, Rijkers GT, . Can exhaled inflammatory markers predict a steroid response in wheezing preschool children? Clin Exp Allergy. 2011 Aug;41(8):1076–83. doi: 10.1111/j.1365-2222.2011.03774.x. PMID: 21623968. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21623968
van den B, M, Kerstjens, . Corticosteroid-induced improvement in the PC20 of adenosine monophosphate is more closely associated with reduction in airway inflammation than improvement in the PC20 of methacholine. American journal of respiratory and critical care medicine. 2001 Oct 1;164(7):1127–32. doi: 10.1164/ajrccm.164.7.2102135 PMID: CN-00374689 UPDATE. The study does not have a comparison group (studies must have a comparison group or pre/post design)11673197
van Den Toorn LM, Prins JB, Overbeek SE, . Adolescents in clinical remission of atopic asthma have elevated exhaled nitric oxide levels and bronchial hyperresponsiveness. Am J Respir Crit Care Med. 2000 Sep;162(3 Pt 1):953–7. doi: 10.1164/ajrccm.162.3.9909033. PMID: 10988112. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10988112
van der Schee MP, Palmay R, Cowan JO, . Predicting steroid responsiveness in patients with asthma using exhaled breath profiling. Clin Exp Allergy. 2013 Nov;43(11):1217–25. doi: 10.1111/cea.12147. PMID: 24152154. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24152154
Van Der W, E, Postma, . Effects of small airway dysfunction on the clinical expression of asthma: A focus on asthma symptoms and bronchial hyper-responsiveness. Allergy: European Journal of Allergy and Clinical Immunology. 2014 01 Dec;69(12):1681–8. doi: 10.1111/all.12510. PMID: 2014902243. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25123492
van Leeuwen JC, Hoogstrate M, Duiverman EJ, . Effects of dietary induced weight loss on exercise-induced bronchoconstriction in overweight and obese children. Pediatr Pulmonol. 2014 Dec;49(12):1155–61. doi: 10.1002/ppul.22932. PMID: 24166939. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24166939
Van Muylem A, Kerckx Y, Michils A. Acinar effect of inhaled steroids evidenced by exhaled nitric oxide. Journal of Allergy and Clinical Immunology. 2010 Oct;126(4):730–U93. doi: 10.1016/j.jaci.2010.06.019. PMID: WOS:000282510000006. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20709384
Van Muylem A, Kerckx Y, Michils A. Axial distribution of nitric oxide airway production in asthma patients. Respir Physiol Neurobiol. 2013 Jan 15;185(2):313–8. doi: 10.1016/j.resp.2012.09.011. PMID: 23059373. The study does not have a comparison group (studies must have a comparison group or pre/post design)23059373
Van Vliet D, Smolinska A, Jobsis Q, . Association between exhaled inflammatory markers and asthma control in children. Journal of Breath Research. 2016 Mar;10(1)doi: Artn 016014 10.1088/1752-7155/10/1/016014. PMID: WOS:000375749700016. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Vempilly J, Abejie B, Diep V, . The synergetic effect of ambient PM2.5 exposure and rhinovirus infection in airway dysfunction in asthma: a pilot observational study from the Central Valley of California. Exp Lung Res. 2013 Dec;39(10):434–40. doi: 10.3109/01902148.2013.840693. PMID: 24245976. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24245976
Verleden GM, Dupont LJ, Verpeut AC, . The effect of cigarette smoking on exhaled nitric oxide in mild steroid-naive asthmatics. Chest. 1999 Jul;116(1):59–64. doi: 10.1378/chest.116.1.59. PMID: 10424504. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)10424504
Vermeulen S, Barreto M, La Penna F, . Exhaled breath temperature in children: reproducibility and influencing factors. J Asthma. 2014 Sep;51(7):743–50. doi: 10.3109/02770903.2014.906606. PMID: 24654705. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24654705
Vieira, T, Fonseca, . Validity of a questionnaire in a school-based allergic asthma screening- comparison with exhaled nitric oxide fraction and skin prick tests. Revista Portuguesa de Imunoalergologia. 2011 July/August;19(4):215–21. PMID: 2012087181. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Vizmanos-Lamotte G, Cruz MJ, Gomez-Olles S, . [Determining asthma treatment in children by monitoring fractional exhaled nitric oxide, sputum eosinophils and leukotriene B(4)]. An Pediatr (Barc). 2015 Jan;82(1):e21–5. doi: 10.1016/j.anpedi.2014.03.012. PMID: 24857428. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24857428
Vizmanos L, G, Cruz, . Determining asthma treatment in children by monitoring fractional exhaled nitricoxide, sputum eosinophils and leukotriene B<inf>4</inf>. Anales de Pediatria. 2014;82(1):e21–e5. doi: 10.1016/j.anpedi.2014.03.012. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24857428
Von Essen SG, Scheppers LA, Robbins RA, . Respiratory tract inflammation in swine confinement workers studied using induced sputum and exhaled nitric oxide. Journal of Toxicology-Clinical Toxicology. 1998;36(6):557–65. doi: 10.3109/15563659809028049. PMID: WOS:000076347400003. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)9776958
Voutilainen M, Malmberg LP, Vasankari T, . Exhaled nitric oxide indicates poorly athlete’s asthma. Clin Respir J. 2013 Oct;7(4):347–53. doi: 10.1111/crj.12014. PMID: 23560618. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23560618
Waibel V, Ulmer H, Horak E. Assessing asthma control: symptom scores, GINA levels of asthma control, lung function, and exhaled nitric oxide. Pediatr Pulmonol. 2012 Feb;47(2):113–8. doi: 10.1002/ppul.21529. PMID: 22241569. The study does not have a comparison group (studies must have a comparison group or pre/post design)22241569
Walker WT, Liew A, Harris A, . Upper and lower airway nitric oxide levels in primary ciliary dyskinesia, cystic fibrosis and asthma. Respir Med. 2013 Mar;107(3):380–6. doi: 10.1016/j.rmed.2012.11.021. PMID: 23290188. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23290188
Walters GI, Moore VC, Robertson AS, . An outbreak of occupational asthma due to chromium and cobalt. Occup Med (Lond). 2012 Oct;62(7):533–40. doi: 10.1093/occmed/kqs111. PMID: 22826555. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)22826555
Walters GI, Moore VC, McGrath EE, . Fractional exhaled nitric oxide in the interpretation of specific inhalational challenge tests for occupational asthma. Lung. 2014 Feb;192(1):119–24. doi: 10.1007/s00408-013-9531-z. PMID: 24232978. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24232978
Wan GH, Yan DC, Tung TH, . Seasonal Changes in Endotoxin Exposure and Its Relationship to Exhaled Nitric Oxide and Exhaled Breath Condensate pH Levels in Atopic and Healthy Children. PLoS One. 2013 19 Jun;8(6):e66785. doi: 10.1371/journal.pone.0066785. PMID: 23840530. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)23840530
Wang G, Baines KJ, Fu JJ, . Sputum mast cell subtypes relate to eosinophilia and corticosteroid response in asthma. Eur Respir J. 2016 Apr;47(4):1123–33. doi: 10.1183/13993003.01098-2015. PMID: 26699720. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)26699720
Wang K, Tian P, Fan Y, . Assessment of second-line treatments for patients with uncontrolled moderate asthma. Int J Clin Exp Med. 2015;8(10):19476–80. PMID: 26770595. The study does not evaluate FeNO26770595
Wang L, Hollenbeak CS, Mauger DT, . Cost-effectiveness analysis of fluticasone versus montelukast in children with mild-to-moderate persistent asthma in the Pediatric Asthma Controller Trial. J Allergy Clin Immunol. 2011 Jan;127(1):161–6, 6 e1. doi: 10.1016/j.jaci.2010.10.035. PMID: 21211651. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21211651
Wang W, Huang KW, Wu BM, . Correlation of eosinophil counts in induced sputum and fractional concentration of exhaled nitric oxide and lung functions in patients with mild to moderate asthma. Chin Med J (Engl). 2012 Sep;125(17):3157–60. PMID: 22932198. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22932198
Warke TJ, Fitch PS, Brown V, . Exhaled nitric oxide correlates with airway eosinophils in childhood asthma. Thorax. 2002 May;57(5):383–7. doi: 10.1136/thorax.57.5.383. PMID: 11978911. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11978911
Watanabe T, Fajt ML, Trudeau JB, . Brain-Derived Neurotrophic Factor Expression in Asthma. Association with Severity and Type 2 Inflammatory Processes. Am J Respir Cell Mol Biol. 2015 Dec;53(6):844–52. doi: 10.1165/rcmb.2015-0015OC. PMID: 25945802. The study does not evaluate FeNO25945802
Wechsler ME, Castro M, Lehman E, . Impact of race on asthma treatment failures in the asthma clinical research network. Am J Respir Crit Care Med. 2011 Dec 01;184(11):1247–53. doi: 10.1164/rccm.201103-0514OC. PMID: 21885625. The study does not have a comparison group (studies must have a comparison group or pre/post design)21885625
Wedes SH, Khatri SB, Zhang R, . Noninvasive markers of airway inflammation in asthma. Clin Transl Sci. 2009 Apr;2(2):112–7. doi: 10.1111/j.1752-8062.2009.00095.x. PMID: 20234847. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20234847
Wedes SH, Wu W, Comhair SA, . Urinary bromotyrosine measures asthma control and predicts asthma exacerbations in children. J Pediatr. 2011 Aug;159(2):248–55 e1. doi: 10.1016/j.jpeds.2011.01.029. PMID: 21392781. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21392781
Welsh L, Lercher P, Horak E. Exhaled nitric oxide: interactions between asthma, hayfever, and atopic dermatitis in school children. Pediatr Pulmonol. 2007 Aug;42(8):693–8. doi: 10.1002/ppul.20632. PMID: 17588251. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17588251
Westergaard CG, Porsbjerg C, Backer V. The effect of smoking cessation on airway inflammation in young asthma patients. Clin Exp Allergy. 2014 Mar;44(3):353–61. doi: 10.1111/cea.12243. PMID: 24286379. Other reason24286379
Whelan GJ, Blake K, Kissoon N, . Effect of montelukast on time-course of exhaled nitric oxide in asthma: influence of LTC4 synthase A(-444)C polymorphism. Pediatr Pulmonol. 2003 Nov;36(5):413–20. doi: 10.1002/ppul.10385. PMID: 14520724. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)14520724
Wildhaber JH, Moller A, Hall GL, . Levels of exhaled nitric oxide in recurrently wheezy infants are decreased following inhaled steroid therapy. Schweizerische Medizinische Wochenschrift. 2000 Apr 15;130(15):529–34. PMID: WOS:000086821100001. Other reason
Williamson PA, Clearie K, Menzies D, . Assessment of small-airways disease using alveolar nitric oxide and impulse oscillometry in asthma and COPD. Lung. 2011 Apr;189(2):121–9. doi: 10.1007/s00408-010-9275-y. PMID: 21174112. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)21174112
illiamson PA, Menzies D, Nair A, . A proof-of-concept study to evaluate the antiinflammatory effects of a novel soluble cyclodextrin formulation of nebulized budesonide in patients with mild to moderate asthma. Ann Allergy Asthma Immunol. 2009 Feb;102(2):161–7. doi: 10.1016/S1081-1206(10)60248-7. PMID: 19230469. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19230469
Williamson PA, Vaidyanathan S, Clearie K, . Relationship between fractional exhaled nitric oxide and nasal nitric oxide in airways disease. Ann Allergy Asthma Immunol. 2010 Aug;105(2):162–7. doi: 10.1016/j.anai.2010.05.014. PMID: 20674828. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20674828
Wilson AM, Dempsey OJ, Sims EJ, . A comparison of topical budesonide and oral montelukast in seasonal allergic rhinitis and asthma. Clin Exp Allergy. 2001 Apr;31(4):616–24. doi: 10.1046/j.1365-2222.2001.01088.x. PMID: 11359431. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11359431
Wilson AM, Dempsey OJ, Sims EJ, . Subjective and objective markers of treatment response in patients with seasonal allergic rhinitis. Ann Allergy Asthma Immunol. 2000 Aug;85(2):111–4. doi: 10.1016/S1081-1206(10)62449-0. PMID: 10982217. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)10982217
Wilson AM, Duong M, Pratt B, . Anti-inflammatory effects of once daily low dose inhaled ciclesonide in mild to moderate asthmatic patients. Allergy. 2006 May;61(5):537–42. doi: 10.1111/j.1398-9995.2006.01061.x. PMID: 16629781. Other reason16629781
Wu WT, Liao HY, Chung YT, . Effect of nanoparticles exposure on fractional exhaled nitric oxide (FENO) in workers exposed to nanomaterials. Int J Mol Sci. 2014 Jan 09;15(1):878–94. doi: 10.3390/ijms15010878. PMID: 24413755. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)24413755
Yamauchi K, Tanifuji Y, Pan LH, . Effects of pranlukast, a leukotriene receptor antagonist, on airway inflammation in mild asthmatics. J Asthma. 2001 Feb;38(1):51–7. doi: 10.1081/JAS-100000021. PMID: 11256554. Other reason11256554
Yasui H, Fujisawa T, Inui N, . Impact of add-on pranlukast in stable asthma; the additive effect on peripheral airway inflammation. Respir Med. 2012 Apr;106(4):508–14. doi: 10.1016/j.rmed.2011.12.014. PMID: 22265857. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)22265857
Yurdakul AS, Canbakan S, Capan N, . Exhaled nitric oxide levels in patients with bronchial asthma and allergic rhinitis. Turkiye Klinikleri Tip Bilimleri Dergisi. 2008 Feb;28(1):12–7. PMID: WOS:000254501300003. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)
Zanconato S, Carraro S, Corradi M, . Leukotrienes and 8-isoprostane in exhaled breath condensate of children with stable and unstable asthma. J Allergy Clin Immunol. 2004 Feb;113(2):257–63. doi: 10.1016/j.jaci.2003.10.046. PMID: 14767439. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)14767439
Zanconato S, Scollo M, Zaramella C, . Exhaled carbon monoxide levels after a course of oral prednisone in children with asthma exacerbation. J Allergy Clin Immunol. 2002 Mar;109(3):440–5. doi: 10.1067/mai.2002.121954. PMID: 11897988. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)11897988
Zerah-Lancner F, Boyer L, Rezaiguia-Delclaux S, . Airway responsiveness measured by forced oscillation technique in severely obese patients, before and after bariatric surgery. J Asthma. 2011 Oct;48(8):818–23. doi: 10.3109/02770903.2011.613508. PMID: 21910666. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)21910666
Zhang JJ, McCreanor JE, Cullinan P, . Health effects of real-world exposure to diesel exhaust in persons with asthma. Res Rep Health Eff Inst. 2009 Feb(138):5–109; discussion 11–23. PMID: 19449765. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)19449765
Zhang L, Gang J, Zhigang C, . Irreversible airway obstruction assessed by high-resolution computed tomography (HRCT), exhaled nitric oxide (FENO), and biological markers in induced sputum in patients with asthma. Wien Klin Wochenschr. 2014 Sep;126(17–18):515–23. doi: 10.1007/s00508-014-0568-7. PMID: 25138548. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)25138548
Zhao Z, Huang C, Zhang X, . Fractional exhaled nitric oxide in Chinese children with asthma and allergies--a two-city study. Respir Med. 2013 Feb;107(2):161–71. doi: 10.1016/j.rmed.2012.11.001. PMID: 23199703. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)23199703
Zielen S, Christmann M, Kloska M, . Predicting short term response to anti-inflammatory therapy in young children with asthma. Curr Med Res Opin. 2010 Feb;26(2):483–92. doi: 10.1185/03007990903485148. PMID: 20001651. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)20001651
Zietkowski, Z, Bodzenta L, . The role of measurement of exhaled nitric oxide in asthma patients. [Polish]. Polskie Archiwum Medycyny Wewnetrznej. 2005;113(1):35–41. PMID: 2005181615. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16130599
Zietkowski, Z, Bodzenta Ł, . The role of measurement of exhaled nitric oxide in asthma patients. Polskie Archiwum Medycyny Wewnetrznej. 2005;113(1):35–41. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16130599
Zietkowski Z, Skiepko R, Tomasiak MM, . Endothelin-1 in exhaled breath condensate of allergic asthma patients with exercise-induced bronchoconstriction. Respir Res. 2007 Oct 31;8:76. doi: 10.1186/1465-9921-8-76. PMID: 17973986. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)17973986
Zietkowski Z, Bodzenta-Lukaszyk A, Tomasiak MM, . Effect of ciclesonide and fluticasone on exhaled nitric oxide in patients with mild allergic asthma. Respir Med. 2006 Sep;100(9):1651–6. doi: 10.1016/j.rmed.2005.12.004. PMID: 16443353. The study does not report any outcomes of interest (diagnosis of asthma, clinical asthma outcomes, healthcare utilization, harms due to over-/under-diagnosis or other side effects)16443353
Zinelli C, Caffarelli C, Strid J, . Measurement of nitric oxide and 8-isoprostane in exhaled breath of children with atopic eczema. Clin Exp Dermatol. 2009 Jul;34(5):607–12. doi: 10.1111/j.1365-2230.2008.03142.x. PMID: 19508477. The study does not have patients of interest (suspected to have asthma, have wheezing, 0–4 years old who may develop asthma in the future)19508477