# Appendix A Search Strategy

## KQ 1a

### Ovid

Database(s): Embase 1988 to 2016 Week 30, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present, EBM Reviews - Cochrane Central Register of Controlled Trials June 2016, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to July 20, 2016

### Search Strategy

# | Searches | Results
1 | exp Asthma/ | 308141
2 | asthma*.mp. | 387608
3 | 1 or 2 | 387722
4 | (“airway nitric oxide” or “airway NO” or “airway oxide” or “breath nitric oxide” or “breath NO” or “breath oxide” or “breathed nitric oxide” or “breathed NO” or “breathed oxide” or “breathing nitric oxide” or “breathing NO” or “breathing oxide” or “exhaled nitric oxide” or “exhaled NO” or “exhaled oxide” or FeNO or “lung nitric oxide” or “lung NO” or “lung oxide” or “pulmonary nitric oxide” or “pulmonary NO” or “pulmonary oxide” or “respiration nitric oxide” or “respiration NO” or “respiration oxide” or “respiratory nitric oxide” or “respiratory NO” or “respiratory oxide”).mp. | 100229
5 | exp diagnostic accuracy/ | 202333
6 | exp Spirometry/ | 48927
7 | exp methacholine/ | 15852
8 | exp Eosinophils/ | 55216
9 | exp Eosinophil/ | 55216
10 | exp eosinophil count/ | 7771
11 | exp Peak Expiratory Flow Rate/ | 17248
12 | ((“respired air” adj3 pressure) or ((hyperreactiv* or hyperrespons* or respons*) adj3 (SABA or “short-acting beta2 agonist*”)) or (breath adj3 measur*) or (diagnos* adj3 (accuracy or accurate)) or bronchoprovocat* or eosinophil* or mecholine or mecholyl or metacholine or methacholine or methacholinium or methylcholine or “peak expiration flow*” or “peak expiratory flow*” or “peak flow*” or spirometr*).mp. | 605846
13 | or/5–12 | 606514
14 | 3 and 4 and 13 | 8599
15 | exp Blood/ | 2555329
16 | blood.fs. | 1571711
17 | exp Heart/ | 879900
18 | exp Blood Vessels/ | 1373624
19 | exp Heart Diseases/ | 2263854
20 | exp Vascular Diseases/ | 3255967
21 | (arter* or blood or cardiac or cardial or heart or plasma or plasmas or serum or vascular* or vein* or vessel*).mp. | 11139543
22 | or/15–21 | 13473717
23 | 14 not 22 | 5081
24 | exp evidence based medicine/ | 904342
25 | exp meta analysis/ | 183265
26 | exp Meta-Analysis as Topic/ | 43341
27 | exp “systematic review”/ | 110642
28 | exp controlled study/ | 5161226
29 | exp Randomized Controlled Trial/ | 821123
30 | exp triple blind procedure/ | 132
31 | exp Double-Blind Method/ | 375029
32 | exp Single-Blind Method/ | 59663
33 | exp latin square design/ | 330
34 | exp Placebos/ | 302126
35 | exp Placebo Effect/ | 9028
36 | exp comparative study/ | 2625586
37 | exp Cohort Studies/ | 1940158
38 | exp longitudinal study/ | 303249
39 | exp retrospective study/ | 1069095
40 | exp prospective study/ | 836601
41 | case report/ | 3441589
42 | ((evidence adj based) or (meta adj analys*) or (systematic* adj3 review*) or (control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) adj3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case adj3 report)).mp,pt. | 17709671
43 | or/24–42 | 19397581
44 | 23 and 43 | 4197
45 | limit 44 to (“preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19–24 and 19–44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) [Limit not valid in Embase,CCTR,CDSR; records were retained] | 4118
46 | limit 45 to (preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years> or adult <18 to 64 years> or aged <65+ years>) [Limit not valid in Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,CCTR,CDSR; records were retained] | 3736
47 | from 46 keep 1–1225 | 1225
48 | ((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) adj2 (year or years)).mp. | 2161044
49 | 48 and child*.mp. | 744191
50 | (adult or adults or “middle age” or “middle aged” or elderly or geriatric*).mp. | 12223883
51 | 44 and (49 or 50) | 3087
52 | 47 or 51 | 3303
53 | remove duplicates from 52 | 2782

### Scopus

TITLE-ABS-KEY(asthma*)

TITLE-ABS-KEY(“airway nitric oxide” OR “airway NO” OR “airway oxide” OR “breath nitric oxide” OR “breath NO” OR “breath oxide” OR “breathed nitric oxide” OR “breathed NO” OR “breathed oxide” OR “breathing nitric oxide” OR “breathing NO” OR “breathing oxide” OR “exhaled nitric oxide” OR “exhaled NO” OR “exhaled oxide” OR FeNO OR “lung nitric oxide” OR “lung NO” OR “lung oxide” OR “pulmonary nitric oxide” OR “pulmonary NO” OR “pulmonary oxide” OR “respiration nitric oxide” OR “respiration NO” OR “respiration oxide” OR “respiratory nitric oxide” OR “respiratory NO” OR “respiratory oxide”)

TITLE-ABS-KEY((“respired air” W/3 pressure) or ((hyperreactiv* or hyperrespons* or respons*) W/3 (SABA or “short-acting beta2 agonist*”)) or (breath W/3 measur*) or (diagnos* W/3 (accuracy or accurate)) or bronchoprovocat* or eosinophil* or mecholine or mecholyl or metacholine or methacholine or methacholinium or methylcholine or “peak expiration flow*” or “peak expiratory flow*” or “peak flow*” or spirometr*)

1 and 2 and 3

TITLE-ABS-KEY(arter* OR blood OR cardiac OR cardial OR heart OR plasma OR plasmas OR serum OR vascular* OR vein* OR vessel*)

4 and not 5

TITLE-ABS-KEY((evidence W/1 based) or (meta W/1 analys*) or (systematic* W/3 review*) or (control* W/3 study) or (control* W/3 trial) or (randomized W/3 study) or (randomized W/3 trial) or (randomised W/3 study) or (randomised W/3 trial) or “pragmatic clinical trial” or (doubl* W/1 blind*) or (doubl* W/1 mask*) or (singl* W/1 blind*) or (singl* W/1 mask*) or (tripl* W/1 blind*) or (tripl* W/1 mask*) or (trebl* W/1 blind*) or (trebl* W/1 mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) W/3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case W/3 report))

TITLE-ABS-KEY((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) W/2 (year or years))

TITLE-ABS-KEY(child*)

TITLE-ABS-KEY(adult or adults or “middle age” or “middle aged” or elderly or geriatric*)

6 and 7 and ((8 and 9) or 10)

DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)

11 not 12

PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)

13 not 14

## KQ 1b

### Ovid

Database(s): Embase 1988 to 2016 Week 30, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present, EBM Reviews - Cochrane Central Register of Controlled Trials June 2016, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to July 20, 2016

### Search Strategy

# | Searches | Results
1 | exp Asthma/ | 308141
2 | asthma*.mp. | 387608
3 | 1 or 2 | 387722
4 | (“airway nitric oxide” or “airway NO” or “airway oxide” or “breath nitric oxide” or “breath NO” or “breath oxide” or “breathed nitric oxide” or “breathed NO” or “breathed oxide” or “breathing nitric oxide” or “breathing NO” or “breathing oxide” or “exhaled nitric oxide” or “exhaled NO” or “exhaled oxide” or FeNO or “lung nitric oxide” or “lung NO” or “lung oxide” or “pulmonary nitric oxide” or “pulmonary NO” or “pulmonary oxide” or “respiration nitric oxide” or “respiration NO” or “respiration oxide” or “respiratory nitric oxide” or “respiratory NO” or “respiratory oxide”).mp. | 100229
5 | exp Spirometry/ | 48927
6 | exp Peak Expiratory Flow Rate/ | 17248
7 | exp symptom assessment/ | 5377
8 | ((“respired air” adj3 pressure) or ((assess* or evaluat*) adj3 (symptom* or asthma* or control*)) or (breath adj3 measur*) or ACQ or “Asthma Control Questionnaire” or monitor* or “peak expiration flow*” or “peak expiratory flow*” or “peak flow*” or spirometr*).mp. | 2011076
9 | 5 or 6 or 7 or 8 | 2011755
10 | 3 and 4 and 9 | 7945
11 | exp Blood/ | 2555329
12 | blood.fs. | 1571711
13 | exp Heart/ | 879900
14 | exp Blood Vessels/ | 1373624
15 | exp Heart Diseases/ | 2263854
16 | exp Vascular Diseases/ | 3255967
17 | (arter* or blood or cardiac or cardial or heart or plasma or plasmas or serum or vascular* or vein* or vessel*).mp. | 11139543
18 | or/11–17 | 13473717
19 | 10 not 18 | 5245
20 | exp evidence based medicine/ | 904342
21 | exp meta analysis/ | 183265
22 | exp Meta-Analysis as Topic/ | 43341
23 | exp “systematic review”/ | 110642
24 | exp controlled study/ | 5161226
25 | exp Randomized Controlled Trial/ | 821123
26 | exp triple blind procedure/ | 132
27 | exp Double-Blind Method/ | 375029
28 | exp Single-Blind Method/ | 59663
29 | exp latin square design/ | 330
30 | exp Placebos/ | 302126
31 | exp Placebo Effect/ | 9028
32 | exp comparative study/ | 2625586
33 | exp Cohort Studies/ | 1940158
34 | exp longitudinal study/ | 303249
35 | exp retrospective study/ | 1069095
36 | exp prospective study/ | 836601
37 | case report/ | 3441589
38 | ((evidence adj based) or (meta adj analys*) or (systematic* adj3 review*) or (control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) adj3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case adj3 report)).mp,pt. | 17709671
39 | or/20–38 | 19397581
40 | 19 and 39 | 4326
41 | limit 40 to (“preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19–24 and 19–44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) [Limit not valid in Embase,CCTR,CDSR; records were retained] | 4252
42 | limit 41 to (preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years> or adult <18 to 64 years> or aged <65+ years>) [Limit not valid in Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,CCTR,CDSR; records were retained] | 3857
43 | from 42 keep 1–1267 | 1267
44 | ((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) adj2 (year or years)).mp. | 2161044
45 | 44 and child*.mp. | 744191
46 | (adult or adults or “middle age” or “middle aged” or elderly or geriatric*).mp. | 12223883
47 | 40 and (45 or 46) | 3101
48 | 43 or 47 | 3346
49 | remove duplicates from 48 | 2797

### Scopus

TITLE-ABS-KEY(asthma*)

TITLE-ABS-KEY(“airway nitric oxide” OR “airway NO” OR “airway oxide” OR “breath nitric oxide” OR “breath NO” OR “breath oxide” OR “breathed nitric oxide” OR “breathed NO” OR “breathed oxide” OR “breathing nitric oxide” OR “breathing NO” OR “breathing oxide” OR “exhaled nitric oxide” OR “exhaled NO” OR “exhaled oxide” OR FeNO OR “lung nitric oxide” OR “lung NO” OR “lung oxide” OR “pulmonary nitric oxide” OR “pulmonary NO” OR “pulmonary oxide” OR “respiration nitric oxide” OR “respiration NO” OR “respiration oxide” OR “respiratory nitric oxide” OR “respiratory NO” OR “respiratory oxide”)

TITLE-ABS-KEY((“respired air” W/3 pressure) or ((assess* or evaluat*) W/3 (symptom* or asthma* or control*)) or (breath W/3 measur*) or ACQ or “Asthma Control Questionnaire” or monitor* or “peak expiration flow*” or “peak expiratory flow*” or “peak flow*” or spirometr*)

1 and 2 and 3

TITLE-ABS-KEY(arter* OR blood OR cardiac OR cardial OR heart OR plasma OR plasmas OR serum OR vascular* OR vein* OR vessel*)

4 and not 5

TITLE-ABS-KEY((evidence W/1 based) or (meta W/1 analys*) or (systematic* W/3 review*) or (control* W/3 study) or (control* W/3 trial) or (randomized W/3 study) or (randomized W/3 trial) or (randomised W/3 study) or (randomised W/3 trial) or “pragmatic clinical trial” or (doubl* W/1 blind*) or (doubl* W/1 mask*) or (singl* W/1 blind*) or (singl* W/1 mask*) or (tripl* W/1 blind*) or (tripl* W/1 mask*) or (trebl* W/1 blind*) or (trebl* W/1 mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) W/3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case W/3 report))

TITLE-ABS-KEY((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) W/2 (year or years))

TITLE-ABS-KEY(child*)

TITLE-ABS-KEY(adult or adults or “middle age” or “middle aged” or elderly or geriatric*)

6 and 7 and ((8 and 9) or 10)

DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)

11 and not 12

PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)

#13 and not #14

## KQ 1c

### Ovid

Database(s): Embase 1988 to 2016 Week 30, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present, EBM Reviews - Cochrane Central Register of Controlled Trials June 2016, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to July 20, 2016

### Search Strategy

# | Searches | Results
1 | exp Asthma/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy] | 47695
2 | exp asthma/dm, dt, rt, su, th [Disease Management, Drug Therapy, Radiotherapy, Surgery, Therapy] | 56442
3 | asthma*.mp. | 387624
4 | (drug* or pharmacotherap* or medication* or agent* or chemotherap* or intervention* or manag* or microbicid* or prevent* or radiotherap* or surg* or resect* or operat* or repair* or reconstruction* or therap* or treat*).mp. | 24384025
5 | 3 and 4 | 249963
6 | 1 or 2 or 5 | 261247
7 | (“airway nitric oxide” or “airway NO” or “airway oxide” or “breath nitric oxide” or “breath NO” or “breath oxide” or “breathed nitric oxide” or “breathed NO” or “breathed oxide” or “breathing nitric oxide” or “breathing NO” or “breathing oxide” or “exhaled nitric oxide” or “exhaled NO” or “exhaled oxide” or FeNO or “lung nitric oxide” or “lung NO” or “lung oxide” or “pulmonary nitric oxide” or “pulmonary NO” or “pulmonary oxide” or “respiration nitric oxide” or “respiration NO” or “respiration oxide” or “respiratory nitric oxide” or “respiratory NO” or “respiratory oxide”).mp. | 100229
8 | exp Eosinophils/ | 55216
9 | exp Eosinophil/ | 55216
10 | exp eosinophil count/ | 7771
11 | exp sputum examination/or exp sputum/or exp sputum level/or exp sputum analysis/ | 53693
12 | exp Bronchoalveolar Lavage Fluid/ | 66065
13 | exp Skin Tests/ | 109868
14 | exp Hypersensitivity/di [Diagnosis] | 94630
15 | exp sensitization/ | 49920
16 | exp allergy test/ | 3670
17 | exp Immunoglobulin E/ | 95525
18 | (((allerg* or skin or hypersensitivit* or sensitiz*) adj3 test*) or “alveolar lavage” or “bronchial lavage” or “bronchoalveolar lavage” or eosinophil* or expectorate or IgE or “immunoglobulin e” or “lung lavage” or “lung washing” or “pulmonary lavage” or “pulmonary washing” or sputum).mp. | 495523
19 | or/8–18 | 619799
20 | 6 and 7 and 19 | 4530
21 | exp Blood/ | 2555329
22 | blood.fs. | 1571711
23 | exp Heart/ | 879900
24 | exp Blood Vessels/ | 1373624
25 | exp Heart Diseases/ | 2263854
26 | exp Vascular Diseases/ | 3255967
27 | (arter* or blood or cardiac or cardial or heart or plasma or plasmas or serum or vascular* or vein* or vessel*).mp. | 11140330
28 | or/21–27 | 13474504
29 | 20 not 28 | 2127
30 | exp evidence based medicine/ | 904342
31 | exp meta analysis/ | 183265
32 | exp Meta-Analysis as Topic/ | 43341
33 | exp “systematic review”/ | 110642
34 | exp controlled study/ | 5161226
35 | exp Randomized Controlled Trial/ | 821123
36 | exp triple blind procedure/ | 132
37 | exp Double-Blind Method/ | 375029
38 | exp Single-Blind Method/ | 59663
39 | exp latin square design/ | 330
40 | exp Placebos/ | 302126
41 | exp Placebo Effect/ | 9028
42 | exp comparative study/ | 2625586
43 | exp Cohort Studies/ | 1940158
44 | exp longitudinal study/ | 303249
45 | exp retrospective study/ | 1069095
46 | exp prospective study/ | 836601
47 | case report/ | 3441591
48 | ((evidence adj based) or (meta adj analys*) or (systematic* adj3 review*) or (control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) adj3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case adj3 report)).mp,pt. | 17710846
49 | or/30–48 | 19398758
50 | 29 and 49 | 1584
51 | limit 50 to (“preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19–24 and 19–44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) [Limit not valid in Embase,CCTR,CDSR; records were retained] | 1527
52 | limit 51 to (preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years> or adult <18 to 64 years> or aged <65+ years>) [Limit not valid in Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,CCTR,CDSR; records were retained] | 1324
53 | from 52 keep 1–652 | 652
54 | ((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) adj2 (year or years)).mp. | 2161258
55 | 54 and child*.mp. | 744238
56 | (adult or adults or “middle age” or “middle aged” or elderly or geriatric*).mp. | 12224142
57 | 50 and (55 or 56) | 1050
58 | 53 or 57 | 1191
59 | remove duplicates from 58 | 1007

### Scopus

TITLE-ABS-KEY(asthma*)

TITLE-ABS-KEY(drug* or pharmacotherap* or medication* or agent* or chemotherap* or intervention* or manag* or microbicid* or prevent* or radiotherap* or surg* or resect* or operat* or repair* or reconstruction* or therap* or treat*)

TITLE-ABS-KEY(“airway nitric oxide” OR “airway NO” OR “airway oxide” OR “breath nitric oxide” OR “breath NO” OR “breath oxide” OR “breathed nitric oxide” OR “breathed NO” OR “breathed oxide” OR “breathing nitric oxide” OR “breathing NO” OR “breathing oxide” OR “exhaled nitric oxide” OR “exhaled NO” OR “exhaled oxide” OR FeNO OR “lung nitric oxide” OR “lung NO” OR “lung oxide” OR “pulmonary nitric oxide” OR “pulmonary NO” OR “pulmonary oxide” OR “respiration nitric oxide” OR “respiration NO” OR “respiration oxide” OR “respiratory nitric oxide” OR “respiratory NO” OR “respiratory oxide”)

TITLE-ABS-KEY(((allerg* or skin or hypersensitivit* or sensitiz*) W/3 test*) or “alveolar lavage” or “bronchial lavage” or “bronchoalveolar lavage” or eosinophil* or expectorate or IgE or “immunoglobulin e” or “lung lavage” or “lung washing” or “pulmonary lavage” or “pulmonary washing” or sputum)

1 and 2 and 3 and 4

TITLE-ABS-KEY(arter* OR blood OR cardiac OR cardial OR heart OR plasma OR plasmas OR serum OR vascular* OR vein* OR vessel*)

5 and not 6

TITLE-ABS-KEY((evidence W/1 based) or (meta W/1 analys*) or (systematic* W/3 review*) or (control* W/3 study) or (control* W/3 trial) or (randomized W/3 study) or (randomized W/3 trial) or (randomised W/3 study) or (randomised W/3 trial) or “pragmatic clinical trial” or (doubl* W/1 blind*) or (doubl* W/1 mask*) or (singl* W/1 blind*) or (singl* W/1 mask*) or (tripl* W/1 blind*) or (tripl* W/1 mask*) or (trebl* W/1 blind*) or (trebl* W/1 mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) W/3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case W/3 report))

TITLE-ABS-KEY((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) W/2 (year or years))

TITLE-ABS-KEY(child*)

TITLE-ABS-KEY(adult or adults or “middle age” or “middle aged” or elderly or geriatric*)

7 and 8 and ((9 and 10) or 11)

DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)

12 and not 13

PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)

14 and not 15

## KQ 1d

### Ovid

Database(s): Embase 1988 to 2016 Week 30, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present, EBM Reviews - Cochrane Central Register of Controlled Trials June 2016, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to July 20, 2016

### Search Strategy

# | Searches | Results
1 | exp Asthma/dh, dt, rt, su, th [Diet Therapy, Drug Therapy, Radiotherapy, Surgery, Therapy] | 47695
2 | exp asthma/dm, dt, rt, su, th [Disease Management, Drug Therapy, Radiotherapy, Surgery, Therapy] | 56442
3 | asthma*.mp. | 387624
4 | (drug* or pharmacotherap* or medication* or agent* or chemotherap* or intervention* or manag* or microbicid* or prevent* or radiotherap* or surg* or resect* or operat* or repair* or reconstruction* or therap* or treat*).mp. | 24384025
5 | 3 and 4 | 249963
6 | 1 or 2 or 5 | 261247
7 | (“airway nitric oxide” or “airway NO” or “airway oxide” or “breath nitric oxide” or “breath NO” or “breath oxide” or “breathed nitric oxide” or “breathed NO” or “breathed oxide” or “breathing nitric oxide” or “breathing NO” or “breathing oxide” or “exhaled nitric oxide” or “exhaled NO” or “exhaled oxide” or FeNO or “lung nitric oxide” or “lung NO” or “lung oxide” or “pulmonary nitric oxide” or “pulmonary NO” or “pulmonary oxide” or “respiration nitric oxide” or “respiration NO” or “respiration oxide” or “respiratory nitric oxide” or “respiratory NO” or “respiratory oxide”).mp. | 100229
8 | exp Spirometry/ | 48927
9 | exp Peak Expiratory Flow Rate/ | 17248
10 | exp symptom assessment/ | 5377
11 | ((“respired air” adj3 pressure) or ((assess* or evaluat*) adj3 (symptom* or asthma* or control*)) or (breath adj3 measur*) or ACQ or “Asthma Control Questionnaire” or monitor* or “peak expiration flow*” or “peak expiratory flow*” or “peak flow*” or spirometr*).mp. | 2011281
12 | 8 or 9 or 10 or 11 | 2011960
13 | 6 and 7 and 12 | 6539
14 | exp Blood/ | 2555329
15 | blood.fs. | 1571711
16 | exp Heart/ | 879900
17 | exp Blood Vessels/ | 1373624
18 | exp Heart Diseases/ | 2263854
19 | exp Vascular Diseases/ | 3255967
20 | (arter* or blood or cardiac or cardial or heart or plasma or plasmas or serum or vascular* or vein* or vessel*).mp. | 11140330
21 | or/14–20 | 13474504
22 | 13 not 21 | 4246
23 | exp evidence based medicine/ | 904342
24 | exp meta analysis/ | 183265
25 | exp Meta-Analysis as Topic/ | 43341
26 | exp “systematic review”/ | 110642
27 | exp controlled study/ | 5161226
28 | exp Randomized Controlled Trial/ | 821123
29 | exp triple blind procedure/ | 132
30 | exp Double-Blind Method/ | 375029
31 | exp Single-Blind Method/ | 59663
32 | exp latin square design/ | 330
33 | exp Placebos/ | 302126
34 | exp Placebo Effect/ | 9028
35 | exp comparative study/ | 2625586
36 | exp Cohort Studies/ | 1940158
37 | exp longitudinal study/ | 303249
38 | exp retrospective study/ | 1069095
39 | exp prospective study/ | 836601
40 | case report/ | 3441591
41 | ((evidence adj based) or (meta adj analys*) or (systematic* adj3 review*) or (control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) adj3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case adj3 report)).mp,pt. | 17710846
42 | or/23–41 | 19398758
43 | 22 and 42 | 3621
44 | limit 43 to (“preschool child (2 to 5 years)” or “child (6 to 12 years)” or “adolescent (13 to 18 years)” or “young adult (19 to 24 years)” or “adult (19 to 44 years)” or “young adult and adult (19–24 and 19–44)” or “middle age (45 to 64 years)” or “middle aged (45 plus years)” or “all aged (65 and over)” or “aged (80 and over)”) [Limit not valid in Embase,CCTR,CDSR; records were retained] | 3567
45 | limit 44 to (preschool child <1 to 6 years> or school child <7 to 12 years> or adolescent <13 to 17 years> or adult <18 to 64 years> or aged <65+ years>) [Limit not valid in Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,CCTR,CDSR; records were retained] | 3268
46 | from 45 keep 1–897 | 897
47 | ((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) adj2 (year or years)).mp. | 2161258
48 | 47 and child*.mp. | 744238
49 | (adult or adults or “middle age” or “middle aged” or elderly or geriatric*).mp. | 12224142
50 | 43 and (48 or 49) | 2627
51 | 46 or 50 | 2789
52 | remove duplicates from 51 | 2389

### Scopus

TITLE-ABS-KEY(asthma*)

TITLE-ABS-KEY(drug* or pharmacotherap* or medication* or agent* or chemotherap* or intervention* or manag* or microbicid* or prevent* or radiotherap* or surg* or resect* or operat* or repair* or reconstruction* or therap* or treat*)

TITLE-ABS-KEY(“airway nitric oxide” OR “airway NO” OR “airway oxide” OR “breath nitric oxide” OR “breath NO” OR “breath oxide” OR “breathed nitric oxide” OR “breathed NO” OR “breathed oxide” OR “breathing nitric oxide” OR “breathing NO” OR “breathing oxide” OR “exhaled nitric oxide” OR “exhaled NO” OR “exhaled oxide” OR FeNO OR “lung nitric oxide” OR “lung NO” OR “lung oxide” OR “pulmonary nitric oxide” OR “pulmonary NO” OR “pulmonary oxide” OR “respiration nitric oxide” OR “respiration NO” OR “respiration oxide” OR “respiratory nitric oxide” OR “respiratory NO” OR “respiratory oxide”)

TITLE-ABS-KEY((“respired air” W/3 pressure) or ((assess* or evaluat*) W/3 (symptom* or asthma* or control*)) or (breath W/3 measur*) or ACQ or “Asthma Control Questionnaire” or monitor* or “peak expiration flow*” or “peak expiratory flow*” or “peak flow*” or spirometr*)

1 and 2 and 3 and 4

TITLE-ABS-KEY(arter* OR blood OR cardiac OR cardial OR heart OR plasma OR plasmas OR serum OR vascular* OR vein* OR vessel*)

5 and not 6

TITLE-ABS-KEY((evidence W/1 based) or (meta W/1 analys*) or (systematic* W/3 review*) or (control* W/3 study) or (control* W/3 trial) or (randomized W/3 study) or (randomized W/3 trial) or (randomised W/3 study) or (randomised W/3 trial) or “pragmatic clinical trial” or (doubl* W/1 blind*) or (doubl* W/1 mask*) or (singl* W/1 blind*) or (singl* W/1 mask*) or (tripl* W/1 blind*) or (tripl* W/1 mask*) or (trebl* W/1 blind*) or (trebl* W/1 mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) W/3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case W/3 report))

TITLE-ABS-KEY((“5” or “6” or “7” or “8” or “9” or “10” or “11” or “12” or “13” or “14” or “15” or “16” or “17” or five or six or seven or eight or nine or ten or eleven or twelve or thirteen or fourteen or fifteen or sixteen or seventeen) W/2 (year or years))

TITLE-ABS-KEY(child*)

TITLE-ABS-KEY(adult or adults or “middle age” or “middle aged” or elderly or geriatric*)

7 and 8 and ((9 and 10) or 11)

DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)

12 and not 13

PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)

14 and not 15

## KQ 1e

### Ovid

Database(s): Embase 1988 to 2016 Week 30, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) 1946 to Present, EBM Reviews - Cochrane Central Register of Controlled Trials June 2016, EBM Reviews - Cochrane Database of Systematic Reviews 2005 to July 20, 2016

### Search Strategy

# | Searches | Results
1 | (“airway nitric oxide” or “airway NO” or “airway oxide” or “breath nitric oxide” or “breath NO” or “breath oxide” or “breathed nitric oxide” or “breathed NO” or “breathed oxide” or “breathing nitric oxide” or “breathing NO” or “breathing oxide” or “exhaled nitric oxide” or “exhaled NO” or “exhaled oxide” or FeNO or “lung nitric oxide” or “lung NO” or “lung oxide” or “pulmonary nitric oxide” or “pulmonary NO” or “pulmonary oxide” or “respiration nitric oxide” or “respiration NO” or “respiration oxide” or “respiratory nitric oxide” or “respiratory NO” or “respiratory oxide”).mp. | 100229
2 | exp Respiratory Sounds/ | 51820
3 | (rhonchi or rhonchus or wheez*).mp. | 37161
4 | 2 or 3 | 64711
5 | exp “Predictive Value of Tests”/ | 269135
6 | (predict* or API).mp. | 2747478
7 | 5 or 6 | 2747478
8 | 1 and 4 and 7 | 499
9 | exp Blood/ | 2555329
10 | blood.fs. | 1571711
11 | exp Heart/ | 879900
12 | exp Blood Vessels/ | 1373624
13 | exp Heart Diseases/ | 2263854
14 | exp Vascular Diseases/ | 3255967
15 | (arter* or blood or cardiac or cardial or heart or plasma or plasmas or serum or vascular* or vein* or vessel*).mp. | 11140330
16 | or/9–15 | 13474504
17 | 8 not 16 | 282
18 | exp evidence based medicine/ | 904342
19 | exp meta analysis/ | 183265
20 | exp Meta-Analysis as Topic/ | 43341
21 | exp “systematic review”/ | 110642
22 | exp controlled study/ | 5161226
23 | exp Randomized Controlled Trial/ | 821123
24 | exp triple blind procedure/ | 132
25 | exp Double-Blind Method/ | 375029
26 | exp Single-Blind Method/ | 59663
27 | exp latin square design/ | 330
28 | exp Placebos/ | 302126
29 | exp Placebo Effect/ | 9028
30 | exp comparative study/ | 2625586
31 | exp Cohort Studies/ | 1940158
32 | exp longitudinal study/ | 303249
33 | exp retrospective study/ | 1069095
34 | exp prospective study/ | 836601
35 | case report/ | 3441591
36 | ((evidence adj based) or (meta adj analys*) or (systematic* adj3 review*) or (control* adj3 study) or (control* adj3 trial) or (randomized adj3 study) or (randomized adj3 trial) or (randomised adj3 study) or (randomised adj3 trial) or “pragmatic clinical trial” or (doubl* adj blind*) or (doubl* adj mask*) or (singl* adj blind*) or (singl* adj mask*) or (tripl* adj blind*) or (tripl* adj mask*) or (trebl* adj blind*) or (trebl* adj mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) adj3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case adj3 report)).mp,pt. | 17710846
37 | or/18–36 | 19398758
38 | 17 and 37 | 247
39 | limit 38 to (“all infant (birth to 23 months)” or “newborn infant (birth to 1 month)” or “infant (1 to 23 months)” or “preschool child (2 to 5 years)”) [Limit not valid in Embase,CCTR,CDSR; records were retained] | 234
40 | limit 39 to (infant or preschool child <1 to 6 years>) [Limit not valid in Ovid MEDLINE(R),Ovid MEDLINE(R) In-Process,CCTR,CDSR; records were retained] | 182
41 | from 40 keep 1–31 | 31
42 | ((“1” or “2” or “3” or “4” or one or two or three or four) adj2 (year or years)).mp. | 1727622
43 | 42 and child*.mp. | 432826
44 | (newborn* or neonat* or infant* or toddler*).mp. | 2225413
45 | 38 and (43 or 44) | 113
46 | 41 or 45 | 117
47 | remove duplicates from 46 | 105

### Scopus

TITLE-ABS-KEY(“airway nitric oxide” OR “airway NO” OR “airway oxide” OR “breath nitric oxide” OR “breath NO” OR “breath oxide” OR “breathed nitric oxide” OR “breathed NO” OR “breathed oxide” OR “breathing nitric oxide” OR “breathing NO” OR “breathing oxide” OR “exhaled nitric oxide” OR “exhaled NO” OR “exhaled oxide” OR FeNO OR “lung nitric oxide” OR “lung NO” OR “lung oxide” OR “pulmonary nitric oxide” OR “pulmonary NO” OR “pulmonary oxide” OR “respiration nitric oxide” OR “respiration NO” OR “respiration oxide” OR “respiratory nitric oxide” OR “respiratory NO” OR “respiratory oxide”)

TITLE-ABS-KEY(rhonchi or rhonchus or wheez*)

TITLE-ABS-KEY(predict* or API)

1 and 2 and 3

TITLE-ABS-KEY(arter* OR blood OR cardiac OR cardial OR heart OR plasma OR plasmas OR serum OR vascular* OR vein* OR vessel*)

4 and not 5

TITLE-ABS-KEY((evidence W/1 based) or (meta W/1 analys*) or (systematic* W/3 review*) or (control* W/3 study) or (control* W/3 trial) or (randomized W/3 study) or (randomized W/3 trial) or (randomised W/3 study) or (randomised W/3 trial) or “pragmatic clinical trial” or (doubl* W/1 blind*) or (doubl* W/1 mask*) or (singl* W/1 blind*) or (singl* W/1 mask*) or (tripl* W/1 blind*) or (tripl* W/1 mask*) or (trebl* W/1 blind*) or (trebl* W/1 mask*) or “latin square” or placebo* or nocebo* or “comparative study” or “comparative survey” or “comparative analysis” or cohort* or “longitudinal study” or “longitudinal survey” or “longitudinal analysis” or “longitudinal evaluation” or longitudinal* or ((retrospective or “ex post facto”) W/3 (study or survey or analysis or design)) or retrospectiv* or “prospective study” or “prospective survey” or “prospective analysis” or prospectiv* or “clinical study” or “clinical trial” or “multicenter study” or “multi-center study” or ((study or trial or random* or control*) and compar*) or (case W/3 report))

TITLE-ABS-KEY ((“1” or “2” or “3” or “4” or one or two or three or four) W/2 (year or years))

TITLE-ABS-KEY(child*)

TITLE-ABS-KEY(newborn* or neonat* or infant* or toddler*)

6 and 7 and ((8 and 9) or 10)

DOCTYPE(le) OR DOCTYPE(ed) OR DOCTYPE(bk) OR DOCTYPE(er) OR DOCTYPE(no) OR DOCTYPE(sh)

11 and not 12

PMID(0*) OR PMID(1*) OR PMID(2*) OR PMID(3*) OR PMID(4*) OR PMID(5*) OR PMID(6*) OR PMID(7*) OR PMID(8*) OR PMID(9*)

13 and not 14