# Abbreviations

Abbreviation: Definition
ACT: Asthma control test
ACQ: Asthma Control Questionnaire
AUC: Area under the curve
API: Asthma predictive index
AQLQ: Asthma quality of life questionnaire
ATS: American Thoracic Society
AUC: Area under the curve
BMI: Body mass index
DOR: Diagnostic odds ratio
EBC: Exhaled breath condensate
ED: Emergency Department
ERS: European Respiratory Society
FEF25–75: Forced expiratory flow at 25–75% of forced vital capacity
FeNO: Fraction exhaled nitric oxide
FEV_1_: Forced expiratory volume in the first second
FVC: Forced vital capacity
GINA: Global Initiative for Asthma
HSROC: Hierarchical summary receiver operating characteristic
ICS: Inhaled corticosteroid
ICU: Intensive care unit
IgE: Immunoglobulin E
IQR: Interquartile range
KQ: Key question
LABA: Long acting beta agonist
LR+: Positive likelihood ratio
LR-: Negative likelihood ratio
LTRA: Leukotriene receptor antagonist
NO: Nitric oxide
NPV: Negative predictive value
OR: Odds ratio
PACQLQ: Pediatric asthma caregiver’s quality of life questionnaire
PAQLQ: Pediatric asthma quality of life questionnaire
PC15: Provocation concentration causing a 15% fall in FEV_1_
PC20: Provocation concentration causing a 20% fall in FEV_1_
PD15: Provocation dose causing a 15% decline in FEV_1_
PD20: Provocation dose causing a 20% decline in FEV_1_
PEF: Peak expiratory flow
PH: Potential hydrogen
PIAMA: Prevention and Incidence of Asthma and Mite Allergy
PICOTS: Patient, Intervention, Comparison, Outcome, Timing, Settings
ppb: Part per billion
PPV: Positive predictive value
QALY: Quality-adjusted life year
QUADAS-2: Quality Assessment of Diagnostic Accuracy Studies-2
R: Correlation
RCT: Randomized controlled trial
ROC curve: Receiver operating characteristic curve
SD: Standard deviation
SOE: Strength of evidence