# Results

## Search Results

Our search for Key Question (KQ) 1a–c identified 10,763 nonduplicate records, of which 913 required full text review after title and abstract screening, and 74 met eligibility criteria for inclusion in this review (Figure 2). These 74 citations reported results from 41 unique studies, 39 randomized controlled trials (RCTs) and 2 observational studies. Of these 41 studies, 6 met criteria for KQ1a (reported in 7 citations),^44–50^ 11 met criteria for KQ1b (reported in 18 citations),^51–68^ and 24 met criteria for KQ1c (reported in 49 citations).^69–117^ Citations excluded at the full-text review stage are presented in Appendix B.

Figure 2 Literature flow diagram for Key Questions 1a, 1b, and 1c

This figure depicts literature flow for key questions 1a, 1b and 1c. Records odentified from the database searching found 5633 citation in Medline, 4690 citations in Embase and 3960 citation in Central. An additional 6 citations were found as a result of manual searching. After duplicates were removed, 10,763 remained and were screened at the abstract level. A total of 9850 citations were excluded, 3460 because they were not human studies, 1449 because of study design, 563 because they were not the target population, 3908 because they were not the intervention of interest, 321 becasue they lacked an English language abstract, 149 becasue they were duplicate citations that remained. A total of 913 citation remained and were screened at the full text level. A total of 839 citation were excluded, 208 becasue they were not human studies, 57 because of study design, 46 because they were not the target population, 442 because they were not the intervention of interest, 10 because they did not report an outcome of interest, 3 becasue they lacked an English language abstract, 5 becasue they were absracts without full text publication, 7 becasue they were duplicates that reminaed, and 61 becaue they citations were irretreviable. A total of 74 citation were finally included in this review, representing 43 unique studies.

Our search for KQ2a–c identified 854 nonduplicate records, of which 146 required full text review after title and abstract screening, and 58 met eligibility criteria for inclusion in this review (Figure 3). These 58 citations reported results from 15 unique studies, all of which were RCTs. Of these 15 RCTs, 8 met criteria for KQ2a (reported in 29 citations),^27,118–145^ 8 met criteria for KQ2b (reported in 21 citations),^27,118–120,124–126,130–137,144–149^ and 4 met criteria for KQ2c (reported in 26 citations).^145,150–174^ Citations excluded at the full-text review stage are presented in Appendix B.

Figure 3 Literature flow diagram for Key Questions 2a, 2b, and 2c

This figure depicts literature flow for key questions 2a, 2b and 2c. Records odentified from the database searching found 340 citation in Medline, 504 citations in Embase and 225 citation in Central. An additional 16 citations were found as a result of manual searching. After duplicates were removed, 854 remained and were screened at the abstract level. A total of 708 citations were excluded, 406 becasuse they were not human studies, 60 because of study design, 156 because they were not the target population, 35 because they were not the intervention of interest, 33 becasue they lacked an English language abstract, 18 becasue they were duplicate citations that remained. A total of 146 citation remained and were screened at the full text level. A total of 88 citation were excluded, 34 becasue they were not human studies, 4 because of study design, 15 because they were not the target population, 14 because they were not the intervention of interest, 17 becasue they did not report an outcome of interest, 3 because they were abstract only without full text publication, and 1 becasue it was duplicate citation that remained. A total of 58 citation were finally included in this review, representing 15 unique studies.

In total, 56 unique studies were included, 54 RCTs and 2 observational studies. The distribution of studies by study design and age category are presented in Table 5.

Table 5 Number of studies included per KQ, study design, and age group

| Characteristic | KQ1a | KQ1b | KQ1c (RCT/NonRCT) | KQ2a | KQ2b | KQ2c
Study Design | RCTs | 6 | 11 | 22 | 8 | 8 | 4
Study Design | Non RCTs | 0 | 0 | 2 | 0 | 0 | 0
Age Group | ≥12y | NA | 9 | 22 (20/2) | 8 | 8 | 4
Age Group | 5–11y | NA | 0 | 0 | NA | NA | NA
Age Group | 0–4y | 5 | 0 | 0 | NA | NA | NA
Age Group | Mixed | 1 | 2 | 2 (2/0) | 0 | 0 | 0
TOTAL | | 6 | 11 | 24 | 8 | 8 | 4

KQ = Key Question; NA = not applicable; RCT = randomized controlled trial; y = years

## Organization of This Report

The results are presented in order of KQ and furthermore by intervention/comparator combinations. The same outcomes were sought from all studies regardless of the KQ and are reported when data were available. Supporting tables and figures relevant to the results appear in Tables 6 through 27 and in Appendices C–F, including study and population characteristics, study level outcomes data, study risk of bias assessments and details regarding the strength of evidence grading of each outcome.

Table 21 Evidence overview for KQ2a, LAMA as add-on to ICS versus placebo

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 5 RCTs^118–120,122,123^ (3036) | Favors LAMA RR 0.67 (0.48 to 0.92) | High
Exacerbations | Asthma worsening^a^ | 3 RCTs^119,122,123^ (2420) | Favors LAMA RR 0.81 (0.68 to 0.97) | High
Death | All-cause | 6 RCTs^119–123^ (3065) | No deaths occurred | Insufficient (no events occurred)
Death | Asthma-specific | 6 RCTs^119–123^ (3065) | No deaths occurred | Insufficient (no events occurred)
Asthma control composite scores | ACQ-7 score | 4 RCTs^119,122,123^ (2304) | No difference MD −0.10 (−0.28 to 0.07) | Moderate (inconsistent)
Asthma control composite scores | ACQ-7 responder^b^ | 5 RCTs^119–123^ (2680) | No difference RR 1.08 (0.96 to 1.21) | Moderate (inconsistent)
Spirometry | FEV1 peak | 4 RCTs^119,122,123^ (2310) | Favors LAMA MD 0.18 (0.13 to 0.24) | High
Spirometry | FEV1 trough | 7 RCTs^119–123^ (3173) | Favors LAMA MD 0.13 (0.10 to 0.17) | High
Spirometry | FEV1 AUC | 3 RCTs^119,122,123^ (2310) | Favors LAMA MD 0.18 (0.13 to 0.23) | High
Spirometry | FEV1 % predicted | 1 RCT^122^ (457) | Favors LAMA [underlined: Paggiaro, 2016]^112^ MD 3.5 (1.58 to 5.42) | Low (unknown consistency)
Spirometry | FVC peak | 3 RCTs^119,123^ (1853) | Favors LAMA MD 0.11 (0.05 to 0.18) | High
Spirometry | FVC trough | 5 RCTs^118,119,121,123^ (2390) | Favors LAMA MD 0.08 (0.04 to 0.13) | High
Spirometry | FVC AUC | 3 RCTs^119,123^ 1859) | Favors LAMA MD 0.11 (0.05 to 0.17) | High
Quality of life | AQLQ score | 2 RCTs^119^ (1461) | No difference [underlined: Kerstjens Trial 1, 2015]^119^ MD 0.07 (−0.06 to 0.20) [underlined: Kerstjens Trial 2, 2015]^119^ MD 0.11 (−0.03 to 0.25) | High
Quality of life | AQLQ-mini score | 1 RCT^118^ (253) | No difference [underlined: Bateman, 2011]^118^ MD −0.09 (−0.27 to 0.08) | Low (unknown consistency)^c^
Health care utilization | Rescue medication use, number of puffs in 24h | 7 RCTs^119–123^ (3104) | No difference MD −0.08 (−0.23 to 0.07) | Moderate (inconsistent)

ACQ = Asthma Control Questionnaire; AQLQ = Asthma Quality of Life Questionnaire; AUC = area under the curve; CI = confidence interval; FEV1 = forced expiratory volume in one second; ICS = inhaled corticosteroid; LAMA = long-acting muscarinic antagonist; MD = mean difference; n = patient sample size; PEF = peak expiratory flow; RCT = randomized controlled trial; RR = relative risk

a Defined as progressive increase in asthma symptoms compared to day-to-day symptoms or a decrease in morning PEF greater than or equal to 30 percent for 2 or more days

b Defined as a decrease in score by 0.5 or more

c Strength of evidence was rated low even in the setting of one domain downgraded because of the small sample size within a single trial for this outcome and thus lack of confidence in the true effect estimate.

Table 22 Evidence overview for KQ2a, LAMA as add-on to ICS versus doubling the ICS dose

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 1 RCT^27^ (210) | No difference [underlined: Peters, 2010]^27^ RR 0.48 (0.12 to 1.84) | Low (unknown consistency, imprecise)
Exacerbations | Requiring oral corticosteroid or increase in ICS or other asthma medication | 1 RCT^27^ (210) | No difference [underlined: Peters, 2010]^27^ RR 0.32 (0.09 to 1.13) | Low (unknown consistency, imprecise)
Asthma control composite scores | ACQ-6 score | 1 RCT^27^ (127) | No difference [underlined: Peters, 2010]^27^ MD −0.15 (−0.45 to 0.15) | Low (unknown consistency)^a^
Spirometry | FEV1 trough | 1 RCT^27^ (118) | No difference [underlined: Peters, 2010]^27^ MD 0.09 (−0.20 to 0.38) | Low (unknown consistency)^a^
Quality of life | AQLQ score | 1 RCT^27^ (122) | No difference [underlined: Peters, 2010]^27^ MD 0.04 (−0.32 to 0.40) | Low (unknown consistency)^a^

ACQ = Asthma Control Questionnaire; AQLQ = Asthma Quality of Life Questionnaire; AUC = area under the curve; CI = confidence interval; FEV1 = forced expiratory volume in one second; ICS = inhaled corticosteroid; LAMA = long-acting muscarinic antagonist; MD = mean difference; n = patient sample size; PEF = peak expiratory flow; RCT = randomized controlled trial; RR = relative risk

a Strength of evidence was rated low even in the setting of one domain downgraded because of the small sample size within a single trial for this outcome and thus lack of confidence in the true effect estimate.

Table 23 Evidence overview for KQ2b, LAMA versus LABA as add-on to ICS

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 4 RCTs^27,118–120^ (2574) | No difference RR 0.87 (0.53 to 1.42) | Low (inconsistent, imprecise)
Exacerbations | Asthma worsening^a^ | 1 RCT^119^ (1577) | No difference [underlined: Kerstjens Trial 1 & 2, 2015]^119^ RR 1.00 (0.84 to 1.20) | Moderate (unknown consistency)
Exacerbations | Requiring oral corticosteroid or increase in ICS or other asthma medication | 1 RCT^27^ (210) | No difference [underlined: Peters, 2010]^27^ RR 0.60 (0.15 to 2.42) | Low (unknown consistency imprecise)
Death | All-cause | 4 RCTs^119,120,148^ (3572) | No difference OR 7.50 (0.78 to 72.27) | Low (inconsistent, imprecise)
Death | Asthma-specific | 4 RCTs^119,120,148^ (3572) | No difference OR 7.49 (0.47 to 119.86) | Low (inconsistent, imprecise)
Asthma control composite scores | ACQ-6 score | 1 RCT^27^ (126) | No difference [underlined: Peters, 2010]^27^ MD 0.30 (0.00 to 0.60) | Low (unknown consistency, imprecise)
Asthma control composite scores | ACQ-7 score | 2 RCTs^119^ (1577) | No difference [underlined: Kerstjens Trial 1, 2015]^119^ MD 0.04 (−0.05 to 0.13) [underlined: Kerstjens Trial 2, 2015]^119^ MD 0.00 (−0.09 to 0.09) | High
Asthma control composite scores | ACQ-7 responder^b^ | 2 RCTs^119^ (1577) | No difference [underlined: Kerstjens Trial 1, 2015]^119^ RR 1.06 (0.96 to 1.18) [underlined: Kerstjens Trial 2, 2015]^119^ RR 1.00 (0.90 to 1.12) | High
Spirometry | FEV1 peak | 2 RCTs^119^ (1483) | No difference [underlined: Kerstjens Trial 1, 2015]^119^ MD 0.004 (−0.05 to 0.05) [underlined: Kerstjens Trial 2, 2015]^119^ MD 0.014 (−0.03 to 0.06) | High
Spirometry | FEV1 trough | 6 RCTs^27,118–120,148^ (3261) | No difference MD 0.02 (−0.03 to 0.06) | High
Spirometry | FEV1 AUC | 2 RCTs^119^ (1483) | No difference [underlined: Kerstjens Trial 1, 2015]^119^ MD −0.004 (−0.05 to 0.04) [underlined: Kerstjens Trial 2, 2015]^119^ MD 0.004 (−0.04 to 0.05) | High
Spirometry | FEV1 % predicted | 3 RCTs^146–148^ (542) | No difference MD −4.54 (−12.69 to 3.61) | Low (medium ROB, inconsistent)
Spirometry | FVC peak | 2 RCTs^119^ (1483) | No difference [underlined: Kerstjens Trial 1, 2015]^119^ MD 0.02 (−0.04 to 0.07) [underlined: Kerstjens Trial 2, 2015]^119^ MD −0.02 (−0.07 to 0.03) | High
Spirometry | FVC trough | 3 RCTs^118–119^ (1745) | No difference MD 0.02 (0.00 to 0.05) | High
Spirometry | FVC AUC | 2 RCTs^119^ (1483) | No difference [underlined: Kerstjens Trial 1, 2015]^119^ MD 0.005 (−0.05 to 0.06) [underlined: Kerstjens Trial 2, 2015]^119^ MD −0.03 (−0.09 to 0.03) | High
Quality of life | AQLQ score | 4 RCTs^27,118,119^ (1982) | No difference MD −0.06 (−0.15 to 0.03) | High
Quality of life | AQLQ-mini score | 1 RCT^118^ (262) | No difference [underlined: Bateman, 2011]^118^ MD −0.15 (−0.32 to 0.02) | Low (unknown consistency)^c^
Health care utilization | Rescue medication use, number of puffs in 24h | 7 RCT^118–120,146–148^ (2450) | No difference MD 0.61 (−0.12 to 1.35) | Low (inconsistent, imprecise)

ACQ = Asthma Control Questionnaire; AQLQ = Asthma Quality of Life Questionnaire; AUC = area under the curve; CI = confidence interval; FEV1 = forced expiratory volume in one second; FVC = forced vital capacity; ICS = inhaled corticosteroid; LABA = long-acting β_2_-agonist; LAMA = long-acting muscarinic antagonist; MD = mean difference; n = patient sample size; RCT = randomized controlled trial; ROB = risk of bias; RR = relative risk

a Defined as progressive worsening of asthma symptoms compared to day-to-day symptoms or a decrease in morning PEF greater than or equal to 30 percent for 2 or more days

b Defined as a decrease in score by 0.5 or more

c Graded with low strength of evidence in the setting of one domain downgraded due to the small sample size in a single trial and lack of confidence in the true effect estimate.

Table 24 Evidence overview for KQ2b, LAMA versus montelukast as add-on to ICS

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Spirometry | FEV1 % predicted | 2 RCTs^146,147^ (214) | Favors montelukast [underlined: Rajanandh, 2014]^146^ MD −2.14 (−2.93 to −1.35) [underlined: Rajanandh, 2015]^147^ MD −0.87 (−2.77 to 1.03) | Moderate (medium ROB)
Health care utilization | Rescue medication use, number of puffs in 24h | 2 RCTs^146,147^ (214) | Favors montelukast [underlined: Rajanandh, 2014]^146^ MD 0.26 (−0.25 to 0.77) [underlined: Rajanandh, 2015]^147^ MD 1.19 (0.88 to 1.50) | Low (medium ROB, inconsistent)

CI = confidence interval; FEV1 = forced expiratory volume in one second; MD = mean difference; n = patient sample size; RCT = randomized controlled trial; ROB = risk of bias; RR = relative risk

Table 25 Evidence overview for KQ2b, LAMA versus doxofylline as add-on to ICS

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Spirometry | FEV1 % predicted | 2 RCTs^146,147^ (209) | Favors doxofylline [underlined: Rajanandh, 2014]^146^ MD −3.87 (−4.6 to −3.14) [underlined: Rajanandh, 2015]^147^ MD −2.69 (−4.79 to −0.59) | Moderate (medium ROB)
Health care utilization | Rescue medication use, number of puffs in 24h | 2 RCTs^146,147^ (209) | Favors doxofylline [underlined: Rajanandh, 2014]^146^ MD 0.30 (−0.21 to 0.81) [underlined: Rajanandh, 2015]^147^ MD 1.21 (0.89 to 1.53) | Low (medium ROB, inconsistent)

CI = confidence interval; FEV1 = forced expiratory volume in one second; MD = mean difference; n = patient sample size; RCT = randomized controlled trial; ROB = risk of bias; RR = relative risk

Table 26 Evidence overview for KQ2c, LAMA added to ICS plus LABA versus ICS plus LABA

Comparison | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 3 RCTs^150,152^ (1299) | No Difference RR 0.84 (0.57 to 1.22) | Moderate (imprecise)
Exacerbations | Requiring hospitalization | 2 RCTs^150^ (907) | No difference [underlined: Kerstjens Trial 1, 2012]^150^ RR 1.33 (0.54 to 3.32) [underlined: Kerstjens Trial 2, 2012]^150^ RR 1.16 (0.47 to 2.89) | Moderate (imprecise)
Exacerbations | Asthma worsening^a^ | 3 RCTs^150,152^ (1299) | Lower with LAMA RR 0.78 (0.72 to 0.86) | High
Death | All-cause | 3 RCTs^150,152^ (1299) | No deaths occurred | Insufficient (no events occurred)
Death | Asthma-specific | 3 RCTs^150,152^ (1299) | No deaths occurred | Insufficient (no events occurred)
Asthma control composite scores | ACQ-5 responder^b^ | 1 RCT^150^ (907) | Favors LAMA [underlined: Kerstjens Trial 1 & 2, 2012]^150^ OR 1.42 (1.08 to 1.86) | Low (unknown consistency, imprecise)
Asthma control composite scores | ACQ-6 score | 1 RCT^152^ (338) | No difference [underlined: Hamelmann, 2016]^152^ MD 0.09 (−0.08 to 0.25) | Low (unknown consistency, imprecise)
Asthma control composite scores | ACQ-6 responder^b^ | 2 RCTs^150,152^ (1299) | Favors LAMA [underlined: Hamelmann, 2016]^152^ RR 1.00 (0.88 to 1.12) [underlined: Kerstjens Trial 1 & 2, 2012]^150^ OR 1.49 (1.14 to 1.90) | Low (inconsistent, imprecise)
Asthma control composite scores | ACQ-7 score | 3 RCTs^150,152^ (1301) | No Difference MD −0.07 (−0.31 to 0.17) | Moderate (inconsistent)
Asthma control composite scores | ACQ-7 responder^b^ | 2 RCTs^150,152^ (1299) | Favors LAMA [underlined: Hamelmann, 2016]^152^ RR 1.01 (0.89 to 1.14) [underlined: Kerstjens Trial 1 & 2, 2012]^150^ RR 1.28 (1.13 to 1.46) | Moderate (inconsistent)
Spirometry | FEV1 peak | 3 RCTs^150,152^ (1295) | No difference MD 0.10 (0.00 to 0.22) | Moderate (inconsistent)
Spirometry | FEV1 trough | 3 RCTs^150,152^ (1295) | No difference MD 0.07 (0.00 to 0.14) | Moderate (inconsistent)
Spirometry | FEV1 AUC | 3 RCTs^150,152^ (1295) | Favors LAMA MD 0.10 (0.01 to 0.19) | High
Spirometry | FVC peak | 3 RCTs^150,152^ (1295) | Favors LAMA MD 0.11 (0.05 to 0.17) | High
Spirometry | FVC trough | 3 RCTs^150,152^ (1295) | Favors LAMA MD 0.09 (0.03 to 0.15) | High
Spirometry | FVC AUC | 3 RCTs^150,152^ (1295) | Favors LAMA MD 0.10 (0.04 to 0.17) | High
Quality of life | AQLQ score | 2 RCTs^150^ (907) | No difference [underlined: Kerstjens Trial 1, 2012]^150^ MD 0.04 (−0.13 to 0.20) [underlined: Kerstjens Trial 2, 2012]^150^ MD 0.14 (−0.03 to 0.31) | High
Quality of life | AQLQ responder^c^ | 1 RCT^150^ (907) | Favors LAMA [underlined: Kerstjens Trial 1 & 2, 2012]^150^ RR 1.62 (1.34 to 1.96) | Moderate (imprecise)
Health care utilization | Rescue medication use, number of puffs in 24h | 3 RCTs^150,152^ (1302) | No difference MD −0.10 (−0.37 to 0.18) | Moderate (inconsistent)

ACQ = Asthma Control Questionnaire; AQLQ = Asthma Quality of Life Questionnaire; AUC = area under the curve; CI = confidence interval; h = hours; FEV1 = forced expiratory volume in one second; FVC = forced vital capacity; LAMA = long-acting muscarinic antagonist; MD = mean difference; n = sample size; OR = odds ratio; PEF = peak expiratory flow; RCT = randomized controlled trial; RR = relative risk

a Defined as progressive increase in asthma symptoms compared to usual day-to-day symptoms or decrease in morning PEF greater than or equal to 30 percent for 2 or more days

b Defined as a decrease in score by 0.5 or more

c Defined as an increase in score of 0.5 or more

Table 27 Evidence overview for KQ2c, LAMA added to ICS plus LABA versus increasing ICS dose plus LABA

Comparison | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Asthma control composite scores | ACT score | 1 RCT^151^ (63) | No difference [underlined: Wang, 2012]^151^ MD −0.61 (−4.82 to 3.60) | Low (unknown consistency, imprecise)

ACT = Asthma Control Test; CI = confidence interval; h = hours; MD = mean difference; n = sample size; RCT = randomized controlled trial

## KQ1a What is the comparative effectiveness of intermittent inhaled corticosteroid (ICS) compared to no treatment, pharmacologic, or nonpharmacologic therapy in children 0 to 4 years old with recurrent wheezing?

Results of this KQ are reported separately based on whether the comparator was pharmacologic or nonpharmacologic therapy. There were two distinct pharmacologic comparators: as-needed short-acting β_2_-agonist (SABA) and ICS controller, and data were analyzed separately. We found no studies in which the comparator was nonpharmacologic therapy. While this KQ focuses on the age category of 0 to 4y, one included trial^45^ allowed enrollment of patients up to the age of 6y but because the mean age was 2y we determined the population was considered to represent that of interest.

### Key Points

- Intermittent ICS with as-needed SABA versus as-needed SABA, initiated with onset of a respiratory tract infection (RTI), reduces the risk of exacerbation requiring oral corticosteroids (moderate strength of evidence [SOE]) and improves Pediatric Asthma Caregiver’s Quality of Life Questionnaire (PACQLQ) scores (low SOE).
- Intermittent ICS with as-needed SABA versus ICS controller with as-needed SABA did not significantly differ in effect on the risk of exacerbation requiring oral corticosteroid, the risk of exacerbation requiring hospitalization or daytime or nighttime rescue medication use (all low SOE).
- There is insufficient evidence to determine the impact of intermittent ICS versus no therapy on outcomes.

### Intermittent ICS With As-Needed SABA Versus As-Needed SABA

Table 6 Evidence overview for KQ1a, intermittent ICS with as-needed SABA vs. as-needed SABA

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring oral corticosteroid therapy | 3 RCTs^44,45,48^ (324) | Favors intermittent ICS RR 0.67 (0.46 to 0.98) | Moderate (imprecise)
Exacerbations | Asthma-related acute care visits | 3 RCTs^44,45,48^ (324) | No difference RR 0.90 (0.77 to 1.05) | High
Exacerbations | Asthma-related hospital admissions | 3 RCT^44,45,48^ (324) | No difference RR 0.77 (0.06 to 9.68) | Low (inconsistent, imprecise)
Quality of life | PACQLQ score | 2 RCTs^44,48^ (270) | Favors intermittent ICS^a^ [underlined: Bacharier, 2008]^44^ MD −0.10 (−0.36 to 0.34) [underlined: Ducharme, 2009]^48^ MD 0.49 (0.10 to 0.86) | Low (inconsistent, imprecise)
Health care utilization | Daytime rescue medication use, number of inhalations/day | 1 RCT^47^ (166) | No difference [underlined: Papi, 2009]^47^ MD −0.08 (−0.21 to 0.05) | Low (unknown consistency)^b^
Health care utilization | Nighttime rescue medication use, number of inhalations/night | 1 RCT^47^ (166) | No difference [underlined: Papi, 2009]^47^ MD −0.04 (−0.11 to 0.03) | Low (unknown consistency)^b^

CI = confidence interval; ICS = inhaled corticosteroid; MD = mean difference; n = patient sample size; PACQLQ = Pediatric Asthma Caregiver’s Quality of Life Questionnaire; PRN = pro re nata (i.e., as-needed); RCT = randomized controlled trial; RR = relative risk; SABA = short-acting β_2_-agonist

a A positive mean difference in PACQLQ suggest improvement in quality of life

b Strength of evidence was low even with only one domain downgraded due to the small sample size and lack of confidence in the true effect estimate

#### Overview of Studies

Four trials (n=493) were included in the analysis of intermittent ICS with as-needed SABA versus as-needed SABA.^44,45,47,48^ Three trials^44,45,48^ required a history of recurrent wheezing in the context of RTI and randomized patients to ICS treatment every day for a defined length of time (ranging from 7 to 10d or until symptom free for 48 hours) in addition to SABA as-needed versus placebo with SABA as-needed. Svedmyr et al.,^48^ also required patients to be diagnosed with wheezy bronchitis or asthma and allowed continued use of theophylline or cromoglycate during the trial. Bacharier et al., reported that 61 percent of enrolled patients were modified Asthma Prediction Index (mAPI) positive and 64 percent were diagnosed with asthma by a physician.^44^ The fourth trial^47^ did not specify a requirement of RTI co-occurrence although did require that patients were referred to a specialist due to recurrent wheezing. In this trial, patients were randomized to beclomethasone/salbutamol as-needed for symptom relief versus salbutamol as-needed for symptom relief. Race was reported as 78 percent Caucasian in one trial^45^ and as 25 percent minority in a second trial^44^. All trials were multicenter and were conducted in single countries including United States (US), Italy, Sweden and Canada. Two trials^45,47^ were industry sponsored, one^44^ was nonindustry sponsored, and one trial^48^ did not report funding. Studies were 12m in duration except one^47^ which was 12 weeks. Risk of bias was low with the exception of Svedmyer et al.,^48^ which was determined to be unclear.

#### Results

In patients 0 to 4 years old with recurrent wheezing, intermittent ICS with as-needed SABA, initiated with and continued during RTI, reduces the risk of exacerbation requiring oral corticosteroids by 33 percent compared to as-needed SABA (moderate SOE) (Figure 4). The risk of asthma-related acute care visits or asthma-related hospitalizations was no different between groups. Mean difference (MD) in PACQLQ score improved in the group receiving intermittent ICS versus as-needed SABA (MD = 0.49, low SOE) in one trial but was not different in a second trial. Change in either daytime or nighttime rescue medication inhalations was no different between groups (low SOE).

Figure 4 Risk of requiring a course of oral steroids: intermittent ICS with as-needed SABA versus as-needed SABA

CI = confidence interval; ICS = inhaled corticosteroids; PRN = as needed; RR = relative risk; SABA = short-acting beta-agonist

This figure depicts the meta-analysis of the impact of intermittent inhaled corticosteroid with as needed short-acting beta agonists versus as needed short-acting beta agonists on exacerbations requiring oral steroids in patients with asthma. Three trials were included in this analysis. The first trial by Svedmyr and colleagues in 1999 provided a risk ratio of 0.90 with a 95 percent confidence interval of 0.44 to 1.85. The second trial by Bacharier and colleagues in 2008 provided a risk ratio of 0.70 with a 95 percent confidence interval of 0.49 to 1.00. The third trial by Ducharme and colleagues in 2009 provided a risk ratio of 0.60 with a 95 percent confidence interval of 0.42 to 0.87. The combined effect of these three trials showed a risk ratio of 0.67 with a 95 percent confidence interval of 0.46 to 0.98. The I-squared value was 0 percent with a p-value of 0.60.

### Intermittent ICS With As-Needed SABA Versus ICS Controller With As-Needed SABA

Table 7 Evidence overview for KQ1a, intermittent ICS with as-needed SABA versus ICS controller with as-needed SABA

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring oral corticosteroid | 1 RCT^49^ (278) | No difference [underlined: Zeiger, 2011]^49^ RR 0.99 (0.80 to 1.22) | Low (unknown consistency)^a^
Exacerbations | Requiring hospitalization | 1 RCT^49^ (278) | No difference [underlined: Zeiger, 2011]^49^ RR 1.25 (0.34 to 4.56) | Low (unknown consistency, imprecise)
Health care utilization | Daytime rescue medication use, number of inhalations/day | 1 RCT^47^ (220) | No difference [underlined: Papi, 2009]^47^ MD 0.07 (−0.4 to 1.8) | Low (unknown consistency, imprecise)
Health care utilization | Nighttime rescue medication use, number of inhalations/night | 1 RCT^47^ (220) | No difference [underlined: Papi, 2009]^47^ MD −0.02 (−0.7 to 0.3) | Low (unknown consistency, imprecise)

CI = confidence interval; ICS = inhaled corticosteroid; MD = mean difference; n = patient sample size; RCT = randomized controlled trial; RR = relative risk

a Strength of evidence was low even with only one domain downgraded due to the small sample size and lack of confidence in the true effect estimate

#### Overview of Studies

Two trials (n=498) were included in the analysis of intermittent ICS with as-needed SABA versus ICS controller with as-needed SABA.^47,49^ Papi et al.,^47^ was a multicenter trial in Italy of 12 weeks duration, with industry sponsorship and low risk of bias. Patients were required to be referred to a specialist due to recurrent wheezing. They were randomized to the use of beclomethasone/salbutamol on an as-needed basis for symptom relief versus beclomethasone twice daily plus as-needed salbutamol for symptom relief. Race was not reported. Zeiger et al.,^49^ was a multicenter trial conducted in the US with 52 weeks duration, nonindustry sponsorship, and low risk of bias. Patients were required to have a history of frequent wheezing and to be positive on the mAPI. They were randomized to budesonide for 7d with onset of RTI versus budesonide controller, both groups received albuterol four times daily for the first 48h of RTI then as-needed. Most patients were Caucasian (62 percent).

#### Results

The risk of exacerbation requiring oral corticosteroid and the risk of exacerbation requiring hospitalization was no different between intermittent ICS and ICS controller in a single trial (low SOE).^49^ Daytime and nighttime rescue medication use was no different between intermittent ICS and ICS controller in a single trial (low SOE).^49^ Mean cumulative salbutamol (mg) was similar between intermittent ICS and ICS controller [30.1 (43.0) versus 34.2 (42.3)].^47^

### Intermittent ICS Versus No Therapy

Table 8 Evidence overview for KQ1a, intermittent ICS versus no therapy

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 1 RCT^46^ (26) | Inconclusive [underlined: Ghirga, 2002]^46^ RR 0.54 (0.12 to 2.44) | Insufficient (unknown consistency, imprecise)
Exacerbations | Asthma-related ER visit | 1 RCT^46^ (26) | Inconclusive [underlined: Ghirga, 2002]^46^ RR 0.27 (0.04 to 2.10) | Insufficient (unknown consistency, imprecise)
Exacerbations | Asthma-related hospitalization | 1 RCT^46^ (26) | Inconclusive [underlined: Ghirga, 2002]^46^ No events occurred | Insufficient (no events occurred)

CI = confidence interval; ER = emergency room; ICS = inhaled corticosteroid; n = patient sample size; RCT = randomized controlled trial; RR = relative risk

#### Overview of Studies

One trial^46^ (n=26) was included in the analysis of intermittent ICS versus no therapy. Patients were 7 to 12m in age, presented with a history of recurrent wheezing during RTI and were randomized to beclomethasone 400μg three times daily for 5d at the first sign of RTI versus no preventative treatment. Ethnicity and sponsorship were not reported and the risk of bias was medium because it was open-label.

#### Results

Although the outcomes of exacerbation requiring oral steroid and the risk of asthma-related emergency room (ER) visits were reported, the evidence is insufficient to draw a conclusion. No asthma-related hospitalizations occurred.

## KQ1b What is the comparative effectiveness of intermittent ICS compared to ICS controller therapy in patients 5 years of age and older with persistent asthma?

Results of this KQ are reported separately based on the comparators. The first group of studies reported below under the subheading of “Intermittent ICS and ICS controller versus ICS controller” compared the addition of intermittent ICS to ICS controller therapy versus ICS controller therapy. The second group of studies reported below under the subheading “Intermittent ICS versus ICS controller” compared intermittent ICS where the patient was not otherwise on ICS controller versus ICS controller therapy. One study was included in both groups because three arms were reported.^60^ Although this KQ focuses on 2 of the 3 EPR-3 age categories (5 to 11y, 12y or older), all but two studies^54,60^ were specific to the age category of 12y or older. One trial^54^ allowed enrollment of patients as young as 4y old although this study was included in the analysis for 5 to 11y because the mean age was 7y and the populations was determined to represent that of interest. One trial^60^ enrolled 6 to 18y olds and represents a mixed population based on age and the mean was 10 to 11y, thus this trial was considered under the age category of 5 to 11y. We report results separately per age group when possible.

### Key Points

- In patients 12y of age or older, intermittent ICS and ICS controller versus ICS controller does not significantly differ in effect on the risk of exacerbations (low SOE) with exception of asthma-related outpatient visits (low SOE) which favors intermittent ICS with ICS controller versus ICS controller. Evidence is insufficient to draw conclusions in patients 5 to 11y old.
- In patients 12y of age or older, intermittent ICS versus ICS controller therapy does not significantly differ in the risk of exacerbations (low SOE), Asthma Control Questionnaire (ACQ)-7 or ACQ-5 score (low SOE), spirometry (low to high SOE), Asthma Quality of Life Questionnaire (AQLQ)-(S) score (moderate SOE), albuterol rescue use (moderate SOE). Evidence is insufficient to draw conclusions in patients 5 to 11y old aside from Pediatric Asthma Quality of Life Questionnaire (PAQLQ) score and rescue inhaler use which was no different between groups (low SOE).

### Intermittent ICS and ICS Controller Versus ICS Controller

Table 9 Evidence overview for KQ1b, intermittent ICS with ICS controller versus ICS controller in patients 12 years of age and older

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring oral corticosteroid (full population)^a^ | 3 RCTs^59,62,67^ (908) | No difference RR 0.68 (0.31 to 1.49) | Low (inconsistent, imprecise)
Exacerbations | Requiring oral corticosteroid (of those starting study inhaler)^a^ | 3 RCTs^55,59,62^ (399) | No difference RR 0.64 (0.26 to 1.57) | Low (inconsistent, imprecise)
Exacerbations | Requiring oral corticosteroid, unscheduled doctor visit, ER, or having unstable asthma^b^ | 1 RCT^55^ (98) | No difference [underlined: Fitzgerald, 2004]^55^ RR 1.03 (0.63 to 1.65) | Low (unknown consistency, imprecise)
Exacerbations | Asthma-related hospitalization | 1 RCT^67^ (115) | Inconclusive [underlined: Lahdensuo, 1996]^67^ RR 0.70 (0.12 to 4.05) | Insufficient (medium ROB, unknown consistency, imprecise)
Exacerbations | Asthma-related outpatient visit | 2 RCTs^59,67^ (505) | Favors intermittent ICS and ICS controller [underlined: Lahdensuo, 1996]^67^ RR 0.53 (0.29 to 0.96) [underlined: Harrison, 2004]^59^ RR 1.14 (0.71 to 1.83) | Low (inconsistent, imprecise)
Exacerbations | Unstable asthma^b^ | 1 RCT^55^ (98) | No difference [underlined: Fitzgerald, 2004]^55^ RR 0.57 (0.23 to 1.38) | Low (unknown consistency, imprecise)
Exacerbations | 2 or 3 exacerbations requiring oral corticosteroid (full population)^a^ | 1 RCT^62^ (403) | No difference [underlined: Oborne, 2009]^62^ RR 0.63 (0.15 to 2.59) | Low (unknown consistency, imprecise)
Exacerbations | 2 or 3 exacerbations requiring oral corticosteroid (of those starting study inhaler)^a^ | 1 RCT^62^ (403) | No difference [underlined: Oborne, 2009]^62^ RR 0.34 (0.07 to 1.76) | Low (unknown consistency, imprecise)
Exacerbations | Fall in PEF <70% from baseline | 1 RCT^56^ (134) | No difference [underlined: Foresi, 2000]^56^ RR 1.09 (0.52 to 2.30) | Low (unknown consistency, imprecise)

CI = confidence interval; ICS = inhaled corticosteroid; MD = mean difference; n = patient sample size; OR = odds ratio; RCT = randomized controlled trial; ROB = risk of bias; RR = relative risk; y=year

a The full population reflects all patients randomized in that trial, regardless if they ever initiated the study inhaler which would have provided the intermittent ICS dose. The population which started the study inhaler reflects the patients randomized who actually initiated the study inhaler and thus received the intermittent ICs dose they were randomized too.

b Defined as lack of stability, where stability was defined as morning peak expiratory flow 90 percent or more of mean baseline value on either of the two previous days, <4 inhalations of inhaled corticosteroid per day over the past 2 days, no nocturnal awakenings in the prior 2 nights, and a total symptom score not exceeding mean baseline value more than 2 ordinal values over the previous 2 days

Table 10 Evidence overview for KQ1b, intermittent ICS with ICS controller versus ICS controller in patients 4 to 11 years of age

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbation | Requiring oral corticosteroids | 1 RCT^60^ (143) | Inconclusive [underlined: Martinez, 2011]^60^ RR 1.12 (0.67 to 1.86) | Insufficient (unknown consistency, imprecise, indirect)^a^
Exacerbation | Requiring hospitalization | 1 RCT^54^ (29) | Inconclusive [underlined: Colland, 2004]^54^ OR 0.14 (0.003 to 7.31) | Insufficient (unclear ROB, unknown consistency, imprecise)
Exacerbation | Treatment failure^b^ | 1 RCT^60^ (143) | Inconclusive [underlined: Martinez, 2011]^60^ RR 2.03 (0.39 to 10.72) | Insufficient (unknown consistency, imprecise, indirect)^a^
Spirometry | FEV1 % predicted | 1 RCT^54^ (29) | Inconclusive [underlined: Colland, 2004]^54^ MD 5 (−6.01 to 16.01) | Insufficient (unclear ROB, unknown consistency, imprecise)
Quality of life | PAQLQ score | 1 RCT^60^ (143) | No difference [underlined: Martinez, 2011]^60^ MD −0.003 (−0.25 to 0.25) | Low (unknown consistency, Indirect)^a^
Health care utilization | Albuterol puffs/day | 1 RCT^60^ (143) | Inconclusive [underlined: Martinez, 2011]^60^ MD 0.04 (−0.33 to 0.40) | Insufficient (unknown consistency, imprecise, indirect)^a^

CI = confidence interval; ER = emergency room; FEV1 = forced expiratory volume in one second; ICS = inhaled corticosteroid; MD = mean difference; n = patient sample size; OR = odds ratio; PAQLQ = Pediatric Asthma Quality of Life Questionnaire; RCT = randomized controlled trial; ROB = risk of bias; RR = relative risk; y = year

a Martinez et al. enrolled patients 6 to 18 years of age, with mean of 10 and 11y per arm although since this is the only trial that provides data for the EPR-3 age group of 5–11y old, we used the data but downgraded strength of evidence for indirectness

b Defined as any of following: (1) Hospitalization due to asthma; (2) Hypoxic seizure due to asthma; (3) Intubation due to asthma; (4) Requirement for a second burst of prednisone within any 6m period; (5) Significant adverse event related to the use of a study medication. The only criterion for assignment of treatment failure during the trial was the requirement for a second burst of prednisone within any six-month period

#### Overview of Studies

Seven RCTs^54–56,59,60,62,67^ (n=1312) were included in the analysis of intermittent ICS plus ICS controller versus ICS controller. Five RCTs^55,56,59,62,67^ enrolled patients 12 years of age and older (mean 31 to 55 years). One trial^54^ enrolled patients 4 to 11y old and 1 trial^60^ enrolled a mixed population of 6 to 18y olds (mean 10 to 11y); thus, results of these trials are presented separately from results of patients 12y of age or older. The trial^60^ that enrolled patients 6 to 18 years of age was the only source of data for the population of 4 to 11y old for some of the outcomes evaluated thus we used this data and downgraded the SOE for indirectness. Of the 7 trials, one further specified persistent asthma to be mild,^60^ one^67^ specified mild to moderate, and two^54,56^ specified moderate severity. One trial^60^ required patients to be well controlled, one^59^ described patients as stable, two trials^54,56^ considered patients symptomatic, and the others did not specify asthma control. Race was reported in one trial^60^ and was mostly Caucasian (71%). In all trials, patients were taking ICS controller therapy and in the intervention arm peak expiratory flow (PEF),^55,56,59,62,67^ prodromal symptoms,^54^ or real-life scenarios where the patient would normally use albuterol or treat a reduced PEF^60^ triggered a temporary increase in the ICS dose. Of the trials that used PEF to trigger additional ICS, trigger values ranged from <70 percent to <85 percent. The duration of increased ICS dose was either 7 or 14d except in a single trial^60^ instructing patients to use the inhaler whenever albuterol would be normally used. The increase in ICS dose was equivalent to doubling, ^54,55,59,67^ quadrupling,^56,62^ or patient driven^60^. In 5 trials^55,56,59,62,67^ PEF (either <60% or <70%) also triggered oral corticosteroid initiation for a duration ranging from 3 to 10d. The control arm was randomized to a set ICS dose in all trials except one^67^ where physicians modified therapy according to their judgement. All trials were multicenter, of either 6 or 12m duration, and conducted in a single country (Canada, US, United Kingdom [UK], Netherlands, Finland, Italy). Three trials were industry sponsored^55,56,67^ and 4 were nonindustry sponsored.^54,59,60,62^ Risk of bias was low in 4 trials,^55,59,60,62^ medium in 1 trial^67^ and unclear in 2 trials.^54,56^

#### Results

In patients 12y of age or older, intermittent ICS and ICS controller versus ICS controller does not significantly differ in the effect on risk of exacerbation requiring oral corticosteroid, for the full study population (Figure 5, Panel A) or in those patients who actually initiated the study inhaler (Figure 5, Panel B) (low SOE), or other measures of asthma exacerbation (low SOE) with exception of asthma-related outpatient visits which decreased with intermittent ICS and ICS controller versus ICS controller (low SOE). In patients 5 to 11y old, there is insufficient evidence to draw conclusions on the impact of intermittent ICS and ICS controller versus ICS controller. The exception is PAQLQ, where there is a low SOE that there is no difference in effect between groups.

Figure 5 Risk of exacerbations requiring oral corticosteroid: Intermittent ICS and ICS controller versus ICS controller

Panel A represents the comparison of intermittent ICS and ICS controller vs. ICS controller on the outcome of exacerbations requiring steroid in the full population, which is all patients regardless if they initiated their intermittent ICS therapy. Panel B represents the same comparison and outcome but only in patients who actually initiated their intermittent ICS therapy.

Panel A of this figure depicts the meta-analysis of the impact of intermittent doubling of the inhaled corticosteroid dose versus inhaled corticosteroid controller therapy on exacerbations requiring systemic steroids in patients with asthma in the full study population. Three trials were included in this analysis. The first trial by Harrison and colleagues in 2004 provided a risk ratio of 0.95 with a 95 percent confidence interval of 0.55 to 1.63. The second trial by Oborne and colleagues in 2009 provided a risk ratio of 0.65 with a 95 percent confidence interval of 0.37 to 1.13. The third trial by Lahdensuo and colleagues in 1996 provided a risk ratio of 0.51 with a 95 percent confidence interval of 0.29 to 0.88. The combined effect of these three trials showed a risk ratio of 0.68 with a 95 percent confidence interval of 0.31 to 1.49. The I-squared value was 21 percent with a p-value of 0.28. Panel B of this figure depicts the meta-analysis of the impact of intermittent doubling of the inhaled corticosteroid dose versus inhaled corticosteroid controller therapy on exacerbations requiring systemic steroids in patients with asthma who initiated the study inhaler. Three trials were included in this analysis. The first trial by FitzGerald and colleagues in 2004 provided a risk ratio of 0.85 with a 95 percent confidence interval of 0.39 to 1.83. The second trial by Harrison and colleagues in 2004 provided a risk ratio of 0.76 with a 95 percent confidence interval of 0.44 to 1.32. The third trial by Oborne and colleagues in 2009 provided a risk ratio of 0.43 with a 95 percent confidence interval of 0.24 to 0.78. The combined effect of these three trials showed a risk ratio of 0.64 with a 95 percent confidence interval of 0.26 to 1.57. The I-squared value was 25 percent with a p-value of 0.27.

#### Subgroup Data

[underlined: ICS dose]: Harrison et al., analyzed a subgroup of patients on ICS doses up to 1000μg of beclomethasone equivalents (considered low to moderate ICS dose) and the risk of starting oral corticosteroids was similar to the main analysis.^59^ Fitzgerald et al., compared patients on ICS doses less than or equal to 400μg/d vs. greater than 400μg/d and found the subgroup receiving less that or equal to 400μg/d were less likely to experience treatment failure during the trial.^55^ In this study, treatment failure was defined as any one of the following: hospitalization due to asthma, hypoxic seizure due to asthma, intubation due to asthma, requirement for a second burst of prednisone within any 6m period, or significant adverse event related to the use of a study medication.

[underlined: Age]: Fitzgerald et al., also compared adolescents versus adults and found no effect on the outcome of treatment failure (as defined above).^55^

### Intermittent ICS Versus ICS Controller

Table 11 Evidence overview for KQ1b, intermittent ICS versus ICS controller in patients 12 years of age and older

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring oral corticosteroid | 1 RCT^51^ (149) | No difference [underlined: Boushey, 2005]^51^ RR 0.70 (0.30 to 1.64) | Low (unknown consistency, imprecise)
Exacerbations | Requiring hospitalization | 1 RCT^51^ (149) | [underlined: Boushey, 2005]^51^ No events occurred | Insufficient (no events occurred)
Exacerbations | Asthma-related urgent care visit | 1 RCT^52^ (227) | No difference [underlined: Calhoun, 2012]^52^ RR 0.25 (0.05 to 1.16) | Low (unknown consistency, imprecise)
Exacerbations | Mild^a^ or severe^b^ exacerbation | 1 RCT^63^ (228) | No difference [underlined: Papi, 2007]^63^ RR 0.87 (0.29 to 2.61) | Low (unknown consistency, imprecise)
Exacerbations | Severe exacerbation^b^ | 1 RCT^63^ (228) | No difference [underlined: Papi, 2007]^63^ OR 0.11 (0.01 to 1.11) | Low (unknown consistency, imprecise)
Asthma control composite scores | ACQ-7 score | 1 RCT^51^ (149) | No difference [underlined: Boushey, 2005]^51^ MD 0.1 (−0.12 to 0.32) | Low (unknown consistency)^c^
Asthma control composite scores | ACQ-5 score | 1 RCT^52^ (227) | No difference [underlined: Calhoun, 2012]^52^ MD −0.01 (−0.17 to 0.15)^d^ | Low (unknown consistency)^c^
Spirometry | FEV1, trough | 2 RCTs^52,63^ (564) | No difference [underlined: Papi, 2007]^63^ MD 0.09 (−0.01 to 0.18) [underlined: Calhoun, 2012]^52^ MD 0.01 (−0.13 to 0.15)^d^ | High
Spirometry | FEV1 % predicted | 2 RCTs^52,63^ (564) | No difference [underlined: Papi, 2007]^63^ MD 2.04 (−0.71 to 4.79) [underlined: Calhoun, 2012]^52^ MD 0.01 (−1.89 to 1.91)^d^ | Moderate (imprecise)
Spirometry | FVC, trough | 1 RCT^63^ (228) | No difference [underlined: Papi, 2007]^63^ MD 0.07 (−0.03 to 0.18)^d^ | Low (unknown consistency)
Spirometry | FVC % predicted | 1 RCT^63^ (228) | No difference [underlined: Papi, 2007]^63^ MD 1.72 (−1.04 to 4.48) | Low (Unknown consistency, imprecise)
Quality of life | AQLQ(S) score | 2 RCT^51,52^ (376) | No difference [underlined: Boushey, 2005]^51^ MD −0.2 (−0.48 to 0.08) [underlined: Calhoun, 2012]^52^ MD 0.01 (−0.19 to 0.21)^d^ | Moderate (inconsistent)
Health care utilization | Rescue albuterol puffs/day | 2 RCT^52,63^ (564) | No difference [underlined: Papi, 2007]^63^ MD 0.07 (−0.13 to 0.26) [underlined: Calhoun, 2012]^52^ MD −0.04 (−0.11 to 0.03)^d^ | Moderate (imprecise)

ACQ = Asthma Control Questionnaire; AQLQ(S) = Standardized Asthma Quality of Life Questionnaire; CI = confidence interval; FEV1 = forced expiratory volume in one second; FVC = forced vital capacity; ICS = inhaled corticosteroid; MD = mean difference; n = patient sample size; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; y=year

a Defined as awakening at night owing to asthma or as a decrease in the morning peak expiratory flow rate to more than 20 percent below the baseline value, the use of more than three additional puffs per day of rescue medication (either albuterol or beclomethasone and albuterol) as compared with during the baseline for 2 or more consecutive days, or both. Single, isolated day on which mild exacerbation occurred were not counted.

b Defined as a decrease in the morning peak expiratory flow rate to more than 30 percent below the baseline value on 2 consecutive days or more than eight puffs per day of rescue medication for 3 consecutive days or the need for treatment with oral corticosteroids, as judged by the investigator.

c Strength of evidence was low even with only one domain downgraded due to the small sample size and lack of confidence in the true effect estimate

d Study reported 97.5 percent confidence intervals which were converted to 95 percent confidence intervals

Table 12 Evidence overview for KQ1b, intermittent ICS versus ICS controller in patients 4 to 11 years of age

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring oral corticosteroids | 1 RCT^60^ (143) | Inconclusive [underlined: Martinez, 2011]^60^ RR 1.27 (0.78 to 2.07) | Insufficient (unknown consistency, imprecise, indirect)
Exacerbations | Treatment failure^e^ | 1 RCT^60^ (143) | Inconclusive [underlined: Martinez, 2011]^60^ RR 3.04 (0.64 to 14.57) | Insufficient (unknown consistency, imprecise, indirect)
Spirometry | FEV1 % predicted | 1 RCT^60^ (143) | Inconclusive [underlined: Martinez, 2011]^60^ MD −1.30 (−4.24 to 1.64) | Insufficient (unknown consistency, imprecise, indirect)
Quality of life | PAQLQ score | 1 RCT^60^ (143) | No difference [underlined: Martinez, 2011]^60^ MD 0.04 (−0.25 to 0.33) | Low (unknown consistency, Indirect)
Health care utilization | Rescue albuterol puffs/day | 1 RCT^60^ (143) | No difference [underlined: Martinez, 2011]^60^ MD 0.003 (−0.24 to 0.25) | Low (unknown consistency, indirect)

CI = confidence interval; FEV1 = forced expiratory volume in one second; MD = mean difference; n = patient sample size; PAQLQ = Pediatric Asthma Quality of Life Questionnaire; RCT = randomized controlled trial; RR = relative risk; y = year

a Defined as any of following: (1) Hospitalization due to asthma; (2) Hypoxic seizure due to asthma; (3) Intubation due to asthma; (4) Requirement for a second burst of prednisone within any 6m period; (5) Significant adverse event related to the use of a study medication. The only criterion for assignment of treatment failure during the trial was the requirement for a second burst of prednisone within any six-month period.

#### Overview of Studies

Five RCTs^51,52,60,63,64^ (n=972) were included in the analysis of intermittent ICS versus ICS controller. Three trials^51,52,63^ enrolled patients 12y of age or older (mean 32 to 39y), all requiring an age of at least 18y to enter the trial. One trial enrolled patients 5 to 10y old and one trial^60^ enrolled a mixed population (6 to 18y, mean 10 to 11y); thus, results of these trials are presented separately from results of patients 12y of age or older. Three trials^51,60,63^ specified asthma to be mild persistent, two of which^60,63^ required asthma to be controlled. One trial evaluated patients with mild to moderate persistent asthma that was well or partially well controlled^52^ and the final trial^64^ evaluated mostly mild persistent asthmatics, symptomatic at the start of the trial. Race was specified as Caucasian in 3 trials^60,63,64^ ranging from 64 to 100 percent of subjects. In all trials, patients in the intervention arm were not on controller therapy. In 3 trials, intermittent ICS was triggered by the need for symptom relief where albuterol would normally be used, and ICS doses were taken with SABA doses as-needed.^52,60,63^ ICS use was triggered by action plan specified symptoms consistent with the yellow zone in one trial^51^ and upon symptom development that prompted contact with study physician who decided if intermittent ICS should be initiated in another trial^64^. In both of these trials^51,64^ intermittent ICS duration was fixed (10 and 14d). In one trial, the control arm received physician-modified therapy according to the step-wise approach^52^ while in the others patients were randomized to a fixed ICS dose. Duration of trials ranged from 6 to 18m. All but 1 trial^64^ were multicenter, 3 trials^51,52,60^ conducted in the US and the others outside of the US. Two trials^63,64^ were industry sponsored while the others were nonindustry sponsored. Risk of bias was low in all trials.

#### Results

In patients 12y of age and older, intermittent ICS versus ICS controller therapy does not significantly differ in effect on the risk of exacerbations (low SOE), ACQ-7 or ACQ-5 score (low SOE), spirometry (low to high SOE), AQLQ(S) score (moderate SOE), or albuterol rescue use (moderate SOE).

In patients 5 to 11y old, there is insufficient evidence to draw conclusions on the impact of intermittent ICS versus ICS controller for all endpoints except for rescue albuterol use where there is a low SOE of no difference between the two strategies.

#### Subgroup Data

[underlined: Race/ethnicity, albuterol reversibility, baseline FEV1, peak flow, symptoms, nitric oxide, sputum eosinophils]: Calhoun et al., found that race/ethnicity and albuterol reversibility predicted the outcome of treatment failure. The odds of treatment failure were increased in Hispanics [Odds Ratio (OR) 3.6 (1.8 to 7.0)] and in blacks [OR 2.1 (1.2 to 4.0)] compared to non-Hispanic white subjects, p<0.02 for both comparisons. ^52^ There was also a significant interaction between race and efficacy suggesting a in non-Hispanic whites, intermittent ICS prevented treatment failure better than ICS controller [HR 4.50 (1.42 to 14.30)] whereas in Hispanics the opposite was found [HR 0.30 (0.04 to 1.80), p=0.01 comparing the two groups).^52^ In this study, treatment failure was defined as a composite of asthma exacerbations, FEV1 measurement at home or in the office, SABA use, or use of additional asthma medications.^52^ The following characteristics were not predictive of treatment failure: baseline forced expiratory volume in 1 second (FEV1), peak flow, symptoms, exhaled nitric oxide, sputum eosinophils.

[underlined: FEV1 percent predicted]: Boushey et al., compared subgroups of patients with FEV1 percent predicted 70 to 79 vs. greater than 80 percent and found no impact on the outcome of post-bronchodilatory FEV1.^51^

## KQ1c What is the comparative effectiveness of ICS with long-acting beta agonist (LABA) used as both controller and quick relief therapy compared to ICS with or without LABA used as controller therapy in patients 5 years of age and older with persistent asthma?

Results for this KQ are reported separately based on the comparator being ICS controller, ICS and LABA controller, or either comparator (conventional best practice [CBP]). CBP describes the comparator arm in a trial when either ICS or ICS and LABA controller was allowed. The estimated comparative daily ICS dose^1^ was used to further categorize studies into the following 6 groups:

- ICS and LABA controller and quick relief versus ICS controller at the same comparative ICS dose (same dose)
- ICS and LABA controller and quick relief versus ICS controller at a higher comparative ICS dose (higher dose)
- ICS and LABA controller and quick relief versus ICS and LABA controller at the same comparative ICS dose (same dose)
- ICS and LABA controller and quick relief versus ICS and LABA controller at a higher comparative ICS dose (higher dose)
- ICS and LABA controller and quick relief versus ICS and LABA controller at a lower comparative ICS dose (lower dose)
- ICS and LABA controller and quick relief versus conventional best practice (CBP)

Some studies met criteria for more than one of the above 6 groups when multiple arms were reported. Although this KQ focuses on 2 of the 3 EPR-3 age categories (5 to 11y, 12y of age and older), all but two studies^83,115^ were specific to the age category of 12 years of age and older. One trial^115^ enrolled patients as young as 6y while the second trial^83^ enrolled patients as young as 4y. This latter trial^83^ was included because the mean age was 36y and the populations was considered to represent that of interest. We report results separately per age group when possible.

### Key Points—ICS and LABA Controller and Quick Relief Versus ICS Controller

- In patients 12 years of age and older, ICS and LABA controller and quick relief versus ICS controller at the same comparative ICS dose reduces the risk of exacerbations as composite outcomes (all moderate SOE), improves FEV1 (moderate SOE) and reduces rescue medication inhalations per day (low SOE).
- In patients 12 years of age and older and in patients 4 to 11y old, ICS and LABA controller and quick relief versus ICS controller at a higher comparative ICS dose reduces the risk of exacerbations as composite outcomes (all low SOE).

### Key Points—ICS and LABA Controller and Quick Relief Versus ICS and LABA Controller

- In patients 12 years of age and older, ICS and LABA controller and quick relief versus ICS and LABA controller at the same comparative ICS dose reduces the risk of composite exacerbations including systemic corticosteroid, hospitalization, or ER visits (high SOE) as well as each of the individual components of the composite outcome (moderate to high SOE). The chance of being an ACQ-5 responder (moderate SOE) and the mean inhalations per week of rescue inhaler (low SOE) also favored controller and quick relief therapy. Results of a subgroup of patients 4–11y old favor ICS and LABA controller and quick relief on composite exacerbation outcomes and on mild exacerbation risk (all low SOE).
- In patients 12 years of age and older, ICS and LABA controller and quick relief versus ICS and LABA controller at a higher comparative ICS dose reduces the risk of composite exacerbations including systemic corticosteroid, hospitalization, or ER visits (high SOE) but not individual components of the composite outcome (moderate SOE).
- There is insufficient evidence to determine the impact of ICS and LABA controller and quick relief versus ICS and LABA controller at a lower comparative ICS dose.

### Key Points—ICS and LABA Controller and Quick Relief Versus CBP

- In patients 12 years of age and older, ICS and LABA as controller and quick relief versus CBP reduces the risk of composite exacerbations (requiring systemic corticosteroids, hospitalization, ER visit, moderate SOE) but not of the individual components of the composite outcome (low SOE). ACQ-5 scores were improved with ICS and LABA controller and quick relief (moderate SOE) and rescue medication use also favored ICS and LABA controller and quick relief (moderate SOE).

### ICS and LABA as Controller and Quick Relief Versus ICS Controller at the Same Comparative ICS Dose

Table 13 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus ICS controller (same dose) in patients 12 years of age and older

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroids, hospitalization, ER visit, or having a PEF<70% | 2 RCTs^94,96^ (2586) | Favors controller and quick relief [underlined: Scicchitano, 2004]^96^ RR 0.65 (0.55 to 0.78) [underlined: Rabe, 2006]^94^ RR 0.49 (0.32 to 0.76) | Moderate (imprecise)
Exacerbations | Requiring systemic corticosteroids, hospitalization, or ER visit | 1 RCT^96^ (1890) | Favors controller and quick relief [underlined: Scicchitano, 2004]^96^ RR 0.64 (0.53 to 0.78) | Moderate (unknown consistency)
Death | All-cause | 1 RCT^96^ (1890) | Inconclusive [underlined: Scicchitano, 2004]^96^ OR 0.51 (0.05 to 4.92) | Insufficient (unknown consistency, imprecise)
Death | Asthma-specific | 1 RCT^96^ (1890) | [underlined: Scicchitano, 2004]^96^ No events occurred | Insufficient^a^ (no events occurred)
Spirometry | FEV1 | 1 RCT^96^ (1890) | Favors controller and quick relief [underlined: Scicchitano, 2004]^96^ MD 0.1 (0.07 to 0.13) | Moderate (unknown consistency)
Health care utilization | Rescue mediation use, number of inhalations/day | 1 RCT^94^ (697) | Favors controller and quick relief [underlined: Rabe, 2006]^94^ MD −0.34 (−0.51 to −0.17) | Low (unknown consistency, imprecise)

CI = confidence interval; ER = emergency room; FEV1 = forced expiratory volume in one second; MD = mean difference; n = patient sample size; OR = odds ratio; PEF = peak expiratory flow; RCT = randomized controlled trial; RR = relative risk

a Strength of evidence was rated insufficient in the setting of downgrading only one domain because this is a single trial with rare events.

#### Overview of Studies

Three RCTs^94,96,99^ (n=2658) were included in the analysis of ICS and LABA controller and quick relief versus ICS at the same comparative dose, all fitting in the age group of 12 years of age and older (mean 38 to 43y). Two trials^94,96^ included patients 12 to 80y old and the third trial^99^ included patients 18 to 70 years old. Sovani et al.,^99^ enrolled patients with suboptimally controlled persistent asthma but also required patients to have evidence of poor adherence to medications and thus results are separately described from the other two trials. Poor adherence was defined in that trial as having collected less than 70 percent of the expected number of prescriptions for ICS in the year prior to the study.^99^ The remaining two trials enrolled symptomatic patients, one^94^ with mild to moderate persistent asthma and the other^96^ with moderate to severe persistent asthma. Race was not reported. All trials compared budesonide/formoterol controller and quick relief to budesonide controller and short-acting β_2_-agonist (SABA) quick relief. Two trials^94,96^ were multicenter, multinational while the third^99^ was multicenter in the UK. All trials were industry sponsored and were either 6 or 12mo in duration. Risk of bias was low in two trials^94,96^ but high in one trial^99^ due to the open-label design, high attrition, and lack of intention-to-treat analysis.

#### Results

In patients 12 years of age and older, a single trial^96^ found the risk of exacerbation requiring systemic corticosteroid, hospitalization or ER visit was reduced by 36 percent with ICS and LABA controller and quick relief versus ICS at the same comparative dose (moderate SOE). Time to first exacerbation [hazard ratio (HR) 0.61 (0.49 to 0.75)] and exacerbation rate [incident rate ratio (IRR) 0.55 (0.46 to 0.66)] favored ICS and LABA controller and quick relief.^96^ Addition of PEF<70 percent to that composite outcome also found a reduction in exacerbation risk favoring ICS and LABA controller and quick relief (moderate SOE). Time to first exacerbation including the PEF component [HR 0.61 (0.50 to 0.74)] and time to first mild exacerbation [HR 0.68 (0.61 to 0.75)] also favored ICS and LABA controller and quick relief versus ICS at the same comparative ICS dose.^96^ One trial^96^ reported death as an outcome but few events occurred (1 versus 2 deaths, in ICS and LABA controller and quick relief versus ICS controller), none of which were asthma-specific, thus data were insufficient to draw conclusions. Mean change in FEV1 improved (MD = 0.10 L) with ICS and LABA controller and quick relief in a single trial^96^ (moderate SOE) as did rescue medication use inhalations/day (MD −0.34, low SOE).^94^ Two trials^94,96^ reported the total number of oral corticosteroid days which were numerically lower in the ICS and LABA controller and quick relief group (114 versus 498, 1176 versus 3177).

Sovani et al., found no difference in the mean change in ACQ-7 score, FEV1, or AQLQ-mini score.^99^ The total number of oral corticosteroid courses was 6 per group.

### ICS and LABA as Controller and Quick Relief Versus ICS Controller at a Higher Comparative ICS Dose

Table 14 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus ICS controller (higher dose) in patients 12 years of age and older

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid, hospitalization, ER visit, or having a PEF<70% | 1 RCT^83^ (1851) | Favors controller and quick relief [underlined: O’Byrne, 2005]^a,83^ RR 0.57 (0.48 to 0.69) | Low (unknown consistency, indirect)
Exacerbations | Requiring systemic corticosteroid, hospitalization, or ER visit | 1 RCT^83^ (1847) | Favors controller and quick relief [underlined: O’Byrne, 2005]^a,83^ RR 0.58 (0.46 to 0.72) | Low (unknown consistency, indirect)

CI = confidence interval; ER = emergency room;; n = patient sample size; PEF = peak expiratory flow; RCT = randomized controlled trial; RR = relative risk; y = year

a O’Byrne enrolled patients 4 to 80y old although given this is the only trial that provides data for the EPR-3 age group of 12 years of age and older, we used the data but downgraded strength of evidence for indirectness

Table 15 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus ICS controller (higher dose) in patients 4 to 11 years of age

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid, hospitalization, ER visit, increase in ICS or other medication or having a PEF<70% | 1 RCT^75^ (224) | Favors controller and quick relief [underlined: Bisgaard, 2006]^75^ RR 0.55 (0.32 to 0.94) | Low^a^ (unknown consistency, indirect, imprecise)
Exacerbations | Requiring systemic corticosteroid, hospitalization, ER visit or increase in ICS or other medication | 1 RCT^75^ (224) | Favors controller and quick relief [underlined: Bisgaard, 2006]^75^ RR 0.43 (0.21 to 0.87) | Low^a^ (unknown consistency, indirect, imprecise)
Exacerbations | Mild exacerbations^b^ | 1 RCT^75^ (224) | No difference [underlined: Bisgaard, 2006]^75^ RR 0.86 (0.72 to 1.04) | Low^a^ (unknown consistency, indirect)

CI = confidence interval; EPR = Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ER = emergency room; ICS = inhaled corticosteroid; n = patient sample size; PEF = peak expiratory flow; RCT = randomized controlled trial; RR = relative risk; y = year

a Strength of evidence was downgraded for indirectness due to the dose used in this study, which is lower than that approved in the package insert as well as what the EPR-3 considers “low dose” for this age group.

b Defined as 2 consecutive days with one of the following: morning PEF greater than or equal to 20 percent below the average run-in value, as-needed medication use two or more inhalations a day above baseline, or awakenings due to asthma

#### Overview of Studies

One multicenter, multinational trial^83^ (n=1851) of 12m duration was included. The patients represented a mixed age (4 to 80y, mean 36y, 12% of patients <12y) although given this is the only source of data for patients 12 years of age and older, we utilized the data but downgraded SOE for being indirect. Patients had persistent, symptomatic asthma and race was not reported. Patients were randomized to ICS and LABA (budesonide/formoterol) controller and quick relief versus ICS (budesonide) controller at a higher comparative dose with SABA quick relief. The trial reported industry sponsorship and had low risk of bias.

#### Results

Using the full trial population data to suggest effect in patients 12 years of age and older, the risk of exacerbation requiring systemic corticosteroid, hospitalization or ER visit was reduced by 42 percent with ICS and LABA controller and quick relief versus ICS at a higher comparative dose (low SOE).^83^ Time to first exacerbation [HR 0.55 (0.43 to 0.70)] and exacerbation rate [IRR 0.54 (0.44 to 0.66)] favored ICS and LABA controller and quick relief. Addition of PEF<70 percent to that composite outcome also found a reduction in exacerbation risk favoring ICS and LABA controller and quick relief (low SOE). Time to first exacerbation including the PEF component [HR 0.53 (0.43 to 0.65)] and exacerbation rate [IRR 0.53 (0.44 to 0.64)] and the rate of mild exacerbation [IRR 0.64 (0.57 to 0.73)] also favored ICS and LABA controller and quick relief. In the pre-planned subgroup analysis of patients 4 to 11y old (mean 8y), the same two composite exacerbation outcomes also favored ICS and LABA (both low SOE) controller and quick relief although risk of mild exacerbations was no different.^75^ Time to first composite exacerbation that included the PEF component favored ICS and LABA controller and quick relief [HR 0.49 (0.27 to 0.90)].

### ICS and LABA as Controller and Quick Relief Versus ICS and LABA Controller at the Same Comparative ICS Dose

Table 16 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus ICS and LABA controller (same dose) in patients 12 years of age and older

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 2 RCTs^70,84^ (3792) | Favors controller and quick relief [underlined: Atienza, 2013]^70^ RR 0.77 (0.62 to 0.95) [underlined: Papi, 2013]^84^ RR 0.62 (0.49 to 0.79) | High
Exacerbations | Requiring hospitalization | 2 RCTs^70,86^ (2224) | Favors controller and quick relief [underlined: Atienza, 2013]^70^ RR 0.33 (0.17 to 0.65) [underlined: Patel, 2013]^86^ RR 1.01 (0.14 to 7.05) | Low (inconsistent, imprecise)
Exacerbations | Requiring ER visit | 1 RCT^70^ (2091) | Favors controller and quick relief [underlined: Atienza, 2013]^70^ RR 0.74 (0.59 to 0.93) | Moderate (unknown consistency)
Exacerbations | Requiring intubation | 1 RCT^86^ (1701) | [underlined: Papi, 2013]^86^ No events occurred | Insufficient (no events occurred)
Exacerbations | Requiring systemic corticosteroid, hospitalization, or ER visit | 5 RCTs ^70,84,86,93,103^ (8483) | Favors controller and quick relief RR 0.68 (0.58 to 0.80) | High
Exacerbations | Requiring hospitalization or ER visit | 5 RCTs ^70,84,86,93,103^ (8313) | Favors controller and quick relief RR 0.69 (0.63 to 0.76) | High
Exacerbations | Requiring systemic corticosteroid, hospitalization, ER, or unscheduled visit | 1 RCT^103^ (2143) | Favors controller and quick relief [underlined: Vogelmeier, 2005]^103^ RR 0.79 (0.65 to 0.95) | Moderate (unknown consistency)
Exacerbations | Mild exacerbation^a^ | 3 RCTs^70,84,93^ (6037) | No difference RR 0.94 (0.81 to 1.09) | Moderate (inconsistent)
Death | All-cause | 4 RCTs^70,86,93,103^ (6782) | No difference OR 0.43 (0.04 to 4.49) | Moderate (imprecise)
| Asthma-specific | 4 RCTs^70,86,93,103^ (6782) | No events occurred | Insufficient (no events occurred)
Asthma control composite scores | ACT score | 1 RCT^102^ (63) | Inconclusive [underlined: Takeyama, 2014]^102^ MD 6.3 (5.15 to 7.45) | Insufficient (unclear ROB, unknown consistency)
Asthma control composite scores | ACQ-5 score | 3 RCT^70,78,93^ (4353) | No difference MD −0.16 (−0.39 to 0.06) | Low (inconsistent, imprecise)
Asthma control composite scores | ACQ-5 responder^b^ | 1 RCT^70^ (2091) | Favors controller and quick relief [underlined: Atienza, 2013]^70^ RR 1.14 (1.05 to 1.24) | Moderate (unknown consistency)
Spirometry | FEV1 | 5 RCTs^70,84,86,93,101^ (6343) | No difference MD 0.04 (0.00 to 0.09) | Low (inconsistent, imprecise)
Spirometry | FEV1 % predicted | 2 RCTs^78,86^ (304) | No difference [underlined: Patel, 2013]^86^ MD 1.8 (−2.8 to 6.4) [underlined: Hozawa, 2014]^78^ MD 1.9 (−4.27 to 8.07) | Moderate (medium ROB)
Spirometry | FVC | 1 RCT^84^ (1701) | No difference [underlined: Papi, 2013]^84^ MD −0.01 (−0.07 to 0.04) | Low (unknown consistency, imprecise)
Health care utilization | Rescue medication use, number of inhalations/day | 3 RCT^70,84,93^ (6006) | No difference MD −0.16 (−0.45 to 0.14) | Low (inconsistent, imprecise)
Health care utilization | Rescue medication use, number of inhalations/week | 2 RCTs^78,101^ (93) | Favors controller and quick relief [underlined: Hozawa, 2014]^78^ MD −0.73 (−1.42 to −0.04) [underlined: Takeyama, 2014]^101^ MD −2.2 (−3.92 to −0.48) | Low (medium ROB, imprecise)

ACQ = Asthma Control Questionnaire; ACT = Asthma Control Test; CI = confidence interval; ER = emergency room; FEV1 = forced expiratory volume in one second; FVC = forced vital capacity; MD = mean difference; n = patient sample size; OR = odds ratio; PEF = peak expiratory flow; RCT = randomized controlled trial; ROB = risk of bias; RR = relative risk; y = year

a Defined as meeting one of the following: the need for 2 or more as-needed medication inhalations over baseline, nighttime awakening from asthma or PEF decrease by at least 20 percent

b Defined as a reduction in score by 0.5 or more

Table 17 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus ICS and LABA controller (same dose) in patients 4 to 11 years of age

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroids, hospitalization, ER visit, increase in ICS or other medication or having a PEF<70% | 1 RCT^75^ (341) | Favors controller and quick relief [underlined: Bisgaard, 2006]^75^ RR 0.38 (0.23 to 0.63) | Low (unknown consistency, indirect)^a^
Exacerbations | Requiring hospitalization, systemic corticosteroids, ER visit, or increase in ICS or other medications | 1 RCT^75^ (341) | Favors controller and quick relief [underlined: Bisgaard, 2006]^75^ RR 0.28 (0.14 to 0.53) | Low (unknown consistency, indirect)^a^
Exacerbations | Mild exacerbations^b^ | 1 RCT^75^ (341) | Favors controller and quick relief [underlined: Bisgaard, 2006]^75^ RR 0.75 (0.64 to 0.88) | Low (unknown consistency, indirect)^a^

CI = confidence interval; ER = emergency room; n = patient sample size; OR = odds ratio; PEF = peak expiratory flow; RCT = randomized controlled trial; RR = relative risk; y = year

a Strength of evidence was downgraded for indirectness due to the dose used in this study, which is lower than that approved in the package insert as well as what the EPR-3 considers “low dose” for this age group.

b Defined as meeting one of the following: the need for 2 or more as-needed medication inhalations over baseline, nighttime awakening from asthma or PEF decrease by at least 20 percent

#### Overview of Studies

Nine RCTs^70,78,83,84,86,93,100,101,103^ (n=12,902) were included in the analysis of ICS and LABA controller and quick relief versus ICS and LABA controller at the same comparative ICS dose, all but one fitting the age group of 12 years of age and older (mean 39 to 49y). O’Byrne et al.,^83^ enrolled patients 4 to 80y old thus was not pooled with the base analysis but added in a sensitivity analysis given the mean age was 36y. The trial provided data from a pre-planned subgroup analysis of 4 to 11y olds which are presented separately.^75^ Of the trials meeting the age group 12 years of age and older, most required the age of 12y^93,100,104^ or 16y^70,86,101^ for inclusion. Vogelmeier et al.,^103^ although fitting into this group based on ICS comparative doses at the start of the trial, allowed dose titration in the comparator group; and thus we conducted sensitivity analysis excluding this trial. Of the 9 trials, 1 trial^101^ further specified persistent asthma severity as moderate to severe. Six trials enrolled patients with symptomatic asthma,^70,78,83,93,101,103^ 1 trial^100^ enrolled patients regardless of symptom presence, 4 trials^70,78,84,101^ specified patients were not controlled, and 1 trial^86^ did specify control or symptom presence. Race was reported in one trial^70^ and was 31.8 percent Caucasian and 62.3 percent Asian. Six trials used budesonide/formoterol in both arms^70,83,86,93,100,101^ and 1 trial^84^ compared beclomethasone/formoterol in both arms. Two trials compared budesonide/formoterol controller and quick relief to fluticasone/salmeterol controller.^78,103^ The comparator in Stallberg et al.,^100^ included both similar and a higher comparative ICS dose thus this trial was excluded from pooled analysis. Seven trials^70,78,83,84,93,100,103^ were industry sponsored and 2 trials^86,101^ were nonindustry sponsored. Five trials^70,83,84,93,103^ were multicenter, multinational while the others were conducted in a single country (Japan, Sweden, New Zealand). Trials were mostly 12m in duration but ranged from 8 weeks to 1 year. Risk of bias was low in all trials except 4^78,86,100,103^ considered medium risk of bias due to the open-label design and 1 trial^101^ had an unclear risk of bias.

#### Results

In patients 12y and older, ICS and LABA controller and quick relief versus ICS and LABA controller at the same comparative ICS dose reduces the risk of exacerbation requiring systemic corticosteroids by 23 percent to 38 percent (high SOE), the risk of exacerbation requiring hospitalization by 67 percent (moderate SOE), the risk of exacerbation requiring ER visit by 26 percent (moderate SOE) and the composite outcome of all three exacerbation types by 32 percent (high SOE) (Figure 6, Panel A). Time to first composite exacerbation was reduced in favor of controller and quick relief [HR 0.65 (0.54 to 0.78)] as was rate of composite exacerbations [IRR 0.54 (0.42 to 0.69)]. One trial reported that no patients required intubation from exacerbation.^84^ Additional composite outcomes for exacerbation also suggest reduction in risk favoring ICS and LABA as controller and quick relief (moderate to high SOE) (Figure 6, Panel B) although no difference was found for the risk of mild exacerbations (Figure 6, Panel C) or in the time to first mild exacerbation [HR 0.88 (0.71 to 1.10)]. Deaths were infrequent and occurred in 3 of the 4 trials reporting this outcome^70,86,93,103^ and no difference was found (moderate SOE). No asthma specific deaths occurred. Sensitivity analysis adding O’Byrne et al.,^83^ to the composite of exacerbations requiring systemic steroids, hospitalization or ER visits [relative risk (RR) 0.65 (0.55 to 0.77), HR 0.62 (0.52 to 0.74), IRR 0.52 (0.44 to 0.63)] did not impact the magnitude or direction of effect for any results. Sensitivity analysis removing Vogelmeier et al.,^103^ did not impact magnitude or direction of effect for the composite of exacerbations requiring systemic steroids, hospitalization or ER visits [RR 0.66 (0.55 to 0.78), HR 0.62 (0.51 to 0.76)], exacerbation requiring hospitalization or ER visit [RR 0.69 (0.60 to 0.79)] or death [OR 0.68 (0.01 to 34.96)].

Figure 6 Risk of exacerbation: ICS and LABA controller and quick relief versus ICS and LABA controller (same dose)

CI = confidence interval; ER = emergency room; RR = relative risk

Panel A of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at the same dose on composite exacerbations in patients with asthma. Five trials were included in this analysis. The first trial by Vogelmeier and colleagues in 2005 provided a risk ratio of 0.80 with a 95 percent confidence interval of 0.64 to 0.99. The second trial by Rabe and colleagues in 2006 provided a risk ratio of 0.60 with a 95 percent confidence interval of 0.50 to 0.72. The third trial by Atienza and colleagues in 2013 provided a risk ratio of 0.74 with a 95 percent confidence interval of 0.62 to 0.88. The fourth trial by Papi and colleagues in 2013 provided a risk ratio of 0.65 with a 95 percent confidence interval of 0.51 to 0.82. The fifth trial by Patel and colleagues in 2013 provided a risk ratio of 0.56 with a 95 percent confidence interval of 0.38 to 0.84. The combined effect of these five trials showed a risk ratio of 0.68 with a 95 percent confidence interval of 0.58 to 0.80. The I-squared value was 29 percent with a p-value of 0.23. Panel B of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at the same dose on exacerbations requiring hospitalization or emergency room visits in patients with asthma. Five trials were included in this analysis. The first trial by Vogelmeier and colleagues in 2005 provided a risk ratio of 0.68 with a 95 percent confidence interval of 0.43 to 1.06. The second trial by Rabe and colleagues in 2006 provided a risk ratio of 0.61 with a 95 percent confidence interval of 0.44 to 0.85. The third trial by Atienza and colleagues in 2013 provided a risk ratio of 0.72 with a 95 percent confidence interval of 0.58 to 0.90. The fourth trial by Papi and colleagues in 2013 provided a risk ratio of 0.69 with a 95 percent confidence interval of 0.49 to 0.96. The fifth trial by Patel and colleagues provided a risk ratio of 0.78 with a 95 percent confidence interval of 0.30 to 2.05. The combined effect of these five trials showed a risk ratio of 0.69 with a 95 percent confidence interval of 0.63 to 0.76. The I-squared value was 0 percent with a p-value of 0.939. Panel C of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at the same dose on mild exacerbations in patients with asthma. Three trials were included in this analysis. The first trial by Rabe and colleagues in 2006 provided a risk ratio of 0.94 with a 95 percent confidence interval of 0.90 to 0.99. The second trial by Atienza and colleagues in 2013 provided a risk ratio of 0.89 with a 95 percent confidence interval of 0.84 to 0.93. The third trial by Papi and colleagues in 2013 provided a risk ratio of 1.00 with a 95 percent confidence interval of 0.94 to 1.06. The combined effect of these three trials showed a risk ratio of 0.94 with a 95 percent confidence interval of 0.81 to 1.09. The I-squared value was 79 percent with a p-value of 0.01.

Mean difference in ACQ-5 score was no different between groups although 1 trial^86^ found the chance of being an ACQ-5 responder to favor ICS and LABA controller and quick relief (moderate SOE). Asthma Control Test (ACT) score was reported by a single trial with unclear risk of bias thus impact of ICS and LABA controller and quick relief is undetermined. Mean change in FEV1, FEV1 percent predicted and FVC were no different between groups although the lower limit of the confidence interval for FEV1 was at zero. Mean inhalations of rescue medication per day was no different between groups but when evaluated as mean inhalations per week, favored ICS and LABA controller and quick relief therapy (low SOE).

Stallberg et al., found no difference in the composite exacerbation outcome of those requiring systemic corticosteroids, hospitalization or ER visit with ICS and LABA controller and quick relief versus ICS and LABA controller and a similar or higher comparative ICS dose, in patients 12y old and older.^100^

In patients 4 to 11 years old ICS and LABA controller and quick relief versus ICS and LABA controller reduces the risk of three exacerbation types (all low SOE): the composite of exacerbations requiring systemic corticosteroids, hospitalization, ER visit, increase in ICS or other medication or having a PEF less than 70 percent; the composite of exacerbations requiring hospitalization, systemic corticosteroids, ER, or increase in ICS or other medications; and finally mild exacerbations.^75^

#### Subgroup Data

[underlined: Race/ethnicity:] Pilcher et al.,^90^ conducted an analysis of a prior trial^86^ for ethnicity-treatment interaction with specific interest in Maori versus non-Maori people. Maori are indigenous Polynesians of New Zealand. Maori had a greater improvement in ACQ-7 score than non-Maori [−1.01 (−1.55 to −0.51) versus −0.10 (−0.31 to 0.11), p<0.001] at the end of the trial. Vogelmeier et al., conducted a post-hoc subgroup analysis^104^ of patients 16 years of age and older old in Asian countries (China, Taiwan, Korea and Thailand) from a prior international trial that enrolled patients 12 years of age and older.^103^ Being Asian vs. the international population did not affect the composite exacerbation outcome. ^104^

[underlined: Baseline ICS dose]: Papi et al.,^84^ found that regardless if maintenance ICS dose on entry was less than or equal to 500μg or greater than 500μg beclomethasone equivalents, the rate of and time to first exacerbation requiring systemic corticosteroid, hospitalization or ER visit favored ICS and LABA controller and quick relief versus ICS and LABA controller, consistent with the main results study results.

[underlined: Smoking status:] Pilcher et al.,^116^ conducted an analysis of a prior trial^86^ regarding the effect of smoking status on outcomes. Being a current, former or never smoker did not impact treatment efficacy for the outcomes of exacerbations, hospital or ER attendance, ACQ-7 or FEV1.

[underlined: FEV1 percent predicted, exacerbation history and gender]: Patel et al.,^87^ analyzed data from a prior trial^86^ and found the following patient characteristics to increase the risk of exacerbation requiring systemic corticosteroids or hospitalization/ER visit for treatment: lower baseline FEV1 percent predicted per 10 percent [rate ratio 1.14 (1.03 to 1.27)], higher number of exacerbations in the prior year per 1 exacerbation [rate ratio 1.15 (1.01 to 1.13)], treatment with ICS and LABA controller as opposed to controller and quick relief [rate ratio 1.62 (1.07 to 2.47)], and female gender [rate ratio 2.18 (1.29 to 3.67)].

### ICS and LABA as Controller and Quick Relief Versus ICS and LABA Controller at a Higher Comparative ICS Dose

Table 18 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus ICS and LABA controller (higher dose) in patients 12 years of age and older

Outcome categories | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 1 RCT^76^ (2304) | No difference [underlined: Bousquet, 2007]^76^ RR 0.82 (0.62 to 1.07) | Moderate (unknown consistency)
Exacerbations | Requiring systemic corticosteroid, hospitalization, or ER visit | 3 RCTs^76,81^ (6742) | Favors controller and quick relief RR 0.75 (0.59 to 0.96) | High
Exacerbations | Requiring hospitalization or ER visit | 3 RCTs^76,81^ (6742) | No difference RR 0.76 (0.46 to 1.25) | Moderate (imprecise)
Exacerbations | Mild exacerbation^a^ | 2 RCTs^81^ (3321) | No difference [underlined: Kuna, 2007a]^81^ RR 0.97 (0.91 to 1.04) [underlined: Kuna, 2007b]^81^ RR 1.04 (0.97 to 1.11) | Moderate (unknown consistency because single trial)
Death | All-cause | 4 RCTs^76,81,89^ (5757) | No difference OR 2.72 (0.38 to 19.31) | Moderate (imprecise)
Death | Asthma-specific | 4 RCTs^76,81,89^ (5757) | No events occurred | Insufficient (no events occurred)
Asthma control composite scores | ACQ-5 score | 3 RCTs^76,81^ (6559) | No difference [underlined: Bousquet, 2007]^76^ MD −0.02 (−0.07 to 0.04) [underlined: Kuna, 2007a]^81^ MD −0.02 (−0.08 to 0.05) [underlined: Kuna, 2007b]^81^ MD 0.03 (−0.03 to 0.09) | High
Spirometry | FEV1 | 2 RCTs^81^ (4424) | No difference [underlined: Kuna, 2007a]^81^ MD 0.01 (−0.03 to 0.04) [underlined: Kuna, 2007b]^81^ MD 0.01 (−0.03 to 0.04) | Moderate (unknown consistency)
Quality of life | AQLQ(S) score | 2 RCTs^81^ (4270) | No difference [underlined: Kuna, 2007a]^81^ MD 0.01 (−0.07 to 0.08) [underlined: Kuna, 2007b]^81^ MD −0.02 (−0.09 to 0.06) | Moderate (unknown consistency because single trial)
Heath care utilization | Rescue medication use, number of inhalations/day | 3 RCTs^76,81^ (6559) | No difference [underlined: Bousquet, 2007]^76^ MD −0.04 (−0.12 to 0.04) [underlined: Kuna, 2007a]^81^ MD −0.03 (−0.12 to 0.06) [underlined: Kuna, 2007b]^81^ MD 0.07 (−0.02 to 0.16) | High

ACQ = Asthma Control Questionnaire; AQLQ = Asthma Quality of Life Questionnaire; CI = confidence interval; ER = emergency room; FEV1 = forced expiratory volume in one second; MD = mean difference; n = patient sample size; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk

a Defined as meeting one of the following: the need for 2 or more as-needed medication inhalations over baseline, nighttime awakening from asthma or a PEF decrease by at least 20 percent

#### Overview of Studies

Five RCTs^76,81,89,100,115^ (n=7605) were included in the analysis of ICS and LABA as controller and quick relief versus ICS and LABA controller at a higher comparative ICS dose. Kuna et al., contributed two unique comparisons which were considered independently for analysis.^81^ All trials fit the age group of 12 years of age and older (mean 38 to 45y) except Lundborg et al.,^115^ which studied a mixed age group (≥6y old). However, this trial^115^ used formoterol instead of SABA as quick relief in the control arm thus the trial was not pooled with the others. Three trials enrolled patients with symptomatic persistent asthma^76,81,89^ and two trials enrolled patients with persistent asthma and mixed control/presence of symptoms.^100,115^ Race was not reported. All studies compared budesonide/formoterol as controller and quick relief to either fluticasone/salmeterol controller^76,81^ or budesonide/formoterol controller.^81,89,100,115^ The comparator in Stallberg et al.,^100^ included both similar and a higher comparative ICS dose thus this trial was excluded from pooled analysis. All trials were multicenter and industry sponsored, 3 trials^76,81,89^ were multinational and 2^100,115^ were conducted in Sweden. Trials ranged from 6 to 12m in duration. Risk of bias was low in 3 trials^76,81,89^ and medium in 2 trials^100,115^ due to the open-label design and the risk of performance and detection bias.

#### Results

In patients 12 years of age and older, ICS and LABA as controller and quick relief versus ICS and LABA controller at a higher comparative ICS dose did not significantly differ in effect on the risk of exacerbations requiring systemic corticosteroids or requiring hospitalization/ER visit (Figure 7, Panel B) (both moderate SOE) but when evaluated as a composite outcome requiring systemic corticosteroids, hospitalization or ER visit risk was reduced by 25 percent (high SOE) (Figure 7, Panel A). The risk of mild exacerbations was no different (moderate SOE). Deaths occurred in 3 of the 4 trials reporting this outcome^76,81^ and no difference was found (moderate SOE). No asthma-specific deaths occurred. There was no difference in ACQ-5 score (high SOE), FEV1 (moderate SOE), AQLQ(S) score (moderate SOE) or rescue medication use (high SOE).

Figure 7 Risk of exacerbation: ICS and LABA controller and quick relief versus ICS and LABA controller (higher dose)

CI = confidence interval; ER = emergency room; RR = relative risk

Panel A of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at a higher dose on exacerbations requiring systemic corticosteroids, hospitalization or emergency room visits in patients with asthma. Three trial arms were included in this analysis. The first trial arm by Bousquet and colleagues in 2007 provided a risk ratio of 0.83 with a 95 percent confidence interval of 0.65 to 1.06. The second trial arm by Kuna and colleagues in 2007 is the first of two comparator trial arms reported in that publication and provided a risk ratio of 0.75 with a 95 percent confidence interval of 0.58 to 0.96. The third trial arm by Kuna and colleagues in 2007 is the second of two comparator trial arms reported in that publication and provided a risk ratio of 0.68 with a 95 percent confidence interval of 0.53 to 0.87. The combined effect of these three trial arms showed a risk ratio of 0.75 with a 95 percent confidence interval of 0.59 to 0.96. The I-squared value was 0 percent with a p-value of 0.53. Panel B of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at a higher dose on exacerbations requiring hospitalization or emergency room visits in patients with asthma. Three trial arms were included in this analysis. The first trial arm by Bousquet and colleagues in 2007 provided a risk ratio of 0.66 with a 95 percent confidence interval of 0.44 to 0.98. The second trial arm by Kuna and colleagues in 2007 is the first of two comparator trial arms reported in that publication and provided a risk ratio of 0.96 with a 95 percent confidence interval of 0.65 to 1.41. The third trial arm by Kuna and colleagues in 2007 is the second of two comparator trial arms reported in that publication and provided a risk ratio of 0.69 with a 95 percent confidence interval of 0.48 to 0.98. The combined effect of these three trial arms showed a risk ratio of 0.76 with a 95 percent confidence interval of 0.46 to 1.25. The I-squared value was 9 percent with a p-value of 0.33.

Lundborg et al.,^115^ provided data for patients 6y and older and compared two approaches to controller and quick relief therapy, budesonide/formoterol once daily or twice daily, both compared to ICS and LABA controller and formoterol quick relief. ACQ-5 was no different with either controller and quick relief approach compared to ICS and LABA controller. Stallberg et al., found no difference in the composite exacerbation outcome of those requiring systemic corticosteroids, hospitalization or ER visit with ICS and LABA controller and quick relief versus ICS and LABA controller and a similar or higher comparative ICS dose, in patients 12y old and older.^100^

#### Subgroup Data

[underlined: Race/ethnicity]: Lin et al.,^113^ conducted a post-hoc subgroup analyses comparing Chinese patients vs. the full international population and found no impact on the outcomes of exacerbation and ACQ-5 score.

[underlined: Age]: Kuna et al.,^80^ conducted a post-hoc subgroup analysis of a prior trial^81^ in patients 16y of age and older old vs. the original population of 12 years of age and older and found no impact on the outcomes of exacerbations, ACQ-5, AQLQ(S) or rescue medication use inhalations/d.

### ICS and LABA as Controller and Quick Relief Versus ICS and LABA Controller at a Lower Comparative ICS Dose

Table 19 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus ICS and LABA controller (lower dose) in patients 12 years of age and older

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Asthma control composite scores | ACQ-5 score | 1 RCT^117^ (30) | Inconclusive [underlined: Hozawa, 2016]^117^ MD −0.40 (−0.53 to −0.27) | Insufficient (medium ROB, unknown consistency, imprecise)
Spirometry | FEV1 % predicted | 1 RCT^117^ (30) | Inconclusive [underlined: Hozawa, 2016]^117^ MD 3.10 (−1.36 to 7.56) | Insufficient (medium ROB, unknown consistency)
Health care utilization | Rescue medication use, number of inhalations/week | 1 RCT^117^ (30) | Inconclusive [underlined: Hozawa, 2016]^117^ MD −0.9 (−1.48 to −0.32) | Insufficient (medium ROB, unknown consistency, imprecise)

ACQ = Asthma Control Questionnaire; CI = confidence interval; FEV1 = forced expiratory volume in one second; MD = mean difference; n = patient sample size; RCT = randomized controlled trial; ROB = risk of bias; RR = relative risk

#### Overview of Studies

One RCT^117^ (n=30) was included in the analysis of ICS and LABA as controller and quick relief versus ICS and LABA controller at a lower comparative ICS dose. Hozawa et al., studied patients 20y of age and older, with a mean age of 41y. Patients were considered to have symptomatic, persistent asthma. Race was not reported. Patient were randomized to budesonide/formoterol as controller and quick relief or fluticasone/vilanterol as controller with procaterol as needed. The trial was single center, industry-sponsored in Japan for 4 weeks. Risk of bias was medium due to the open-label design and the risk of performance and detection bias.

#### Results

Although the outcomes of ACQ-5 score, FEV1 percent predicted, and rescue medication use were reported, the evidence is insufficient to draw a conclusion.

### ICS and LABA as Controller and Quick Relief Versus CBP

Table 20 Evidence overview for KQ1c, ICS and LABA controller and quick relief versus CBP in patients 12 years of age and older

Outcome category | Outcome | Quantity and type of evidence (n) | Conclusion Effect estimate (95% CI) | Strength of evidence (rationale)
Exacerbations | Requiring systemic corticosteroid | 4 RCTs^82,91,97,98^ (4935) | No difference RR 0.84 (0.61 to 1.17) | Low (medium ROB, imprecise)
Exacerbations | Requiring hospitalization | 4 RCTs^82,91,97,98^ (4935) | No difference OR 0.89 (0.34 to 2.30) | Low (medium ROB, imprecise)
Exacerbations | Requiring ER visit | 4 RCTs^82,91,97,98^ (4935) | No difference RR 0.78 (0.50 to 1.21) | Low (medium ROB, imprecise)
Exacerbations | Requiring systemic corticosteroid, hospitalization, or ER visit | 6 RCTs^82,91,95,97,98,100^ (6354) | Favors controller and quick relief RR 0.78 (0.64 to 0.95) | Moderate (medium ROB)
Death | All-cause | 4 RCTs^82,91,97,98^ (4935) | No difference OR 2.20 (0.32 to 14.96) | Moderate (imprecise)
Death | Asthma-specific | 4 RCTs^82,91,97,98^ (4935) | No events occurred | Insufficient (no events occurred)
Asthma control composite scores | ACQ-5 score | 5 RCTs^82,91,95,97,98^ (4996) | Favors controller and quick relief MD −0.09 (−0.14 to −0.03) | Moderate (medium ROB)
Asthma control composite scores | ACQ-5 responder^a^ | 2 RCTs^91,97^ (2166) | Favors controller and quick relief [underlined: Sears, 2008]^97^ RR 1.22 (1.03 to 1.44) [underlined: Quirce, 2011]^91^ RR 1.09 (0.92 to 1.30) | Moderate (medium ROB)
Spirometry | FEV1 | 1 RCT^82^ (271) | No difference [underlined: Louis, 2009]^82^ MD −0.03 (−0.12 to 0.06) | Low (unknown consistency)^b^
Spirometry | FEV1 % predicted | 1 RCT^95^ (102) | No difference [underlined: Riemersma, 2012]^95^ MD 0.70 (−1.80 to 3.20) | Low (unknown consistency)^b^
Health care utilization | Rescue medication use, number of inhalations/day | 2 RCTs^82,97^ (2404) | Favors controller and quick relief [underlined: Sears, 2008]^97^ MD −0.16 (−0.26 to −0.05) [underlined: Louis, 2009]^82^ MD −0.10 (−0.24 to 0.03) | Moderate (medium ROB)
Health care utilization | ≥1 day w/PRN inhalation | 2 RCTs^82,91^ (1562) | Favors CBP [underlined: Louis, 2009]^82^ RR 2.96 (2.42 to 3.61) [underlined: Quirce, 2011]^91^ RR 0.96 (0.90 to 1.01) | Low (medium ROB, inconsistent)

Abbreviations: ACQ=Asthma Control Questionnaire; CBP=conventional best practice; CI=confidence interval; ER=emergency room; FEV1=forced expiratory volume in one second; MD=mean difference; n=patient sample size; OR=odds ratio; PRN=pro re nata (as-needed); RCT=randomized controlled trial; ROB=risk of bias; RR=relative risk

a Responder was defined as a reduction in score by 0.5 or more

b Strength of evidence was rated low even in the setting of one domain downgraded because of the small sample size within a single trial for this outcome and thus lack of confidence in the true effect estimate.

#### Overview of Studies

Six RCTs^82,91,95,97,98,100^ (n=6832) and two observational studies^79,114^ (n=536) were included in the analysis of ICS and LABA as controller and quick relief versus CBP, all fitting the age category of 12 years of age and older (mean age 40 to 51y). Two trials enrolled patients with mild to severe asthma,^91,97^ 1 enrolled mild to moderate asthma,^95^ and the remaining trials did not further classify persistent asthma severity. Two trials enrolled patients considered to have suboptimal asthma control^91,97^ and the remaining trials enrolled a mixed population in terms of control and/or symptom presence^82,95,98,100^ One trial reported race, which was 94 percent Caucasian.^97^ All trials compared budesonide/formoterol as both controller and quick relief to what we refer to as “CBP”. All patients in the CBP groups received at a minimum ICS and of the trials reporting further details^82,91,97,98^ greater than 80 percent were also on LABA. Changes in medications and doses were determined by the physician throughout the course of the trial. All trials were multicenter industry sponsored. Trials ranged from 6 to 12m in duration. Risk of bias was medium in all trials due to the open-label design and the risk of performance and detection bias.

#### Results

ICS and LABA as controller and quick relief versus CBP did not significantly differ in the effect on the risk of exacerbations requiring systemic corticosteroids, requiring hospitalization, or requiring ER visits (all low SOE) (Figure 8, Panels A–C) but when evaluated as a composite outcome reduces the risk of exacerbations by 22 percent (moderate SOE) (Figure 8, Panel D). Time to first composite exacerbation was not significantly reduced [HR 0.85 (0.58 to 1.23)] while the IRR was in favor of ICS and LABA as controller and quick relief therapy [IRR 0.83 (0.70 to 0.99)]. Deaths were infrequent and occurred in 3 of the 4 trials reporting this outcome^82,97,98^ and no difference was detected. No asthma-specific deaths occurred. Spirometry was infrequently reported and in the single trial that measured FEV1 and FEV1 percent predicted, no difference was found (both low SOE). Mean difference in ACQ-5 favored ICS and LABA as controller and quick relief therapy (MD −0.09, moderate SOE) while the chance of being an ACQ-5 responder was increased in 1 trial^97^ with ICS and LABA as controller and quick relief by 22 percent (moderate SOE) but a second trial^91^ found no difference.

Figure 8 Risk of exacerbation: ICS and LABA controller and quick relief versus CBP

CI = confidence interval; ER = emergency room; RR = relative risk

Panel A of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus conventional best practice on exacerbations requiring systemic steroids in patients with asthma. Four trials were included in this analysis. The first trial by Sears and colleagues in 2008 provided a risk ratio of 1.03 with a 95 percent confidence interval of 0.72 to 1.47. The second trial by Louis and colleagues in 2009 provided a risk ratio of 0.70 with a 95 percent confidence interval of 0.33 to 1.49. The third trial by Quirce and colleagues in 2011 provided a risk ratio of 0.62 with a 95 percent confidence interval of 0.33 to 1.16. The fourth trial by Soes-Peterson and colleagues in 2011 provided a risk ratio of 0.79 with a 95 percent confidence interval of 0.55 to 1.13. The combined effect of these four trials showed a risk ratio of 0.84 with a 95 percent confidence interval of 0.61 to 1.17. The I-squared value was 0 percent with a p-value of 0.48. Panel B of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus conventional best practice on exacerbations requiring hospitalization in patients with asthma. Four trials were included in this analysis. The first trial by Sears and colleagues in 2008 provided an odds ratio of 0.13 with a 95 percent confidence interval of 0.00 to 6.77. The second trial by Louis and colleagues in 2009 provided an odds ratio of 1.99 with a 95 percent confidence interval of 0.21 to 19.14. The third trial by Quirce and colleagues in 2011 provided an odds ratio of 7.34 with a 95 percent confidence interval of 0.15 to 370.13. The fourth trial by Soes-Peterson and colleagues in 2011 provided an odds ratio of 0.71 with a 95 percent confidence interval of 0.23 to 2.21. The combined effect of these four trials showed an odds ratio of 0.89 with a 95 percent confidence interval of 0.34 to 2.30. The I-squared value was 0 percent with a p-value of 0.45. Panel C of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus conventional best practice on exacerbations requiring emergency room visits in patients with asthma. Four trials were included in this analysis. The first trial by Sears and colleagues in 2008 provided a risk ratio of 0.69 with a 95 percent confidence interval of 0.37 to 1.30. The second trial by Louis and colleagues in 2009 provided a risk ratio of 0.25 with a 95 percent confidence interval of 0.03 to 2.27. The third trial by Quirce and colleagues in 2011 provided a risk ratio of 0.99 with a 95 percent confidence interval of 0.47 to 2.11. The fourth trial by Soes-Peterson and colleagues in 2011 provided a risk ratio of 0.80 with a 95 percent confidence interval of 0.45 to 1.51. The combined effect of these four trials showed a risk ratio of 0.78 with a 95 percent confidence interval of 0.50 to 1.21. The I-squared value was 0 percent with a p-value of 0.67. Panel D of this figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus conventional best practice on exacerbations requiring steroids, hospitalizations or emergency room visits in patients with asthma. Six trials were included in this analysis. The first trial by Sears and colleagues in 2008 provided a risk ratio of 0.96 with a 95 percent confidence interval of 0.69 to 1.35. The second trial by Stallberg and colleagues in 2008 provided a risk ratio of 0.72 with a 95 percent confidence interval of 0.51 to 1.03. The third trial by Louis and colleagues in 2009 provided a risk ratio of 0.64 with a 95 percent confidence interval of 0.32 to 1.31. The fourth trial by by Quirce and colleagues in 2011 provided a risk ratio of 0.71 with a 95 percent confidence interval of 0.42 to 1.19. The fifth trial by Soes-Peterson and colleagues in 2011 provided a risk ratio of 0.79 with a 95 percent confidence interval of 0.57 to 1.10. The sixth by Riemersma and colleagues in 2012 provided a risk ratio of 0.30 with a 95% confidence interval of 0.06 to 1.40. The combined effect of these six trials showed a risk ratio of 0.78 with a 95 percent confidence interval of 0.64 to 0.95. The I-squared value was 0 percent with a p-value of 0.62.

Asthma-specific quality of life was not reported in these trials. The mean difference in rescue medication use favored ICS and LABA controller and quick relief therapy in 1 trial^97^ but was no different in a second trial^82^ (moderate SOE). The chance of needing at least 1 day with as-needed inhaler use favored CBP in 1 trial^82^ but found no difference in a second trial^91^. Three trials^82,91,97^ reported the total number of oral corticosteroid days during the trial which was numerically higher with CBP in each trial and one trial provided a p-value indicating statistical significance.

Two observational studies evaluated patients who were treated with ICS and LABA as a controller and quick relief medication versus ICS and LABA as controller with SABA quick relief.^79,114^ In both studies, the mean age was 50y, race was not reported, and asthma was described as requiring step 3 treatment according to the Global Initiative for Asthma guidelines. Kardos et al.,^79^ was industry sponsored and determined to have low risk of bias while Loh et al.,^114^ was nonindustry sponsored but with medium risk of bias due to incomparability of the groups compared. Kardos et al.,^79^ found that mean annual exacerbation rate was not significantly different with ICS and LABA controller and quick relief ([0.20 (0.14 to 0.29)] compared to ICS and LABA controller [0.17 (0.10 to 0.29)], p=0.66). Rescue medication use was reduced with ICS and LABA controller and quick relief versus ICS and LABA controller [MD −0.266 (−0.474 to −0.057), p=0.013]. AQLQ(S) change from baseline was greater in the ICS and LABA controller group [mean change 0.42 (0.89)] than in the ICS and LABA controller and quick relief group [mean change 0.25 (0.82)]. FEV1 improved in both groups and the difference was greater in the ICS and LABA controller and quick relief group [mean change 0.13 (0.48) versus 0.07 (0.431)]. Two patients (0.6%) needed ER treatment in the ICS and LABA controller and quick relief group and one (0.6%) needed hospitalization in the ICS and LABA controller group. Loh et al.,^114^ found that rescue medication use was reduced significantly in both patients treated with ICS and LABA controller and quick relief and those treated with ICS and LABA controller. In the ICS and LABA controller and quick relief group, FEV1 significantly improved (median difference 90 mL, p=0.013) as did the rate of hospitalizations (p=0.039) compared with ICS and LABA controller, although the rate of ER visits did not differ.

## KQ2a What is the comparative effectiveness of long-acting muscarinic antagonist (LAMA) as add-on to ICS controller therapy compared to placebo or increased ICS dose in patients 12 years of age and older with uncontrolled, persistent asthma?

### Key Points—LAMA Versus Placebo as Add-on to ICS

- LAMA versus placebo as add-on to ICS reduces the risk of exacerbations requiring systemic corticosteroids (high SOE) and the risk of asthma worsening (high SOE), and leads to improved mean differences in peak, trough and area under the curve (AUC) for FEV1 and FVC (all high SOE).
- LAMA versus placebo as add-on to ICS does not significantly differ in effect on asthma control composite scores (moderate SOE), asthma-specific quality of life (low to high SOE) or rescue medication use (moderate SOE).

### Key Points—LAMA Add-on to ICS Versus Increasing ICS Dose

- LAMA added on to ICS versus doubling the ICS dose does not significantly differ in effect on the risk of exacerbations requiring systemic corticosteroids or the mean difference in ACQ-6 score, FEV1 trough or AQLQ score (all low SOE).

### LAMA Versus Placebo as Add-on to ICS

#### Overview of Studies

Seven RCTs^118–123^ (n=3321) were included in the analysis of LAMA versus placebo as add-on to ICS, one had a crossover design.^120^ Two replicate trials were reported in a single publication and each trial results were considered unique except for the results that were only reported in a combined way.^119^ Six trials were multicenter, multinational trials^118–120,122,123^ and 1 trial was conducted in Japan.^121^ All trials reported industry sponsorship. Trials ranged from 15d to 52 weeks in duration. All trials required an age of at least 18 years for inclusion except (mean age 41 to 47y) one trial^123^ which focused on patients 12 to 17y old (mean age 14y). Patients in the trials reporting race^118,120^ were mostly Caucasian (87% to 93.3%). One trial^121^ allowed the continued use of pretrial LABA while a second trial^123^ did so for pretrial leukotriene receptor antagonist (LTRA). One trial^120^ studied the LAMA umeclidinium while the others studied tiotropium. Risk of bias was low in 6 trials^118,119,121,–123^ and unclear in 1 trial.^120^

#### Results

As add-on to ICS, LAMA decreases the risk of exacerbation requiring systemic corticosteroid by 33 percent (high SOE) (Figure 9, Panel A) and decreases the risk of asthma worsening by 19 percent (high SOE) (Figure 9, Panel B versus placebo. No deaths occurred in the six trials reporting this outcome.

Figure 9 Risk of exacerbation and of asthma worsening with LAMA versus placebo as add-on to ICS

CI = confidence interval; LAMA = long-acting muscarinic antagonists; RR = relative risk

Panel A of this figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on exacerbations requiring systemic corticosteroids in patients with asthma. Five trials were included in this analysis. The first trial by Bateman and colleagues in 2001 provided a risk ratio of 0.93 with a 95 percent confidence interval of 0.49 to 1.75. The second trial by Paggiaro and colleagues in 2016 provided a risk ratio of 0.88 with a 95 percent confidence interval of 0.26 to 2.95. The third trial by Kerstjens and colleagues in 2015 is a combination of the two individual trials reported in that publication and provided a risk ratio of 0.62 with a 95 percent confidence interval of 0.42 to 0.92. The fourth trial by Lee and colleagues in 2015 provided a risk ratio of 0.64 with a 95 percent confidence interval of 0.07 to 6.09. The fifth trial by Hamelmann and colleagues in 2016 provided a risk ratio of 0.41 with a 95 percent confidence interval of 0.16 to 1.09. The combined effect of these five trials showed a risk ratio of 0.67 with a 95 percent confidence interval of 0.48 to 0.92. The I-squared value was 0 percent with a p-value of 0.69. Panel B of this figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on asthma worsening in patients with asthma. Three trials were included in this analysis. The first trial by Paggiaro and colleagues in 2016 provided a risk ratio of 0.78 with a 95 percent confidence interval of 0.47 to 1.28. The second trial by Kerstjens and colleagues in 2015 is a combination of the two individual trials reported in that publication and provided a risk ratio of 0.79 with a 95 percent confidence interval of 0.67 to 0.94. The third trial by Hamelmann and colleagues in 2016 provided a risk ratio of 0.92 with a 95 percent confidence interval of 0.65 to 1.31. The combined effect of these three trials showed a risk ratio of 0.81 with a 95 percent confidence interval of 0.68 to 0.97. The I-squared value was 0 percent with a p-value of 0.74.

Most measures of lung function obtained from spirometry were improved with LAMA versus placebo, including peak FEV1 (MD 0.18L), trough FEV1 (MD 0.13L) and FEV1 AUC (MD 0.18L), peak FVC (MD 0.11 L), trough FVC (MD 0.08L) and FVC AUC (MD 0.11L) (all with high SOE). FEV1 percent predicted was reported in one trial^122^ and was increased with LAMA versus placebo (MD 3.5%, low SOE). Despite these improvements, the mean difference in ACQ-7 score (moderate SOE) was no different with LAMA versus placebo nor was the chance of being a responder (moderate SOE).

Asthma-specific quality of life was no different with LAMA versus placebo, regardless of AQLQ tool version or when evaluated as a mean difference or as a responder (low to high SOE). The only health care utilization outcome reported was the use of rescue medication defined as the mean number of puffs per 24 hours. The mean difference in rescue medication use was no different with LAMA versus placebo (moderate SOE).

#### Subgroup Data

[underlined: Tiotropium dose]: We conducted preplanned subgroup analysis based on the dose of tiotropium because the a priori base analysis combined tiotropium doses as one intervention arm. Overall, the data do not suggests any substantial differences in the overall conclusions when tiotropium doses were compared separately versus placebo or against each other (Appendix Table 21).

[underlined: Disease duration, age, smoking status, FEV1 percent predicted, allergic status, BMI]: Four^119,122,123^ of the 8 included RCTs conducted subgroup analysis within the original trial. Kertjens et al.,^119^ combined data from the two replicate trials and in a pre-planned subgroup analysis found the following did not influence outcomes of FEV1 peak and trough: disease duration, age, smoking history, FEV1 percent predicted at baseline, allergic status and body mass index (BMI). Hamelmann et al.,^123^ also found that age did not influence outcomes of FEV1 peak and trough. Paggiaro et al.,^122^ also found that age did not influence outcomes of FEV1 peak, trough and percent predicted, neither did smoking history.

### LAMA as Add-on to ICS Versus Increasing the ICS Dose

#### Overview of Studies

One cross-over trial^27^ (n=210) compared the addition of tiotropium 18mcg daily to the run-in dose of ICS versus doubling the dose of ICS for a treatment period of 15 weeks. This study was conducted in the US with nonindustry sponsorship and had a low risk of bias. Patients were required to be at least 18y old for enrollment (mean age 42y). Race was Caucasian in 54.8 percent of patients.

#### Results

There was no difference in the risk of exacerbations requiring oral or intravenous corticosteroids with tiotropium added to ICS versus doubling the ICS dose (low SOE). This trial^27^ also reported the number of patients with exacerbations that required oral corticosteroids or increased use of ICS or other asthma medications, which was not different with tiotropium added to ICS versus doubling the ICS dose (low SOE). No other exacerbation outcomes or death were reported. There was no difference with tiotropium added to ICS versus doubling the ICS dose for any other outcome analyzed including mean difference in ACQ-6, FEV1 trough and AQLQ (all low SOE).

## KQ2b What is the comparative effectiveness of LAMA compared to other controller therapy as add-on to ICS in patients 12 years of age and older with uncontrolled, persistent asthma?

### Key Points

- LAMA versus LABA as add-on to ICS does not significantly differ in their effect on the risk of exacerbations requiring systemic corticosteroids (low SOE) or risk of asthma worsening (moderate SOE), death (low SOE), asthma control composite scores (low to high SOE), spirometry measures (low to high SOE), asthma-specific quality of life (low to high SOE) or rescue medication use (low SOE).
- Few studies, limited to outcomes of FEV1 percent predicted and rescue medication use, compared LAMA to controllers other than LABA as add-on to ICS.

### LAMA Versus LABA as Add-on to ICS

#### Overview of Studies

Eight RCTs^27,118–120,146–148^ (n=3679) were included in the analysis of LAMA versus LABA as add-on to ICS, two of which were crossover in design.^27,120^ Two replicate trials were reported in a single publication and each trial results were considered unique except for the results that were only reported in a combined way.^119^ Four trials were multicenter, multinational trials reporting industry sponsorship.^118–120^ Two trials were conducted in India^146,147^ and 2 in the US,^122,148^ all of which were nonindustry sponsored. Trails ranged from 15d to 18m in duration. All trials required patients to be at least 18y old for enrollment (mean age 36 to 47). One trial^148^ enrolled only African Americans while patients in the remaining trials reporting race^27,118,120^ were mostly Caucasian (54.8% to 93.3%). All trials randomized patients to LAMA versus LABA in addition to background ICS therapy. Seven trials^27,118,119,146–148^ studied tiotropium and one^120^ studied umeclidinium. Four trials^27,118,119^ studied salmeterol, one studied vilanterol,^120^ two studied formoterol,^146,147^ and one studied either salmeterol or formoterol based on pre-study use.^148^ Two trials allowed concurrent asthma therapy that were similar across arms.^119^ Risk of bias was low in 5 trials,^27,118,119,148^ medium in 1 trial (open-label),^146^ high in 1 trial (open-label and significant attrition),^147^ and unclear in 1 trial.^120^

#### Results

There was no difference in the risk of exacerbation requiring systemic corticosteroids (Figure 10) or in the risk of asthma worsening when LAMA was compared with LABA as add-on to ICS. One trial reported exacerbations requiring oral corticosteroid or an increase in ICS or other asthma medication use and the risk was no different with LAMA versus LABA.^27^ Of the four trials that reported death, events occurred in a single trial^148^ and the odds of all-cause mortality or of asthma-specific mortality was no different with LAMA versus LABA.

Figure 10 Risk of exacerbation with LAMA versus LABA as add-on to ICS

CI = confidence interval; LABA = long-acting beta- agonist; LAMA = long-acting muscarinic antagonists; RR = relative risk

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on exacerbations requiring systemic corticosteroids in patients with asthma. Four trials were included in this analysis. The first trial by Peters and colleagues in 2010 provided a risk ratio of 0.60 with a 95 percent confidence interval of 0.15 to 2.42. The second trial by Bateman and colleagues in 2011 provided a risk ratio of 0.99 with a 95 percent confidence interval of 0.52 to 1.87. The third trial by Kerstjens and colleagues in 2015 is a combination of the two individual trials reported in that publication and provided a risk ratio of 0.81 with a 95 percent confidence interval of 0.54 to 1.24. The fourth trial by Lee and colleagues in 2015 provided a risk ratio of 6.93 with a 95 percent confidence interval of 0.36 to 133.57. The combined effect of these four trials showed a risk ratio of 0.87 with a 95 percent confidence interval of 0.53 to 1.42. The I-squared value was 0 percent with a p-value of 0.4895.

The mean difference in ACQ-7 score or the chance of being a responder was no different with LAMA versus LABA. One trial^27^ reported mean difference in ACQ-6 score which was no different with LAMA versus LABA. All measures of spirometry including mean difference in FEV1 percent predicted or in peak, trough and AUC for both FEV1 and FVC were no different with LAMA versus LABA. Asthma-specific quality of life measured by the mean difference in AQLQ was no different with LAMA versus LABA. One trial evaluated the mean difference in AQLQ-mini which also found no difference with LAMA versus LABA.^118^ The only health care utilization outcome reported was rescue medication use, defined as the mean puffs per 24 hours. The mean change in rescue medication use was no different with LAMA versus LABA.

#### Subgroup Data

[underlined: Disease duration, age, smoking status, FEV1 percent predicted, allergic status, BMI, bronchodilator reversibility]: Three^119,148^ of the 8 included RCTs conducted subgroup analysis within the original trial. Kertjens et al.,^119^ combined data from the two replicate trials and in a pre-planned subgroup analysis found the following did not influence outcomes of FEV1 peak and trough: disease duration, age, smoking history, FEV1 percent predicted at baseline, allergic status and BMI. Weschler et al.,^148^ reported no difference in treatment effects based on BMI or smoking history but those with bronchodilator reversibility at 1 month had a higher likelihood of exacerbation with tiotropium versus LABA compared with those without reversibility at 1 month.

### LAMA Versus Other Controllers as Add-on to ICS

#### Results

Two trials (n=320) of the above 8 trials also compared LAMA versus other controllers, including montelukast 10mg daily and doxofylline 400mg daily.^146,147^ Mean difference in FEV1 percent predicted was reduced in one trial with LAMA versus montelukast [MD −2.14 (−2.93 to −1.35)] but no different in the second trial [MD −0.87 (−2.77 to 1.03)]. Mean difference in FEV1 percent predicted was reduced with LAMA versus doxofylline by −2.69 percent and −3.87 percent in two trials (moderate SOE). Mean difference in rescue medication use was inconsistent in the two trials comparing LAMA versus montelukast [MD 0.26 [−0.25 to 0.77) and [MD 1.19 (0.88 to 1.50)] as well as in the two trials comparing LAMA versus doxofylline [MD 0.30 (−0.21 to 0.81) and MD 1.21 (0.89 to 1.53)].

## KQ2c What is the comparative effectiveness of LAMA as add-on to ICS plus LABA compared to ICS plus LABA as controller therapy in patients 12 years of age and older with uncontrolled, persistent asthma?

### Key Points

- LAMA added to ICS plus LABA versus ICS plus LABA does not significantly differ in effect on the risk of asthma exacerbations (low to moderate SOE) but does decrease the risk of asthma worsening (high SOE).
- LAMA added to ICS plus LABA versus ICS plus LABA improved the mean difference in FEV1 AUC and of peak, trough and AUC for FVC (all high SOE), the chance of being an ACQ responder (low to moderate SOE) and the chance of being an AQLQ responder (moderate SOE). There was no difference in asthma control composite scores (low to moderate SOE) or in rescue medication use (moderate SOE).
- In the single trial that compared LAMA added to ICS plus LABA versus increasing the ICS dose and continuing LABA found no significant difference in effect on the mean difference in ACT score.

### LAMA as Add-on to ICS Plus LABA Versus ICS Plus LABA

#### Overview of Studies

Three trials^150,152^ (n=1304) were included in the analysis of LAMA as add-on to ICS plus LABA versus ICS plus LABA. All trials were multicenter, multinational trials reporting industry sponsorship and had low risk of bias. Two trials^150^ required patients to be at least 18y for enrollment (mean age 51 to 53y) while the third trial^152^ focused on patients ages 12 to 17y (mean age 14y). Most patients were Caucasian (82.1% to 94.6%). Two replicate trials randomized patients taking ICS plus LABA to either tiotropium 5μg daily or placebo for 48 weeks.^150^ Concurrent asthma therapies were allowed and use was similar in both arms. These two trials were reported in a single publication and each trial was considered unique in the analyses unless the results were only reported in the source documents in a combined fashion.^150^ The third trial included patients taking high-dose ICS plus one other controller or medium-dose ICS plus two other controllers and randomized patients to tiotropium 2.5μg daily, 5μg daily or placebo for 12 weeks.^152^ LABA was the most common additional controller (83.2%) while use of other controllers was similar in both groups.

#### Results

There was no difference in the risk of exacerbation requiring systemic corticosteroids (Figure 11, Panel A) or in the risk of exacerbation requiring hospitalization when LAMA added to ICS plus LABA was compared with ICS plus LABA. The risk of asthma worsening was reduced by 22 percent with LAMA added to ICS plus LABA versus ICS plus LABA (high SOE) (Figure 11, Panel B). All three trials reported that no deaths occurred.

Figure 11 Risk of exacerbation and of asthma worsening with LAMA as add-on to ICS and LABA versus ICS and LABA

CI = confidence interval; LAMA = long-acting muscarinic antagonists; RR = relative risk

Panel A of this figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on exacerbations requiring systemic corticosteroids in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a risk ratio of 0.73 with a 95 percent confidence interval of 0.54 to 0.99. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a risk ratio of 0.91 with a 95 percent confidence interval of 0.70 to 1.19. The third trial by Hamelmann and colleagues in 2016 provided a risk ratio of 1.58 with a 95 percent confidence interval of 0.17 to 15.00. The combined effect of these three trials showed a risk ratio of 0.84 with a 95 percent confidence interval of 0.57 to 1.22. The I-squared value was 0 percent with a p-value of 0.473. Panel B of this figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on asthma worsening in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a risk ratio of 0.79 with a 95 percent confidence interval of 0.67 to 0.94. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a risk ratio of 0.79 with a 95 percent confidence interval of 0.67 to 0.93. The third trial by Hamelmann and colleagues in 2016 provided a risk ratio of 0.69 with a 95 percent confidence interval of 0.43 to 1.12. The combined effect of these three trials showed a risk ratio of 0.78 with a 95 percent confidence interval of 0.72 to 0.86. The I-squared value was 0 percent with a p-value of 0.8705.

The MD in ACQ score (whether ACQ-6 or ACQ-7) was no different with LAMA added to ICS plus LABA versus ICS plus LABA. The chance of being an ACQ responder, regardless of the ACQ version, favored LAMA in the combined results of two replicate trials of 48 weeks duration but was no different with LAMA in the single trial of 12 weeks duration.^142^ Most measures of lung function obtained from spirometry were improved with LAMA added to ICS plus LABA versus ICS plus LABA including FEV1 AUC (MD 0.10 L), peak FVC (MD 0.11 L), trough FVC (MD 0.09 L) and FVC AUC (MD 0.10 L) (all with high SOE). Data suggest a trend towards improved peak and trough FEV1 with the lower limit of the confidence interval at zero. Mean difference in AQLQ was no different with LAMA added to ICS plus LABA versus ICS plus LABA although the chance of being an AQLQ responder was increased by 62 percent with LAMA added to ICS plus LABA versus ICS plus LABA. The only health care utilization outcome reported was rescue medication use, defined as the mean puffs per 24 hours. The mean change in rescue medication use was no different with LAMA added to ICS plus LABA versus ICS plus LABA.

#### Subgroup Data

We identified one post-hoc analysis^173^ by Kerstjens et al., that combined data from two previous replicate trials^150^ and found ACQ-7 responder rate at week 24 was influenced by smoking status and screening FEV1 percent predicted, favoring a response with tiotropium 5mcg versus placebo in ex-smokers and in those with lower FEV1 percent predicted at screening. ACQ-7 responder at 48 weeks was influenced by blood eosinophils favoring a response with tiotropium 5mcg versus placebo with lower blood counts. The following characteristics did not influence outcomes: age, race, ethnicity, disease duration, BMI, screening FEV1 percent predicted, FEV1 percent reversibility, clinician-determined allergic status and serum IgE.

### LAMA as Add-on to ICS Plus LABA Versus ICS Plus LABA With a Higher ICS Dose

#### Overview of Studies

One trial (n=63) randomized participants taking salmeterol/fluticasone 50/250mcg twice daily to either add-on tiotropium 18μg daily or to increasing the salmeterol/fluticasone dose to 50/500mcg twice daily.^151^ The trial was conducted in China, funding was not reported, and the risk of bias was unclear. The population was referred to as “adults” and the mean age was 35 to 36.

#### Results

The only outcome reported was mean difference in ACT score which was no different LAMA added to ICS plus LABA versus increasing the ICS dose and continuing LABA.^151^