# References

1 Expert Panel Report 3: guidelines for the diagnosis and management of asthma. National Asthma Education and Prevention Program, Third Expert Panel on the Diagnosis and Management of Asthma. Bethesda (MD). Report No: 07-4051. Washington, DC: National Heart, Lung, and Blood Institute; 2007.
2 Most recent asthma data. Centers for Disease Control and Prevention. Available at: http://www.cdc.gov/asthma/most_recent_data.htm [Accessed June 15, 2017].
3 The Global Asthma Report 2014. Auckland, New Zealand: Global Asthma Network, 2014.
4 Asthma national health statistics. Centers for Disease Control and Prevention. Available at: http://www.cdc.gov/nchs/fastats/asthma.htm [Accessed June 15, 2017].
5 National Heart, Lung and Blood Advisory Council Asthma Expert Working Group. Needs Assessment Report for Potential Update of the Expert Panel Report-3 (2007): Guidelines for the Diagnosis and Management of Asthma. 2015.
6 Herndon JB, Mattke S, Evans CA, . Anti-inflammatory medication adherence, healthcare utilization and expenditure among Medicaid children’s health insurance program enrollees with asthma. Pharmacoeconomics. 2012;30:397–412. PMID: 2226844422268444
7 Williams LK, Peterson EL, Wells K. . Quantifying the proportion of severe asthma exacerbations attributable to inhaled corticosteroid nonadherence. J Allergy Clin Immunol. 2011;128:1185.e2–1191.e2. PMID: 2201909022019090
8 Morton RW, Everard ML, Elphick HE. Adherence in childhood asthma: the elephant in the room. Arch Dis Child. 2014;99:949–953. PMID: 2487630324876303
9 Krishnan JA, Bender BG, Wamboldt FS, . Adherence to inhaled corticosteroids: an ancillary study of the childhood athma management program clinical trial. J Allergy Clin Immunol. 2012;129:112–118. PMID: 2210461022104610
10 Desai M, Oppenheimer JJ. Medication adherence in the asthmatic child and adolescent. Curr Allergy Asthma Rep. 2011;11:454–464. PMID: 2196861821968618
11 Lasmar L, Camargos P, Champs NS, . Adherence rate to inhaled corticosteroids and their impact on asthma control. Allergy. 2009;64:784–789. PMID: 1918316619183166
12 Schatz M, Cook EF, Nakahiro R, Petitti D. Inhaled corticosteroids and allergy specialty care reduce emergency hospital use for asthma. J Allergy Clin Immunol.2003;111:503–508. PMID: 1264282912642829
13 Sabate E. Adherence to longterm therapies: evidence for action. Geneva: World Health Organization; 2003.
14 Jackson DJ. Emerging issues in pediatric asthma: gaps in EPR-3 guidelines for infants and children. Curr Allergy Asthma Rep. 2014;14:477. PMID: 25269401.25269401
15 Hoch HE, Szefler SJ. Intermittent steroid inhalation for the treatment of childhood asthma. Expert Rev Clin Immunol. 2016;12:183–194. PMID: 26561351.26561351
16 Peters M. Single-inhaler combination therapy for maintenance and relief of asthma. Drugs. 2009;69:137–150. PMID: 19228072.19228072
17 Spiriva Respimat [package insert]. Boehringer Ingelheim Pharmaceuticals, Inc. Ridgefield, CT. 2016
18 Higgins JPT, Altman DG, Gotzsche PC, . The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. PMID: 22008217.22008217
19 Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Available from http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed December 13, 2016.
20 Viswanathan M, Ansari MT, Berkman ND, . Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions; 2012. In: Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
21 Higgins JPT, Green S (editors). Cochrane Handbook for Systematic Reviews of Interventions Version 5.1.0 [updated March 2011]. The Cochrane Collaboration, 2011. Available from www.handbook.cochrane.org.
22 Hartung J, Knapp G. On tests of the overall treatment effect in meta-analysis with normally distributed responses. Stats Med. 2001 May;20;1771–82. PMID: 11406840.11406840
23 Hartung J, Knapp G. A refined method for meta-analysis of controlled clinical trials with binary outcomes. Stats Med. 2001 Dec;20(24);3875–89. PMID: 11782040.11782040
24 Bradburn MJ, Deeks JJ, Berlin JA, . Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. 2007;26:53–77. PMID: 1659657216596572
25 Higgins JP, Thomas SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327:557–60. PMID: 12958120.12958120
26 Egger M, Davey Smith G, Schneider M, Minder C. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629–34. PMID: 9310563.9310563
27 Peters SP, Kunselman SJ, Icitovic N, . Tiotropium bromide step-up therapy for adults with uncontrolled asthma. N Engl J Med. 2010 Oct 28;363(18):1715–26. PMID: 20979471.20979471
28 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update, 2013. In: Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville MD: Agency for Healthcare Research and Quality; 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
29 Atkins D, Chang S, Gartlehner G, . Assessing the Applicability of Studies When Comparing Medical Interventions; 2010. In: Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
30 Lazarus SC, Chinchilli VM, Rollings NJ, . Smoking affects response to inhaled corticosteroids or leukotriene receptor antagonists in asthma. Am J Respir Crit Care Med. 2007;175:783–90. PMID:1720472517204725
31 Berger WE, Bleecker ER, O-Dowd L, . Efficacy and safety of budesonide/formoterol pressurized metered-dose inhaler: randomized controlled trial comparing once- and twice-daily dosing in patients with asthma. Allergy Asthma Proc. 2010;31:49–59. PMID:2016714520167145
32 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; January 2014. Chapters available at www.effectivehealthcare.ahrq.gov.
33 Schatz M, Kosinski M, Yarlas A, . The minimally important difference of the Asthma Control Test. J Allergy Clin Immunol. 2009;124:719–23. PMID: 19767070.19767070
34 Juniper E, Svensson K, Mork AC, . Measurement properties and interpretation of three shortened versions of the asthma control questionnaire. Respir Med. 2005 May;99:553–8. PMID: 15823451.15823451
35 Juniper EF, Gruffydd-Jones K, Ward S, . Asthma Control Questionnaire in children: validation, measurement properties, interpretation. Eur Respir J. 2010;36:1410–6. PMID: 20530041.20530041
36 Juniper EF, Buist S, Cox FM, . Validation of a standardized version of the Asthma Quality of Life Questionnaire. Chest. 1999;115:1265–70. PMID: 10334138.10334138
37 Juniper EF, Guyatt GH, Cox FM, . Development and validation of the Mini Asthma Quality of Life Questionnaire. Eur Respir .J. 1999;14:32–8. PMID: 10489826.10489826
38 Juniper EF, Guyatt GH, Willam A, . Determining a minimal important change in disease-specific quality of life questionnaire. J Clin Epidemiol. 1994;47(1):81–7. PMID: 8283197.8283197
39 Juniper EF, Svensson K, Mork AC, . Modification of the asthma quality of life questionnaire (standardized) for patients 12 years and older. Health Qual Life Outcomes. 2005;3:58. PMID: 16168050.16168050
40 Wyrwich KW, Ireland AM, Navaratnam P, . Validation of the AQLQ12+ among adolescents and adults with persistent asthma. Qual Life Res. 2011;20:903–12. PMID: 21184185.21184185
41 Juniper EF, Guyatt GH, Feeny DH, . Measuring quality of life in children with asthma. Qual Life Res. 1996;5:35–46. PMID: 8901365.8901365
42 Juniper EF, Guyatt GH, Feeny DH, . Measuring quality of life in the parents of children with asthma. Qual Life Res. 1996;5:27–34. PMID: 8901364.8901364
43 Santanello NC, Zhang J, Seidenberg B, . What are minimal important changes for asthma measures in a clinical trial? Eur Respir J. 1999,14:23–7. PMID: 10489824.10489824
44 Bacharier LB1, Phillips BR, Zeiger RS, . Episodic use of an inhaled corticosteroid or leukotriene receptor antagonist in preschool children with moderate-to-severe intermittent wheezing. J Allergy Clin Immunol. 2008 Dec;122(6):1127–1135. PMID: 18973936.18973936
45 Ducharme FM, Lemire C, Noya FJ, . Preemptive use of high-dose fluticasone for virus-induced wheezing in young children. N Engl J Med. 2009 Jan 22;360(4):339–53. PMID: 19164187.19164187
46 Ghirga G, Ghirga P, Fagioli S, . Intermittent treatment with high dose nebulized beclomethasone for recurrent wheezing in infants due to upper respiratory tract infection. Minerva Pediatr. 2002 Jun;54(3):217–20. PMID: 12070480.12070480
47 Papi A, Nicolini G, Baraldi E, . Regular vs prn nebulized treatment in wheeze preschool children. Allergy. 2009 Oct;64(10):1463–71. PMID: 19772514.19772514
48 Svedmyr J, Nyberg E, Thunqvist P, . Prophylactic intermittent treatment with inhaled corticosteroids of asthma exacerbations due to airway infections in toddlers. Acta Paediatr. 1999 Jan;88(1):42–7. PMID: 10090546.10090546
49 Zeiger RS, Mauger D, Bacharier LB, . Daily or intermittent budesonide in preschool children with recurrent wheezing. N Engl J Med. 2011 Nov 24;365(21):1990–2001. PMID: 22111718.22111718
50 Milton S. Hershey Medical Center; National Heart, Lung, and Blood Institute (NHLBI). Childhood Asthma Research and Education (CARE) network trial – maintenance versus intermittent inhaled steroids in wheezing toddlers (MIST). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Dec 2]. https://clinicaltrials.gov/ct2/show/NCT00675584. NLM Identifier: NCT0067558.
51 Boushey HA, Sorkness CA, King TS, . Daily versus as-needed corticosteroids for mild persistent asthma. N Engl J Med. 2005 Apr 14;352(15):1519–28. PMID: 15829533.15829533
52 Calhoun WJ, Ameredes BT, King TS, . Comparison of physician-, biomarker-, and symptom-based strategies for adjustment of inhaled corticosteroid therapy in adults with asthma: the BASALT randomized controlled trial. JAMA. 2012 Sep 12;308(10):987–97. PMID: 22968888.22968888
53 Milton S. Hershey Medical Center; National Heart, Lung, and Blood Institute (NHLBI). Asthma Clinical Research Network (ACRN) trial- best adjustment strategy for asthma in long term (BASALT). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Dec 2]. https://clinicaltrials.gov/ct2/show/NCT00495157. NLM Identifier: NCT00495157.
54 Colland VT, van Essen-Zandvliet LE, Lans C, . Poor adherence to self-medication instructions in children with asthma and their parents. Patient Educ Couns. 2004 Dec;55(3):416–21. PMID: 15582348.15582348
55 FitzGerald JM, Becker A, Sears MR, . Doubling the dose of budesonide versus maintenance treatment in asthma exacerbations. Thorax. 2004 Jul;59(7):550–6. PMID: 15223858.15223858
56 Foresi A, Morelli MC, Catena E. Low-dose budesonide with the addition of an increased dose during exacerbations is effective in long-term asthma control. Chest. 2000 Feb;117(2):440–6. PMID: 10669688.10669688
57 Gerald JK, Gerald LB, Vasquez MM, . Markers of differential response to inhaled corticosteroid treatment among children with mild persistent asthma. J Allergy Clin Immunol Pract. 2015 Jul–Aug;3(4):540–6. PMID: 25783161.25783161
58 Gerald JK, Gerald LB, Chinchilli VM, . Adherence to rescue inhaled corticosteroid use during the TREXA trial. Am J Respir Crit Care Med. 2012;185:A2200. DOI: http://dx.doi.org/10.1164/ajrccm-conference.2012.185.1_MeetingAbstracts.A2200
59 Harrison TW, Oborne J, Newton S, . Doubling the dose of inhaled corticosteroid to prevent asthma exacerbations: randomised controlled trial. Lancet. 2004 Jan 24;363(9405):271–5. PMID: 14751699.14751699
60 Martinez FD, Chinchilli VM, Morgan WJ, . Use of beclomethasone dipropionate as rescue treatment for children with mild persistent asthma (TREXA): a randomised, double-blind, placebo-controlled trial. Lancet. 2011 Feb 19;377(9766):650–7. PMID: 21324520.21324520
61 Milton S. Hershey Medical Center; National Heart, Lung, and Blood Institute (NHLBI). Childhood Asthma Research and Education (CARE) network trial – treating children to prevent exacerbations of asthma (TREXA). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Dec 2]. https://clinicaltrials.gov/ct2/show/NCT00394329. NLM Identifier: NCT00394329.
62 Oborne J, Mortimer K, Hubbard RB, . Quadrupling the dose of inhaled corticosteroid to prevent asthma exacerbations: a randomized, double-blind, placebo-controlled, parallel-group clinical trial. Am J Respir Crit Care Med. 2009 Oct 1;180(7):598–602. PMID: 19590019.19590019
63 Papi A, Canonica GW, Maestrelli P, . Rescue use of beclomethasone and albuterol in a single inhaler for mild asthma. N Engl J Med. 2007 May 17;356(20):2040–52. PMID: 17507703.17507703
64 Turpeinen M, Nikander K, Pelkonen AS, . Daily versus as-needed inhaled corticosteroid for mild persistent asthma (The Helsinki early intervention childhood asthma study). Arch Dis Child, 2008 Aug;93(8):654–9. PMID: 17634183.17634183
65 Morelli MC, Bordonaro S, Chiesa M, . Clinical efficacy of a new treatment regimen with inhaled budesonide in moderate asthma. Eur Respir J. 1996;9;Suppl 12:79s.
66 Oborne J, Hubbard RB, Tattersfield AE, . Can acute exacerbations of asthma be prevented with a four-fold increase in inhaled corticosteroid dose? Am J Respir Crit Care Med. 2009;179:A2794. DOI: http://dx.doi.org/10.1164/ajrccm-conference.2009.179.1_MeetingAbstracts.A2794
67 Lahdensuo A, Haahtela T, Herrala, . Randomised comparison of guided self management and traditional treatment of asthma over one year. BMJ. 1996 Mar;312(7033):748–52. PMID: 8605463.8605463
68 Lahdensuo, Haahtela T, Herrala J, . PEF-guided use of an inhaled corticosteroid is successful. The FINNISH asthma-self management study. Eur Respir J. 1994;7;Suppl 18:142s.
69 Ambrose HJ, Lawrance RM, Cresswell CJ, . Effect of β2-adrenergic receptor gene (ADRB2) 3′ untranslated region polymorphisms on inhaled corticosteroid/long-acting β2-adrenergic agonist response. Respir Res. 2012 May 4;13:37. PMID: 22559839.22559839
70 Atienza T, Aquino T, Fernández M, . Budesonide/formoterol maintenance and reliever therapy via Turbuhaler versus fixed-dose budesonide/formoterol plus terbutaline in patients with asthma: phase III study results. Respirolog. 2013 Feb;18(2):354–63. PMID: 23126237.23126237
71 AstraZeneca. Study to investigate the efficacy of Symbicort SMART (SAKURA). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Dec 2]. https://clinicaltrials.gov/ct2/show/NCT00839800. NLM Identifier: NCT00839800.
72 Atienza T, Aquino T, Fernandez M, . Budesonide/formoterol maintenance and reliever therapy via turbuhaler vs fixed-dose budesonide/formoterol plus terbutaline in patients with asthma: phase iii study results. Am J Respir Crit Care Med. 2012;185:A3950. DOI: http://dx.doi.org/10.1164/ajrccm-conference.2012.185.1_MeetingAbstracts.A3950
73 Bateman ED, Harrison TW, Quirce S, . Overall asthma control achieved with budesonide/formoterol maintenance and reliever therapy for patients on different treatment steps. Respir Res. 2011 Apr 4;12:38. PMID: 21463522.21463522
74 Bateman ED, Reddel HK, Eriksson G, . Overall asthma control: the relationship between current control and future risk. J Allergy Clin Immunol. 2010 Mar;125(3):600–8. PMID: 20153029.20153029
75 Bisgaard H, Le Roux P, Bjåmer D, . Budesonide/formoterol maintenance plus reliever therapy: a new strategy in pediatric asthma. Chest. 2006 Dec;130(6):1733–43. PMID: 17166990.17166990
76 Bousquet J, Boulet LP, Peters MJ, . Budesonide/formoterol for maintenance and relief in uncontrolled asthma vs. high-dose salmeterol/fluticasone. Respir Med. 2007 Dec;101(12):2437–46. PMID: 17905575.17905575
77 Buhl R, Kuna P, Peters MJ, . The effect of budesonide/formoterol maintenance and reliever therapy on the risk of severe asthma exacerbations following episodes of high reliever use: an exploratory analysis of two randomised, controlled studies with comparisons to standard therapy. Respir Res. 2012 Jul 20;13:59. PMID: 22816878.22816878
78 Hozawa S, Terada M, Hozawa M. Comparison of the effects of budesonide/formoterol maintenance and reliever therapy with fluticasone/salmeterol fixed-dose treatment on airway inflammation and small airway impairment in patients who need to step-up from inhaled corticosteroid monotherapy. Pulm Pharmacol Ther. 2014 Apr;27(2):190–6. PMID: 24388868.24388868
79 Kardos P. Budesonide/formoterol maintenance and reliever therapy versus free-combination therapy for asthma: a real-life study. Pneumologie. 2013 Aug;67(8):463–70. PMID: 23904191.23904191
80 Kuna P. Treatment comparison of budesonide/formoterol with salmeterol/fluticasone propionate in adults aged ≥16 years with asthma: post hoc analysis of a randomized, double-blind study. Clin Drug Investig. 2010;30(9):565–79. PMID: 20593912.20593912
81 Kuna P, Peters MJ, Manjra AI, . Effect of budesonide/formoterol maintenance and reliever therapy on asthma exacerbations. Int J Clin Pract. 2007 May;61(5):725–36. PMID: 17362472.17362472
82 Louis R, Joos G, Michils A, . A comparison of budesonide/formoterol maintenance and reliever therapy vs. conventional best practice in asthma management. Int J Clin Pract. 2009 Oct;63(10):1479–88. PMID: 19769705.19769705
83 O’Byrne PM, Bisgaard H, Godard PP, . Budesonide/formoterol combination therapy as both maintenance and reliever medication in asthma. Am J Respir Crit Care Med. 2005 Jan 15;171(2):129–36. PMID: 15502112.15502112
84 Papi A, Corradi M, Pigeon-Francisco C, . Beclometasone-formoterol as maintenance and reliever treatment in patients with asthma: a double-blind, randomised controlled trial. Lancet Respir Med. 2013 Mar;1(1):23–31. PMID: 24321801.24321801
85 Patel M, Pilcher J, Hancox RJ, . The use of β2-agonist therapy before hospital attendance for severe asthma exacerbations: a post-hoc analysis. NPJ Prim Care Respir Med. 2015 Jan 8;25:14099. PMID: 25569185.25569185
86 Patel M, Pilcher J, Pritchard A, . Efficacy and safety of maintenance and reliever combination budesonide-formoterol inhaler in patients with asthma at risk of severe exacerbations: a randomised controlled trial. Lancet Respir Med. 2013 Mar;1(1):32–42. PMID: 24321802.24321802
87 Patel M, Pilcher J, Reddel HK, . Predictors of severe exacerbations, poor asthma control, and β-agonist overuse for patients with asthma. J Allergy Clin Immunol Pract. 2014 Nov–Dec;2(6):751–8. PMID: 25439367.25439367
88 Patel M, Pilcher J, Shaw D, . A randomised controlled trial of single combination budesonide/formoterol inhaler as maintenance and reliever therapy in asthma patietns at risk of severe exacerbations. Thorax. 2013(68):A148. DOI: 10.1136/thoraxjnl-2013-204457.312.
89 Pavord ID, Jeffery PK, Qiu Y, . Airway inflammation in patients with asthma with high-fixed or low-fixed plus as-needed budesonide/formoterol. J Allergy Clin Immunol. 2009 May;123(5):1083–9. PMID: 19368965.19368965
90 Pilcher J, Patel M, Smith A, . Combination budesonide/formoterol inhaler as maintenance and reliever therapy in Māori with asthma. Respirology. 2014 Aug;19(6):842–51. PMID: 24889937.24889937
91 Quirce S, Barcina C, Plaza V, . A comparison of budesonide/formoterol maintenance and reliever therapy versus conventional best practice in asthma management in Spain. J Asthma. 2011 Oct;48(8):839–47. PMID: 21942354.21942354
92 AstraZeneca. Symbicort single inhaler therapy vs conventional best practice for the treatment of persistent asthma in adults. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Dec 2]. https://clinicaltrials.gov/ct2/show/NCT00385593. NLM Identifier: NCT00385593.
93 Rabe KF, Atienza T, Magyar P, . Effect of budesonide in combination with formoterol for reliever therapy in asthma exacerbations: a randomised controlled, double-blind study. Lancet. 2006 Aug 26;368(9537):744–53. PMID: 16935685.16935685
94 Rabe KF, Pizzichini E, Ställberg B, . Budesonide/formoterol in a single inhaler for maintenance and relief in mild-to-moderate asthma: a randomized, double-blind trial. Chest. 2006 Feb;129(2):246–56. PMID: 16478838.16478838
95 Riemersma RA, Postma D, van der Molen T. Budesonide/formoterol maintenance and reliever therapy in primary care asthma management: effects on bronchial hyperresponsiveness and asthma control. Prim Care Respir J. 2012 Mar;21(1):50–6. PMID: 22015542.22015542
96 Scicchitano R, Aalbers R, Ukena D, . Efficacy and safety of budesonide/formoterol single inhaler therapy versus a higher dose of budesonide in moderate to severe asthma. Curr Med Res Opin. 2004 Sep;20(9):1403–18. PMID: 15383189.15383189
97 Sears MR, Boulet LP, Laviolette M, . Budesonide/formoterol maintenance and reliever therapy: impact on airway inflammation in asthma. Eur Respir J. 2008 May;31(5):982–9. PMID: 18216054.18216054
98 Søes-Petersen U, Kava T, Dahle R, . Budesonide/formoterol maintenance and reliever therapy versus conventional best standard treatment in asthma in an attempted ‘real life’ setting. Clin Respir J. 2011 Jul;5(3):173–82. PMID: 21679353.21679353
99 Sovani MP, Whale CI, Oborne J, . Poor adherence with inhaled corticosteroids for asthma: can using a single inhaler containing budesonide and formoterol help? Br J Gen Pract. 2008 Jan;58(546):37–43. PMID: 18186995.18186995
100 Ställberg B, Ekström T, Neij F, . A real-life cost-effectiveness evaluation of budesonide/formoterol maintenance and reliever therapy in asthma. Respir Med. 2008 Oct;102(10):1360–70. PMID: 18723335.18723335
101 Takeyama K, Kondo M, Tagaya E, . Budesonide/formoterol maintenance and reliever therapy in moderate-to-severe asthma: effects on eosinophilic airway inflammation. Allergy Asthma Proc. 2014 Mar–Apr;35(2):141–7. PMID: 24717791.24717791
102 Takeyama K, Konodo M, Tagaya E, . Efficacy and tolerability of budesonide/formoterol maintenance and reliever therapy in Japanese patients with moderate to severe persistent asthma. Am J Respir Crit Care Med. 2013;187:A2730. Embase 71982190.
103 Vogelmeier C, D’Urzo A, Pauwels R, . Budesonide/formoterol maintenance and reliever therapy: an effective asthma treatment option? Eur Respir J. 2005 Nov;26(5):819–28. PMID: 16264042.16264042
104 Vogelmeier C, Naya I, Ekelund J. Budesonide/formoterol maintenance and reliever therapy in Asian patients (aged ≥16 years) with asthma: a sub-analysis of the COSMOS study. Clin Drug Investig. 2012 Jul 1;32(7):439–49. PMID: 22607479.22607479
105 Weatherall M, Patel M, Pilcher J, . Predictors of severe asthma exacerbations, poor asthma control and beta-agonist overuse in adult asthma. Eur Respir J. 2013;42:P776. Embase 71842638.
106 Pilcher J, Patel M, Smith A, . Single budesonide/formoterol inhaler as maintenance and reliever therapy is beneficial in Maori asthma. Respirology. 2013;18;Suppl 2:44.
107 Kuna P, Peters M, Buhl R. Budesonide/formoterol for maintenance and relief vs. higher dose ICS/LABA therapy: outcomes in patients symptomatic on high-dose inhaled corticosteroids (HDICS). Eur Respir J. 2007;30;Suppl 51:357s.
108 Bousquet J, Boulet LP, AHEAD Investigators. Budesonide/formoterol as maintenance and reliever therapy in uncontrolled asthma compared with high dose salmeterol/fluticasone: the AHEAD double-blind study. Eur Respir J. 2007;30;Suppl 51:358s.
109 Rabe KF, Pizzichini E, Stallberg B, . Single inhaler therapy with budesonide/formoterol provides superior asthma control compared with fixed dosing with budesonide plus terbutaline as-needed. J Allergy Clin Immunol. 2004 Feb;113;Suppl 2:S116.
110 Scicchitano R, Aalbers R, Ukena D, . Single inhaler therapy with budesonide/formoterol reduces the risk of severe exacerbations compared with budesonide plus terbutaline as-needed in patients with asthma. J Allergy Clin Immunol. 2004 Feb;113;Suppl 2:S116.
111 Pistolesi M, Godard P, Aalbers R, . Budesonide/formoterol single inhaler therapy (SiT) provides superior asthma control compared with fixed dose (FD) budesonide or budesonide/formoterol in patients with severe persistent asthma. Eur Respir J. 2004;24;Suppl 48:509s.
112 Sovani MP, Whale CI, Oborne J, . The effect of providing a single inhaler containing formoterol and budesonide to be used once daily and as required on inhaled budesonide use and asthma control in poorly compliant patients. Thorax. 2004;59;Suppl ii:ii11.
113 Lin JT, Chen P, Zhou X, . Budesonide/formoterol maintenance and reliever therapy in Chinese patients with asthma. Chin Med J. 2012 Sep;125(17):2994–3001. PMID: 22932169.22932169
114 Loh LC, Lim BK, Raman S, . Budesonide/formoterol combination therapy as both maintenance and reliever medication in moderate-to-severe asthma: a real-life effectiveness study of Malaysian patients. Med J Malaysia. 2008 Aug;63(3):188–92. PMID: 19248687.19248687
115 Lundborg M, Wille S, Bjermer L, . Maintenance plus reliever budesonide/formoterol compared with a higher maintenance dose of budesonide/formoterol plus formoterol as reliever therapy in asthma: an efficacy and cost-effectiveness study. Curr Med Res Opin. 2006 May;22(5):809–21. PMID: 16709303.16709303
116 Pilcher J, Patel M, reddel H, . Effect of smoking status on the efficacy of SMART regimen in high risk asthma. Respirology.2016;21:858–866. PMID: 2689738926897389
117 Hozawa S, Terada M, Haruta Y, Hozawa M. Comparison of early effects of budesonide/formoterol maintenance and reliever therapy with fluticasone furoate/Vilanterol for asthma patients requiring step-up from inhaled corticosteroid monotherapy. Pulmonary Pharmacology & Therapeutics. 2016;37:15–23. PMID: 2685030726850307
118 Bateman ED, Kornmann O, Schmidt P, . Tiotropium is noninferior to salmeterol in maintaining improved lung function in B16-Arg/Arg patients with asthma. J Allergy Clin Immun. 2011 Aug;128(2):315–22. PMID: 21807250.21807250
119 Kerstjens HA, Casale TB, Bleecker ER, . Tiotropium or salmeterol as add-on therapy to inhaled corticosteroids for patients with moderatesymptomatic asthma: two replicate, double-blind, placebo-controlled, parallel-group, active-comparator, randomised trials. Lancet Respir Med. 2015 May;3(5):367–76. PMID: 25682232.25682232
120 Lee LA, Yang S, Kerwin E, . The effect of fluticasone furoate/umeclidinium in adult patients with asthma: a randomized, dose-ranging study. Respir Med. 2015 Jan;109(1):54–62. PMID: 25452139.25452139
121 Ohta K, Ichinose M, Tohda Y, . Long-term once-daily tiotropium respimat is well tolerated and maintains efficacy over 52 weeks in patients with symptomatic asthma in Japan: a randomized, placebo-controlled study. PLoS One. 2015 Apr 20;10(4):e0124109. PMID: 25894430.25894430
122 Paggiaro P, Halpin DM, Buhl R, . The effect of tiotropium in symptomatic asthma despite low- to medium-dose inhaled corticosteroids: a randomized controlled trial. J Allergy Clin Immunol Pract. 2016 Jan–Feb;4(1):104–13. PMID: 26563670.26563670
123 Hamelmann E, Bateman ED, Vogelberg C, . Tiotropium add-on therapy in adolescents with moderate asthma: A 1-year randomized controlled trial. J Allergy Clin Immunol. 2016 Aug;138(2):441–450. PMID: 26960245.26960245
124 Boehringer Ingelheim. Efficacy and safety of tiotropium and salmeterol in moderate persistent asthma patients homozygous for B16-Arg/Arg. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 29]. https://clinicaltrials.gov/ct2/show/NCT00350207. NLM Identifier: NCT00350207.
125 Boehringer Ingelheim. Evaluation of tiotropium 2.5 and 5 mcg once daily delivered via the Respimat® inhaler compared to placebo and salmeterol hydrofluoroalkane (HFA) metered dose inhaler (MDI) (50 mcg twice daily) in patient with moderate persistent asthma I. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 29]. https://clinicaltrials.gov/ct2/show/NCT01172808. NLM Identifier: NCT01172808.
126 Boehringer Ingelheim. Evaluation of tiotropium 2.5 and 5 mcg once daily delivered via the Respimat® inhaler compared to placebo and salmeterol hydrofluoroalkane (HFA) metered dose inhaler (MDI) (50 mcg twice daily) in patient with moderate persistent asthma II. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 29]. https://clinicaltrials.gov/ct2/show/NCT01172821. NLM Identifier: NCT01172821.
127 Boehringer Ingelheim. Evaluation of tiotropium 2.5 and 5μg once daily delivered via the respimat inhaler compared to placebo in patient with moderate to severe persistent asthma. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 29]. https://clinicaltrials.gov/ct2/show/NCT01340209. NLM Identifier: NCT01340209.
128 Boehringer Ingelheim. Efficacy and safety of 2 doses of tiotropium via respimat in adult patients with mild persistent asthma. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 29]. https://clinicaltrials.gov/ct2/show/NCT01316380. NLM Identifier: NCT01316380.
129 Boehringer Ingelheim. Efficacy and safety of 2 doses of tiotropium via respimat compared to placebo in adolescents with moderate persistent asthma. In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 29]. https://clinicaltrials.gov/ct2/show/NCT01275230. NLM Identifier: NCT01275230.
130 Milton S. Hershey Medical Center. Asthma Clinical Research Network (ACRN) trial – tiotropium bromide as an alternative to increased inhaled corticosteroid in patients inadequately controlled on a lower dose of inhaled corticosteroid (TALC). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 29]. https://clinicaltrials.gov/ct2/show/NCT00565266. NLM Identifier: NCT00565266.
131 Casale T, Bleecker E, Meltzer E, . Phase III trials to investigate tiotropium as add-on therapy to inhaled corticosteroids for patients with symptomatic asthma: trial design and planned statistical analysis. Allergy. 2013;68;Suppl 97:377.
132 Casale TB, Bateman ED, Dahl R, . Tiotropium respimat add-on therapy reduces airflow obstruction in patients with symptomatic moderate asthma, independent of T_H_2 inflammatory status. J Allergy Clin Immun. 2014 Feb;133(2);Suppl:AB5. DOI: http://dx.doi.org/10.1016/j.jaci.2013.12.040.
133 Kerstjens H, Bleecker E, Meltzer E, . Tiotropium as add-on to inhaled corticosteroids significantly improves asthma control as reflected by the ACQ responder rate. Respirology. 2014; 19;Suppl 2:78.
134 Kerstjens H, Bleecker E, Meltzer E, . Tiotropium as add-on therapy to inhaled corticosteroids for patients with symptomatic asthma: lung function and safety. Respirology. 2014;19 Suppl 2:78.
135 Kerstjens HAM, Bleecker E, Meltzer E, . Tiotropium as add-on to inhaled corticosteroids significantly improves asthma control as reflected by the ACQ responder rate. Eur Respir J. 2013;42;Suppl 57:P4130.
136 Kerstjens HAM, Bleecker E, Meltzer E, . Tiotropium as add-on to inhaled corticosteroids for patients with symptomatic asthma: lung function and safety. Eur Respir J. 2013;42;Suppl 57:P4629.
137 Yang WH, Casale T, Bateman ED, . Tiotropium respimat add-on therapy reduces airflow obstruction in patients with symptomatic moderate asthma, independent of T_H_2 inflammatory status. Allergy Asthma Clin Immunol. 2014;10;Suppl 2:A52. DOI: 10.1186/1710-1492-10-S2-A52.
138 Ohta K, Ichinose M, Tohda, . Once-daily tiotropium respimat is well tolerated and efficacious over 52 weeks in Japanese patients with symptomatic asthma receiving inhaled corticosteroids (ics) ± long-acting β2-agonist (laba): a randomized, double-blind, placebo-controlled study. Am J Respir Crit Care Med. 2014;189:A1311.
139 Paggiaro P, Engel M, Tudoric N, . Phase III trial of tiotropium as add-on therapy to low-dose inhaled corticosteroids for patients with symptomatic mild persistent asthma: design and planned analyses. Eur Respir J. 2013;42;Suppl 57:P4133.
140 Paggiaro P, Halpin DMG, Buhl R, . Tiotropium respmat add-on to inhaled corticosteroids improve lung function in patients with symptomatic mild asthma: results from a phase III trial. J Allergy Clin Immunol. 2014;133;(2)Suppl:AB4. DOI: http://dx.doi.org/10.1016/j.jaci.2013.12.039.
141 Dahl R, Szefler SJ, Bernstein J, . Safety and tolerability of once-daily tiotropium respimat add-on to at least inhaled corticosteroid maintenance therapy in adolescent patients with moderate or severe symptomatic asthma. Allergy. 2015;70;Suppl 101:34–5.
142 Hamelmann E, Boner A, Bernstein J, . 1-year efficacy and safety study of tiotropium respimat add-on to ICS in adolescent patients with symptomatic asthma. Eur Respir J. 2014;44;Suppl 58:1889.
143 Vandewalker M, Harper T, Moroni-Zentgraf P, . Once-daily tiotropium respimat add-on therapy improves lung function in adolescent patients with moderate symptomatic asthma, independent of T helper 2 inflammatory status. Ann Allergy Asthma Immunol. 2015;115:A54–5.
144 Peters SP, Bleecker ER, Kunselman SJ, . Predictors of response to tiotropium versus salmeterol in asthmatic adults. J Allergy Clin Immunol. 2013 Nov;132(5):1068–1074. PMID: 24084072.24084072
145 Confirmatory trials: Spiriva respimat in adult and adolescent patients with asthma. Ridgefield, CT: Boehringer Ingelheim Pharmecuticals, Inc. 2016 Nov.
146 Rajanandh MG, Nageswari AD, Ilango K. Pulmonary function assessment in mild to moderate persistent asthma patients receiving montelukast, doxofylline, and tiotropium with budesonide: a randomized controlled study. Clin Ther. 2014 Apr 1;36(4):526–33. PMID: 24650447.24650447
147 Rajanandh MG, Nageswari AD, Ilango K. Assessment of montelukast, doxofylline, and tiotropium with budesonide for the treatment of asthma: which is the best among the second-line treatment? A randomized trial. Clin Ther. 2015 Feb 1;37(2):418–26. PMID: 25577543.25577543
148 Wechsler ME, Yawn BP, Fuhlbrigge AL, . Anticholinergic vs long-acting β-agonist in combination with inhaled corticosteroids in black adults with asthma: the BELT randomized clinical trial. JAMA. 2015 Oct 27;314(16):1720–30. PMID: 26505596.26505596
149 Rajanandh MG, Nageswari AD, Ilango K. Assessment of various second-line medications in addition to inhaled corticosteroid in asthma patients: a randomized controlled trial. Clin Exp Pharmacol Physiol. 2014 Jul;41(7):509–13. PMID: 24738981.24738981
150 Kerstjens HA, Engel M, Dahl, . Tiotropium in asthma poorly controlled with standard combination therapy. N Engl J Med. 2012 Sep 27;367(13):1198–207. PMID: 22938706.22938706
151 Wang K, Tian P, Fan Y, . Assessment of second-line treatments for patients with uncontrolled moderate asthma. Int J Clin Exp Med. 2015 Oct 15;8(10):19476–80. PMID: 26770595.26770595
152 Hamelmann E, Bernstein JA, Vandewalker M, . A randomised controlled trial of tiotropium in adolescents with severe symptomatic asthma. Eur Respir J. 2016 Nov 3;pii:ERJ-01100–2016. Epub 2016 Nov 3. PMID: 27811070.27811070
153 Boehringer Ingelheim. Evaluation of tiotropium 5μg/day delivered via the respimat inhaler over 48 weeks in patients with severe persistent asthma (study I). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 30]. https://clinicaltrials.gov/ct2/show/NCT00772538. NLM Identifier: NCT00772538.
154 Boehringer Ingelheim. Evaluation of tiotropium 5μg/day delivered via the respimat inhaler over 48 weeks in patients with severe persistent asthma (study II). In: ClinicalTrials.gov. Bethesda, MD: National Library of Medicine (US); 2000- [cited 2016 Nov 30]. https://clinicaltrials.gov/ct2/show/NCT00776984. NLM Identifier: NCT00776984.
155 Bernstein JA, Kerstjens HAM, Moroni-Zentgraf P, . Once-daily tiotropium is well tolerated as add-on to standard treatment for patients with symptomatic asthma despite receiving inhaled corticosteroids and long-acting β_2_-agonists. Chest. 2013;144(4_MeetingAbstracts):89A. DOI: 10.1378/chest.1701649.
156 Casale TB, Halpin DM, Engel M, . 24-hour efficacy of tiotropium respimat in asthma. J Gen Intern Med. 2015;30;Suppl 2:S83.
157 Corren J, Frew A, Engel M, . Tiotropium as add-on therapy to ICS+LABA in patients with symptomatic severe asthma: spirometric assessment over 24 hours. Chest. 2013;144(4_MeetingAbstracts):91A. DOI: 10.1378/chest.1702134.
158 Corren J, Murphy KR, Bensch G, . Once-daily tiotropium respimat decreases the risk of exacerbations, independent of baseline characteristics, in patients with symptomatic severe asthma without evidence of chronic obstructive pulmonary disease. J Gen Intern Med. 2014;29;Suppl 1:S157–8.
159 Dahl R, Doherty DE, Corren J, . Once-daily tiotropium respimat improves lung function in patietns with severe symptomatic asthma independent of leukotriene modifier use. Thorax. 2014;69;Suppl 2:A178. DOI: 10.1136/thoraxjnl-2014-206260.358.
160 Dahl R, Paggiaro P, Engel M, . Once-daily tiotropium improves lung function and reduces risk of asthma exacerbation/worsening in patients with symptomatic asthma, regardless of allergic status. Allergy. 2013;68;Suppl 97:40.
161 Doherty DE, Tashkin DP, Harrison TW, . Improvements in lung function with tiotropium as add-on controller therapy to ICS+LABA for patients with severe symptomatic asthma. Chest. 2013;144(4_MeetingAbstracts):88A. DOI: 10.1378/chest.1702143.
162 Halpin DM, Bateman ED, Moroni-Zentgraf P, . Tiotropium is effective in patients with severe asthma without evidence of chronic obstructive pulmonary disease. Am J Respir Crit Care Med. 2013;187:A2731.
163 Halpin DMG, Bateman ED, Moroni-Zentgraf P, . Tiotropium is effective in patients with severe asthma without evidence of chronic obstructive pulmonary disease. Thorax. 2013;68;Suppl 3:A152. DOI: 10.1136/thoraxjnl-2013-204457.320.
164 Halpin DMG, Bateman ED, Tashkin DP, . Tiotropium decreases the risk of exacerbations in patients with symptomatic asthma regardless of baseline characteristics including markers of allergic status. Thorax. 2013;68;Suppl 3:A149–50. DOI: 10.1136/thoraxjnl-2013-204457.314.
165 Halpin DMG, Paggiaro P, Bateman ED, . Once-daily tiotropium respimat add-on to at least ICS maintenance therapy reduces exacerbation risk in patients with uncontrolled symptomatic asthma. Thorax. 2014;69;Suppl 2:A189. DOI: 10.1136/thoraxjnl-2014-206260.383.
166 Hayden M, Engel M, Schmidt H, . Efficacy of once-daily tiotropium respimat 5μg from phase III trials in adults with symptomatic asthma. J Am Pharm Assoc. 2015;55(2):e242–3.
167 Hoy H, Engel M, Schmidt H, . Once-daily tiotropium respimat: safety and tolerability results from phase III trials in adults with symptomatic asthma. J Am Pharm Assoc. 2015;55(2):e244.
168 Hozawa S, Kerstjens HAM, Tashkin DP, . Tiotropium decreases the risk of exacerbations in patients with symptomatic asthma regardless of baseline characteristics. Respirology. 2013;18;Suppl 4:175.
169 Kerstjens HAM, Tashkin DP, Engel M, . Tiotropium decreases the risk of exacerbations in patients with symptomatic asthma regardless of baseline characteristics. Am J Respir Crit Care Med. 2013;187(1_MeetingAbstracts):A4217. DOI: 10.1164/ajrccmconference.2013.187.1_MeetingAbstracts.A4217.
170 Murphy K, Berger W, Engel M, . Tiotropium respimat: control in symptomatic asthma. J Gen Intern Med. 2015;30;Suppl 2:S77.
171 Murphy K, Dahl R, Paggiaro P, . Once-daily tiotropium respimat add-on to at least inhaled corticosteroid maintenance therapy reduces airflow obstruction in patients with symptomatic asthma, independent of allergic status. J Am Pharm Assoc. 2015;55(2):e243.
172 Tashkin DP, Moroni-Zentgraf P, Engel M, . Once-daily tiotropium reduces risk of exacerbations and asthma worsening in patients with symptomatic asthma despite treatment with inhaled corticosteroids and long-acting β_2_-agonists. Chest. 2013;144(4_MeetingAbstracts):90A. DOI: 10.1378/chest.1701739.
173 Kerstjens HA, Moroni-Zentgraf P, Tashkin DP, . Tiotropium improves lung function, exacerbation rate, and asthma control, independent of baseline characteristics including age, degree of airway obstruction, and allergic status. Respir Med. 2016 Aug;117:198–206. PMID: 27492532.27492532
174 Boner A, Hamelmann E, Bernstein J, . One-year efficacy and safety study of tiotropium respimat add-on to ICS in adolescent patients with symptomatic asthma. Orally presented at: 24^th^ Annual Congress of the European Respiratory Society. 2014 Sep 8; Munich, Germany.