# Methods

The protocol for this review is registered as PROSPERO 2016:CRD42016047985. We developed an analytic framework a priori to guide the systematic review process (Figure 1). We searched Ovid MEDLINE, Ovid MEDLINE In-Process & Other Nonindexed Citations, EMBASE via www.embase.com, Cochrane Central Register of Controlled Trials and Cochrane Database of Systematic Reviews via OVID using subject headings and natural language terms reflecting asthma and the drugs of interest (Appendix A). We supplemented the bibliographic database searches with backwards citation tracking of relevant publications. We searched cliniclatrials.gov and the World Health Organization International Controlled Trials Registry Platform (ICTRP) for ongoing studies and those completed with reported results. We reviewed scientific information packets. Searches were updated March 23, 2017 while the draft report was under public/peer review.

Figure 1 Analytic framework

ICS = inhaled corticosteroid; KQ = Key Question; LABA = long-acting β_2_-agonist; LAMA = long-acting muscarinic antagonist; vs = versus

This figure depicts the key questions within the context of the PICOTS described in the previous section. In general, the figure illustrates four patient populations of interest and how specific pharmacologic interventions may impact outcomes including lung function measured via spirometry and final health outcomes including all-cause or asthma specific mortality, asthma exacerbations, asthma-related healthcare utilization, asthma control scores, or asthma-specific quality of life. The four populations of interest and corresponding interventions and comparators for those specific populations include: 1) children zero to four years of age with recurrent wheezing and the impact of intermittent inhaled corticosteroids versus daily, scheduled inhaled corticosteroids 2) patients five years of age and older with persistent asthma and the comparison of intermittent inhaled corticosteroids versus daily, scheduled inhaled corticosteroids 3) patients five years of age and older with uncontrolled, persistent asthma and the comparison of intermittent inhaled corticosteroid plus scheduled, daily inhaled corticosteroid plus long-acting beta-agonist versus scheduled, daily inhaled corticosteroid plus long-acting beta-agonist 4) patients 12 years of age and older with uncontrolled, persistent asthma and the impact of long-acting muscarinic antagonist plus inhaled corticosteroid versus long-acting beta-agonist plus inhaled corticosteroid or the comparison of long-acting muscarinic antagonist plus inhaled corticosteroid plus long-acting beta-agonist versus long-acting beta-agonist plus inhaled corticosteroid.

We screened titles and abstracts using two independent investigators to determine if the citation met inclusion/exclusion criteria (Table 3). Citations that both reviewers agreed met inclusion criteria were reviewed at the full text level for inclusion into the review. Disagreements were resolved through consensus in consultation with a third reviewer. Corresponding authors were contacted for clarification when needed to assess the inclusion criteria. All authors were given a minimum of 2 weeks to acknowledge queries. Abstracts and meeting presentations were matched to their corresponding full text publication and reviewed for supplemental data.

Table 3 Inclusion and exclusion criteria

Category | Inclusion criteria | Exclusion criteria
Population | KQ1a: Patients 0 to 4y old^a^ with recurrent wheezing KQ1b–c: Patients ≥5y old^a^ with persistent asthma KQ2a–c: Patients ≥12y old^a^ with uncontrolled, persistent asthma | KQ1a: Patients ≥5y old KQ1b–c: Patients ≤4y old; Patients with intermittent asthma KQ2a–c: Patients ≤11y old; Patients with controlled, persistent asthma or with intermittent asthma
Intervention | KQ1a–b: Intermittent dosing of an ICS KQ1c: ICS and LABA used as both controller and quick relief therapy KQ2a–b: ICS and LAMA controller therapy KQ2c: ICS and LABA and LAMA controller therapy | KQ1c: ICS and LABA used as controller therapy but not quick relief therapy All KQs: All other interventions outside of pharmacologic therapies listed in PICOTS; Combinations of interventions other than those listed in the PICOTS
Comparator | KQ1a: No treatment OR pharmacologic therapy OR nonpharmacologic therapy (see PICOTS) KQ1b: ICS controller therapy KQ1c: ICS and LABA controller therapy KQ2a: ICS controller therapy, with or without placebo, where the ICS dose is the same or higher than in the intervention arm KQ2b: ICS and another controller therapy as defined in PICOTS KQ2c: ICS and LABA controller therapy | KQ1c: ICS and LABA used as both controller and quick relief therapy All KQs: All other comparators outside of those specified in PICOTS; Combinations of comparators other than those listed in the PICOTS
Outcomes | All KQ: Asthma exacerbations (systemic corticosteroid, hospitalization, ER visit, ICS or intubation or as defined by the study) or asthma-related hospitalizations, ER visits, urgent care and outpatient visits; death (all-cause and asthma-specific); spirometry (FEV1, FVC and FEV1/FVC); asthma symptom control composite measures (ACT, ACQ); asthma-specific quality of life (AQLQ, PAQLQ, PACQLQ); health care utilization (additional asthma medication use, resource use) | Studies that do not include at least one of the outcomes listed in the PICOTS
Timing, Setting | All settings, study durations and follow-up lengths will be included | None
Study design | Randomized-controlled trials, cross-over trials,^b^ prospective or retrospective observational cohort studies, case-controlled studies | Case series, case reports, nonsystematic reviews, systematic reviews with or without meta-analysis^c^
Publication language and dates | No restriction in publication language or date of publication | Publications in a non-English language without an English language abstract^d^

ACT = asthma control test; ACQ = Asthma Control Questionnaire; AQLQ = Asthma Quality of Life Questionnaire; ER = emergency room; FDA = Food and Drug Administration; FEV1 = forced expiratory volume over 1 second; FVC = forced vital capacity; ICS = inhaled corticosteroids; KQ = Key Question; LABA = long-acting β_2_-agonist; LAMA = long-acting muscarinic antagonist; PACQLQ = Pediatric Asthma Caregiver’s Quality of Life Questionnaire; PAQLQ = Pediatric Asthma Quality of Life Questionnaire; PICOTS = population, intervention, comparator, outcomes

a Studies with age inclusion criteria close to the a prior defined age cut-offs for the given KQ were included in the review if the mean age of the population was within the a priori defined age cut-offs.

b Crossover trials were included if the outcomes data can be abstracted after the first period. If data cannot be abstracted after the first period, the trial will be included based on the following criteria, to minimize carry-over effects: for ICS-if the washout period is at least 6 weeks,^30^ for LABA or LAMA- if the washout period is at least 4 weeks^31^

c Systematic reviews w/meta-analysis were flagged for backwards citation tracking but will not be included in this review.

d English language abstracts of non-English language articles were reviewed at the abstract stage and translated when needed to determine eligibility of the full text^32^

Data were extracted into standardized collection forms, evidence and outcomes tables by one investigator and verified by a second investigator. Data for crossover trials were extracted from treatment period 1 when available, otherwise authors were contacted for period 1 outcomes. Risk of bias was assessed by two independent reviewers using the Cochrane Collaboration’s Risk of Bias Tool^18^ for randomized controlled trials (RCTs) and Newcastle Ottawa Scale^19^ for observational studies. Overall risk of bias for each study was classified as low, moderate or high, according to the collective risk of bias per evaluated domain and the investigator’s confidence in the study results given the identified limitations.^20^ Risk of bias was considered unclear if the majority of domains evaluated were unclear.

We assessed clinical and methodologic heterogeneity to determine appropriateness of meta-analysis. We based data synthesis on pharmacologic class (e.g., long-acting muscarinic antagonists [LAMA], long-acting β_2_-agonists [LABA], inhaled corticosteroids [ICS]). When a trial included more than one intervention arm for the same drug but with different doses (e.g., tiotropium 2.5μg and 5μg) we combined the arms into a single intervention group using recommended formulae.^21^ Synthesis was also based on age categories consistent with the Expert Panel Report-3 of 0 to 4y old, 5 to 11y old and 12y of age and older. When there were 3 or more trials of similar pharmacologic comparisons and outcomes, we pooled data using a Hartung-Knapp^22,23^ method random effects model using the ‘meta’ package in R version 3.1.3 (The R Project for Statistical Computing). Relative risks (RR) with corresponding 95 percent confidence intervals (CI) were estimated for binary outcomes and mean differences (MD) with corresponding 95 percent CI were estimated for continuous outcomes. Peto’s odds ratio (OR) and 95 percent confidence intervals were estimated for binary outcomes with rare events (<5%) in place of a RR.^24^ We pooled hazard ratios and corresponding 95 percent CI reported by studies for time to first exacerbation and rate ratios for studies reporting number of exacerbations over follow-up. We assessed presence of statistical heterogeneity using the Cochrane p-value (p<0.10 significant) and the degree of heterogeneity using the I^2^ statistic with a value >50 percent considered substantial.^25^ Publication bias was assessed using funnel plot inspection and Egger’s weighted regression test when 10 or more trials were pooled.^21,26^ A priori determined subgroups of interest included asthma severity, asthma control, age, ICS dose, onset of asthma, obesity, atopy, smoking history, race, pulmonary function, LAMA dose/delivery device, the determinant of ICS use with intermittent ICS dosing and concomitant asthma medications. Subgroup analysis was performed when 3 or more trials per subgroup were available for a given outcome. Studies that fit into more than one predefined age category were not included in the main analysis, unless they were the only source of data, but were added to the age category consistent with the reported mean or median age of the study as a sensitivity analysis. If a study fit into more than one age category but reported results separately for the different age subgroups, those subgroups were considered for the main analyses. Included studies that were not amenable to pooling were qualitatively summarized. Interpretation of results was made in the context of established thresholds that indicate clinical significance where available (Table 4). Data from the crossover trial by Peters et al.,^27^ were provided by the National Heart, Lung and Blood Institute (NHLBI) Biologic Specimen and Data Repository Information Coordinating Center and independently analyzed by the Evidence-based Practice Center to generate outcomes for period 1 since this data was not reported in the primary manuscript. These results do not necessarily reflect the opinions or views of the BASALT-TALC investigators or the NHLBI.

Table 4 Thresholds for clinical significance

Instrument/outcome | Range (points) | Final score | Threshold
ACT | 5 to 25 | Well controlled: ≥20 Not well controlled: ≤19 | ≥12y: Δ 3 points^a,33^
ACQ5, ACQ6 | 0 to 6 | Uncontrolled: ≥1.5 Well-controlled: <0.75 | ≥18y: Δ 0.5 points^a,34^
ACQ7 | 0 to 6 | Uncontrolled: ≥1.5 Well-controlled: <0.75 | ≥6y: Δ 0.5 points^a,34,35^
AQLQ, AQLQ(S), AQLQ-mini | 1 to 7 | Severe impairment = 1 No impairment = 7 | ≥18y: Δ 0.5 points^a,36–38^
AQLQ12+ | 1 to 7 | Severe impairment = 1 No impairment = 7 | ≥12y: Δ 0.5 points^a,39,40^
PAQLQ, PACQLQ | 1 to 7 | Severe impairment = 1 No impairment = 7 | 7–17y: Δ 0.5 points^a,41,42^
FEV1 | Continuous measure, L | NA | ≥18y: −0.2 L^b,43^
Rescue medication use | Continuous measure, puffs per unit of time | NA | ≥18y: −0.81 puffs/day^b,43^

ACT = asthma control test; ACQ = Asthma Control Questionnaire; AQLQ: Asthma Quality of Life Questionnaire; FEV1 = forced expiratory volume in 1 second; L = liter; PACQLQ = Pediatric Asthma Caregiver’s Quality of Life Questionnaire; PAQLQ = Pediatric Asthma Quality of Life Questionnaire; y = year

a Minimal important difference.

b Average minimal patient perceived improvement

Strength of evidence (SOE) for each outcome within each comparison was evaluated independently by two senior investigators and then discussed to arrive at the final grading using established guidance.^28^ We graded the SOE for asthma exacerbations, mortality, asthma control composite scores, spirometry, asthma-specific quality of life and health care utilization. Five required domains included study risk of bias, consistency, directness, precision and publication bias. Based on these elements we assessed the SOE for each comparison and outcome as:

- High: We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
- Moderate: We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe the findings are likely to be stable, but some doubt remains.
- Low: We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
- Insufficient: We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of the effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

We assessed applicability of studies using the population, intervention, comparator, outcomes, timing, setting (PICOTS) framework.^29^ Characteristics that may influence applicability include but are not limited to age, gender, race, ethnicity, severity and control of asthma and co-interventions.