# Introduction

## Background

Asthma is a chronic inflammatory disorder of the airways, characterized by varying degrees of airflow obstruction. Bronchoconstriction, inflammatory cell infiltration, and airway edema reduce airflow intermittently, often in response to specific exposures, resulting in respiratory symptoms.^1^ In the United States, the prevalence of asthma has increased over the past decade, from an estimated 22.2 million Americans in 2005 to 24.6 million Americans in 2015.^2^ Asthma can significantly impact patients’ and families’ quality of life and ability to pursue activities such as school, work, and exercise. Globally, asthma ranks 14th based on the burden of disease, as measured by disability adjusted life years.^3^ In the US, asthma contributes significantly to health care resource utilization and associated costs. For example, in 2012, asthma was one of the top twenty leading diagnosis groups for primary care visits and was the main reason for 1.8 million emergency department visits and 439,000 hospitalizations. While the severity of disease varies between patients and over time in the same patient, asthma can be fatal, accounting for approximately 1 death per 100,000 Americans.^4^ In 2015, 3,651 Americans died from asthma.^4^

## Rationale

In 1989, the National Heart, Lung and Blood Institute (NHLBI) initiated the National Asthma Education and Prevention Program (NAEPP) to address growing concern about asthma in the US. One of the first accomplishments of the NAEPP was to convene a panel of experts who summarized their recommendations in a document, National Asthma Education and Prevention Program Expert Panel Report (EPR): Guidelines for the Diagnosis and Management of Asthma, in 1991. The guidelines address the diagnosis, evaluation, and treatment of asthma. The most recent report, EPR-3, was published in 2007.^1^ NHLBI assessed the need for an update by requesting information from the public, NAEPP Coordinating Committee Members and its affiliates, and members of the 2007 Expert Panel. Collected information was provided to the NHLBI Advisory Council Asthma Expert Working Group, which produced a report to summarize the process and recommendations from their needs assessment.^5^ The Working Group identified six high priority topics that should be updated. For each topic, Key Questions meriting a systematic literature review were formulated. NHLBI engaged the Agency for Healthcare Research and Quality (AHRQ) to perform the systematic reviews through its Evidence-based Practice Centers (EPC). This report summarizes the systematic review of “Intermittent inhaled corticosteroids and of long-acting muscarinic antagonists for asthma” and highlights areas of controversy and identifies needs for future research on these priority areas.

### Intermittent Inhaled Corticosteroid (ICS) Dosing

ICS are highly effective for improving asthma control and reducing exacerbation frequency, yet adherence is often reported to be less than 49 percent to 73 percent in young children and pre-adolescents and less than 50 percent in adolescents and adults.^6–10^ Published data suggest that an increase in ICS adherence to between 60 percent and 80 percent results in reduced emergency department visits for asthma.^6,7,11,12^ As suggested by the World Health Organization, ‘increasing the effectiveness of adherence interventions may have a far greater impact on the health of the population than any improvement in specific medical treatments’.^13^ Despite known barriers to the clinical management of asthma, like nonadherence, continued investigation to alternate dosing strategies for ICS or in the development of novel adjunctive therapies as discussed below continues.

Scheduled, daily dosing of ICS is the preferred pharmacologic controller therapy for persistent asthma in patients of all ages.^1^ “Controller therapy” will be used in this document to describe medications to be taken daily on a long-term basis to achieve and maintain control of persistent asthma.^1^ “Intermittent” ICS dosing will be used in this document to describe the prescribed use of ICS that is not the same on a daily basis. As prescribed, intermittent ICS dosing may specify variations in the dose, frequency, or duration of administration of ICS. The determinant of ICS use with intermittent ICS dosing may be a patient decision (based on need), an index of worsening asthma or some other predefined criteria. Some examples of intermittent ICS dosing include initiating a temporary course of ICS in a patient not regularly taking ICS controller therapy or temporarily increasing the dose of ICS that is otherwise taken as controller therapy, either strategy in response to a measure of worsening asthma.^1,14,15^ An extension of the use of intermittent ICS therapy is the combined use of ICS plus long-acting β_2_-agonist (LABA) as both a controller and quick relief therapy, particularly when the LABA is considered fast-acting.^16^ “Quick relief” therapy will be used in this document to describe inhaled medication to be used as-needed for acute symptom relief.

EPR-3 suggests that intermittent ICS dosing schedules may be useful in some settings though the evidence at that time was insufficient to support the recommendation beyond experts’ consensus.^1^ Since the EPR-3, it was determined by the NHLBI Needs Assessment Workgroup that a sufficient number of studies have been published on intermittent ICS dosing to warrant a systematic literature review.

### Long-Acting Muscarinic Antagonist (LAMA) Added to ICS or to ICS Plus LABA

LAMAs were not included in the EPR-3 although since then, they have been studied as controller therapy for asthma and at least one LAMA has gained Food and Drug Administration (FDA) approval for the long-term maintenance treatment of asthma in patients 6 years of age and older.^17^ This represents a new pharmacologic class of long-acting bronchodilators for consideration in the stepwise approach to asthma management and the NHLBI Needs Assessment Workgroup determined this topic to be of importance for a potential EPR-3 update.

## Key Questions (KQs)

KQ1a What is the comparative effectiveness of intermittent ICS compared to no treatment, pharmacologic, or nonpharmacologic therapy in children 0 to 4 years old with recurrent wheezing?
KQ1b What is the comparative effectiveness of intermittent ICS compared to ICS controller therapy in patients 5 years of age and older with persistent asthma?
KQ1c What is the comparative effectiveness of ICS with LABA used as both controller and quick relief therapy compared to ICS with or without LABA used as controller therapy in patients 5 years of age and older with persistent asthma?
KQ2a What is the comparative effectiveness of LAMA as add-on to ICS controller therapy compared to placebo or increased ICS dose in patients 12 years of age and older with uncontrolled, persistent asthma?
KQ2b What is the comparative effectiveness of LAMA compared to other controller therapy as add-on to ICS in patients 12 years of age and older with uncontrolled, persistent asthma?
KQ2c What is the comparative effectiveness of LAMA as add-on to ICS plus LABA compared to ICS plus LABA as controller therapy in patients 12 years of age and older with uncontrolled, persistent asthma?

## Population, Intervention, Comparator, Outcomes

Populations: We included all patients that meet the KQ specific criteria regardless of gender, race and ethnicity. Age thresholds per KQ were selected to be consistent with the EPR-3 guidelines.

- KQ1a: Patients 0 to 4 years old with recurrent wheezing
- KQ1b–c: Patients 5 years old and older with persistent asthma
- KQ2a–c: Patients 12 years old and older with uncontrolled, persistent asthma

Interventions: This review focuses on pharmacologic interventions at the class level and includes ICS and inhaled LABA and LAMA, regardless of FDA approval (Table 1).

Table 1 Drugs included in this review

Class | Drugs
ICS | Beclomethasone,^a^ budesonide,^a^ ciclesonide,^a^ flunisolide,^a^ fluticasone,^a^ mometasone,^a^ triamcinolone^b^
LABA | Arformoterol, formoterol,^a^ olodaterol, salmeterol,^a^ vilanterol^a,c^
LAMA | Aclidinium, glycopyrrolate, tiotropium,^a^ umeclidinium

ICS = inhaled corticosteroid; LABA = long-acting β_2_-agonist; LAMA = long-acting muscarinic antagonist

a Currently with FDA approval for asthma, either as a single ingredient product or as a component of a multi-ingredient product.

b Previously FDA approved although discontinued in 2010

c Considered an ultra-long-acting β_2_-agonist

The interventions for each of the KQs is as follows (Table 2):

- KQ1a–b: Intermittent ICS dosing
- KQ1c: ICS and LABA used as controller and quick relief therapy
- KQ2a–b: ICS and LAMA as controller therapy
- KQ2c: ICS and LABA and LAMA as controller therapy

Table 2 Intervention and comparator per Key Question

| Comparator: No treatment, pharmacologic or nonpharmacologic therapy^a^ | Comparator: ICS controller therapy | Comparator: ICS and LABA controller therapy | Comparator: ICS and other controller therapy^b^
Intervention: Intermittent ICS | KQ 1a | KQ 1a, 1b | --- | ---
Intervention: ICS and LABA used as controller and quick relief therapy | --- | KQ 1c | KQ 1c | ---
Intervention: ICS and LAMA controller therapy | --- | KQ 2a ^ c ^ | KQ 2b | KQ 2b
Intervention: ICS and LAMA and LABA controller therapy | --- | --- | KQ 2c | ---

Note: The first column represents interventions and the first row represents comparators of interest in this review. The key questions for each intervention are listed below the relevant comparator(s).

ICS = inhaled corticosteroid; KQ = Key Question; LAMA = long-acting muscarinic antagonist; --- = not applicable

a Nonpharmacologic treatment is as per EPR-3 (e.g., avoiding environmental triggers)

b Other controllers include cromolyn, leukotriene modifiers, immunomodulators, methylxanthines, and systemic corticosteroids

c Same or increased ICS dose in the comparator arm relative to intervention dose

Comparators: We are interested in direct comparisons of therapies as described per KQ. Table 2 demonstrates the intervention and comparator for each KQ in a tabular format. The definition of “controller therapy” is provided in the Glossary.

- KQ1a: No treatment (placebo or control) OR pharmacologic therapy which includes controller therapy or as-needed short-acting β_2_-agonist (SABA) OR nonpharmacologic therapy. Controller therapies include ICS, inhaled LABA, leukotriene modifiers, cromolyn, methylxanthines, immunomodulators, and systemic corticosteroids. Nonpharmacologic treatment is as per EPR-3 (e.g., avoiding environmental triggers).
- KQ1b: ICS controller therapy
- KQ1c: ICS controller therapy OR ICS and LABA controller therapy
- KQ2a: ICS controller therapy, with or without placebo, where the ICS dose is the same or increased relative to the intervention arm dose
- KQ2b: ICS and another controller therapy, including LABA, leukotriene modifiers, cromolyn, methylxanthines, immunomodulators and systemic corticosteroids
- KQ2c: ICS and LABA controller therapy

Outcomes: We included outcomes that fell into the categories below, using definitions provided by the study.

- Asthma exacerbations
  ○ Requiring systemic (oral and/or parenteral) corticosteroids, requiring hospitalization, requiring emergency room (ER) visit, requiring intensive care unit or intubation, or as defined by the study
  ○ Asthma-related hospitalizations, ER visits, urgent care and outpatient visits
- Death
  ○ All-cause, asthma-specific
- Asthma control
  ○ Composite Measures: Asthma Control Test (ACT), Asthma Control Questionnaire (ACQ), various versions
  ○ Spirometry: forced expiratory volume in 1 second (FEV1) forced vital capacity (FVC), FEV1/FVC
- Asthma-specific quality of life:
  ○ Asthma Quality of Life Questionnaire (AQLQ), Pediatric Asthma Quality of Life Questionnaire (PAQLQ), Pediatric Asthma Caregiver’s Asthma Quality of Life Questionnaire (PACQLQ)
- Health care utilization:
  ○ Additional asthma-medication use/need
  ○ Additional resource use related to intervention (e.g. personnel time, equipment)

Timing/Setting: There were no requirements based on time or setting.