# Asthma control

Asthma control: The degree to which the manifestations of asthma (symptoms, functional impairments, exacerbations) are minimized. Asthma control is determined by assessing the domains of impairment (patient self-reported symptoms, nighttime awakenings, rescue SABA use, interference with normal activities; objective measures of lung function) and risk (exacerbations requiring oral systemic corticosteroids).
Asthma severity: The intrinsic intensity of the disease process. Asthma severity is assessed in a patient who is not currently receiving controller therapy using the domains of impairment (patient self-reported symptoms, nighttime awakenings, rescue SABA use, interference with normal activities; objective measures of lung function) and risk (exacerbations requiring oral systemic corticosteroids) or it is inferred from the least amount of treatment required to maintain control. Asthma severity is classified as “intermittent”, “mild persistent”, “moderate persistent”, or “severe persistent”.
Controlled asthma: Minimal manifestations of asthma symptoms and functional impairments, as determined by assessment of the impairment and risk domains.
Controller therapy: Medications recommended to be taken daily on a long-term basis to achieve and maintain control of persistent asthma. Long-term controller medications include inhaled corticosteroids, inhaled long-acting bronchodilators, leukotriene modifiers, cromolyn, theophylline, immunomodulators, and oral systemic corticosteroids.
Intermittent dosing: The prescribed use of ICS that is not the same on a daily basis. As prescribed, intermittent ICS dosing may specify variations in the dose or frequency of administration of ICS. The determinant of ICS use with intermittent ICS dosing may be a patient decision (based on need), an index of worsening asthma, or some other pre-defined criteria.
Persistent asthma: A classification of asthma severity defined either by the assessment of the impairment (patient self-reported symptoms, nighttime awakenings, rescue SABA use, interference with normal activities; objective measures of lung function) and/or risk (exacerbations requiring oral systemic corticosteroids) domains in a patient not taking controller therapy or use of controller therapy to achieve and maintain asthma control. Persistent asthma is further sub-divided as “mild persistent”, “moderate persistent”, and “severe persistent”.
Quick-relief therapy: Medication to be used as-needed for acute symptom relief.
Uncontrolled asthma: A lack of asthma control, as determined by assessment of the impairment and/or risk domains.