# Key Messages

## Purpose of Review

To assess the efficacy of intermittent inhaled corticosteroids in different populations of patients with asthma and to assess whether adding long-acting muscarinic antagonists improves outcomes for patients with uncontrolled, persistent asthma.

## Key Messages

- In children less than 5 years old with recurrent wheezing, intermittent use of inhaled corticosteroids during an upper respiratory tract infection decreases asthma exacerbations
- In patients 12 years and older with persistent asthma:
  ○ using inhaled corticosteroids intermittently may be as effective as using them as a controller medication
  ○ using inhaled corticosteroids and long-acting beta-agonists together as controller and quick relief therapy reduces asthma exacerbations compared to using inhaled corticosteroids alone or with long-acting beta agonist as a controller
- In patients 12 years and older with uncontrolled, persistent asthma, adding long-acting muscarinic antagonist to:
  ○ inhaled corticosteroids reduces exacerbations and improves lung function
  ○ inhaled corticosteroids and long-acting beta-agonist controllers improves asthma control and lung function