# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- William Busse, M.D.
  Professor
  Department of Medicine
  School of Medicine and Public Health
  University of Wisconsin
- Fernando Martinez, M.D.
  Regent’s Professor
  Director, Asthma and Airways Disease Research Center
  Swift-McNear Professor of Pediatrics
  College of Medicine, Tucson
  The University of Arizona Health Sciences
  Tucson, AZ
- Natalie Napolitano, M.P.H., RRT-NPS, FAARC
  Research Clinical Specialist
  Respiratory Therapy Department
  The Children’s Hospital of Philadelphia
  Philadelphia, PA