# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Robyn Cohen, M.D., M.P.H.
  Assistant Professor of Pediatrics
  Boston University School of Medicine
  Boston, MA
- Nicola Hanania, M.B.B.S.
  Associate Professor of Medicine-Pulmonary
  Baylor College of Medicine
  Houston, TX
- H. William Kelly, Pharm.D.^*^
  Professor Emeritus of Pediatrics and Pharmacy
  University of New Mexico Health Sciences Center
  Albuquerque, NM
- Wendy C. Moore, M.D.
  Associate Professor of Pulmonary, Critical Care and Allergy and Immunologic Medicine
  Wake Forest University School of Medicine
  Winston-Salem, NC
- Michael Schatz, M.D., M.S.^*^
  Kaiser Permanente Medical Care Program
  San Diego, CA
- Stanley Szefler, M.D.^*^
  Director
  Pediatric Asthma Research Program at Children’s Hospital Colorado
  Aurora, CO

* Provided input on Draft Report