# Addendum

An updated search was conducted for studies to address Key Questions (KQs) 1c and 2a–c. These KQs were related to the combined use of inhaled corticosteroids and long-acting beta agonists as controller and quick relief therapy and to the use of long-acting muscarinic antagonists as add-on therapy to inhaled corticosteroids. The original search was conducted in August 2016 using the earliest date for each database. This update was made on November 28, 2017. No new studies met inclusion criteria.