# Acknowledgments

The authors gratefully acknowledge the contribution of the EPC librarian, Sharon Giovenale, for her contribution to the literature search and citation retrieval process. We would like to acknowledge the affiliations of our content experts:

- Stephen C. Lazarus, M.D.
  Professor of Medicine
  Division of Pulmonary & Critical Care Medicine
  University of California, San Francisco
  San Francisco, CA
- Kathryn V. Blake, Pharm.D.
  Director, Center for Pharmacogenomics and Translational Research
  Nemours Children’s Specialty Care
  Jacksonville, FL
- Jason E. Lang, M.D., M.P.H.
  Division of Allergy, Immunology and Pulmonary Medicine
  Duke University School of Medicine
  Duke Children’s Hospital and Health Center