# Discussion

## Overview and Applicability

We conducted a systematic review with meta-analysis to assess the comparative effectiveness of pharmacologic management of asthma, specifically intermittent inhaled corticosteroid (ICS) dosing (with or without long-acting beta agonist (LABA)) and long-acting muscarinic antagonists (LAMA) in comparison to guideline recommended approaches to the treatment of persistent asthma, or recurrent wheezing in the case of patients 4 years (y) old or younger. A total of 54 randomized controlled trials (RCTs) and 2 observational studies comprised the evidence base of this review.

### Key Question 1a

In this report, intermittent ICS was defined as the prescribed use of ICS that is not the same on a daily basis. We found several types of intermittent dosing within the evidence base. In patients 0 to 4y old (Key Question [KQ]1a) with recurrent wheezing, intermittent ICS was generally defined as an episode of ICS daily dosing initiated with onset of a respiratory tract infection (RTI) and continued for a defined period, generally 7 to 10 days. Otherwise, the patient was not taking ICS. Data from three trials of 324 patients found this practice, when used with as-needed short-acting β_2_-agonist (SABA), reduces the risk of exacerbation requiring oral corticosteroid (moderate strength of evidence [SOE]) in comparison to as-needed SABA. However a difference in exacerbation risk was not detected between intermittent ICS use during RTI compared to ICS controller with as-needed SABA (low SOE), based on a single trial of 278 patients. Thus the strength of evidence was low for the current conclusion. Caregiver quality of life improved (low SOE) versus as-needed SABA although not reaching a minimally important difference and the tool applied has not been validated in this age. Overall, for this KQ the evidence base was limited by the number of trials per comparison and inability to evaluate consistency since several outcomes were based on a single trial, and as such domains of consistency and precision were most impacted for strength of evidence ratings. Evidence was insufficient to draw conclusions for the comparison of intermittent ICS versus no therapy and we found no evidence comparing intermittent ICS to nonpharmacologic therapy.

### Key Question 1b

In patients 5y of age or older, intermittent ICS dosing was described in the evidence base in two ways (KQ1b). The first strategy was in patients regularly taking ICS controller therapy who would increase ICS dose temporarily in response to a specific trigger, most often doubling routine ICS dose upon deterioration of peak expiratory flow consistent with the “yellow zone”. However, some studies allowed quadrupling of dose and due to limited studies in this analysis overall, we were unable to discern if a given strategy for providing intermittent ICS (i.e., doubling vs. quadrupling) resulted in differing effects. We found patients resembled a mixture of persistent asthma severity and levels of control as described by the studies. Evidence was limited to exacerbations, of which we found no difference in effect between intermittent ICS and ICS controller in patients 12 years of age and older. The largest analysis was for exacerbations leading to oral corticosteroid use which included three trials with 908 patients. However, the other analyses were mostly limited to a single study and thus imprecision and either inconsistency or lack of the ability to evaluate consistency led to low strength of evidence for all outcomes with this intermittent ICS strategy. The age of patients included in this evidence base reflects middle-aged adults with mean ages in the 30’s to 50’s. Although data was reported in a single trial for younger patients, evidence was insufficient to draw conclusions in patients 5 to 11y old.

The second strategy of intermittent ICS dosing described by the evidence base was in patients not otherwise on ICS therapy who would temporarily use ICS in comparison to ICS controller therapy. Most studies asked patients to use the ICS study inhaler when they would normally require as-needed SABA, in conjunction with a SABA inhaler. The majority of the population had mild persistent asthma, some of which were required to be at least partially controlled while others were symptomatic at baseline. In the group of studies included in that analysis of 12 years of age and older, the population reflected more of an adult population with the mean age being in the 30’s. We did not detect a difference between intermittent ICS and ICS controller in patients 12 years of age and older on exacerbations, asthma control scores, spirometry, quality of life, rescue inhaler use or asthma-related urgent care visits. However, like the other dosing strategy described for KQ1b, the evidence base for this dosing strategy was scarce as well with most outcomes based on a single trial. Thus, strength of evidence was primarily low due to issues of precision and consistency. Evidence is insufficient to draw conclusions in patients 5 to 11y old.

### Key Question 1c

Analysis of ICS and long-acting β_2_-agonist (LABA) as both controller and quick relief therapy (KQ1c) in patients with persistent asthma was separated based on the comparator being either ICS or ICS and LABA and also in consideration of the comparative daily ICS dose in the intervention and comparator arms, using thresholds set by the Expert Panel Report-3. All but one trial evaluated a single ICS and LABA combination in the intervention arm (budesonide/formoterol) and the majority of control arms were of the same ICS and LABA combination. In the group of studies considered in the evidence base of 12 years of age and older, the age of patients was again more middle-aged with mean ages ranging from the 30’s to 50’s. The evidence comparing ICS and LABA controller and quick relief therapy to ICS controller was small relative to other groups in this KQ and primarily based on composite outcomes of asthma exacerbations with little to no evidence for asthma control, spirometry, quality of life, or health care utilization. Patients represented a mix of asthma severity (mild to severe) and were mostly symptomatic at baseline. Based on composite exacerbation outcomes, ICS and LABA controller and quick relief versus ICS controller at the same or higher comparative ICS dose reduced exacerbation risk, both in patients 12 years of age and older and in patients 4 to 11y old. Strength of evidence was low or moderate due to imprecision and unknown consistency in the event of single trial. Data for patients 4 to 11y was also downgraded for indirectness given the dosing used in the study was lower than approved doses and what would be considered “low dose” according to the EPR-3.

ICS and LABA controller and quick relief versus ICS and LABA controller at the same comparative ICS dose had the largest literature base in this report and most evidence was focused on asthma exacerbations and forced expiratory volume in 1 second (FEV1). Most patients were described as either symptomatic or not controlled, and not further described in terms of persistent asthma severity. In patients 12 years of age and older, not only was the risk of the composite exacerbation requiring systemic corticosteroids, hospitalization or emergency room (ER) visit reduced with ICS and LABA controller and quick relief therapy (high SOE), so were the individual components of the composite outcome (moderate or high SOE). There was no difference in FEV1 (low SOE) and 3 or fewer trials reported data for other outcomes including asthma control composite scores, spirometry (FEV1 % predicted and forced vital capacity [FVC]), and health care utilization. Thus SOE for these outcomes was low to moderate, mostly suggesting no difference in effect between comparison with exception of asthma control questionnaire (ACQ)-5 responder (moderate SOE) and rescue medication use (low SOE) which both favored ICS and LABA controller and quick relief therapy. Evidence in patients 4 to 11y old was limited to a single subgroup analysis of a larger trial and suggested benefit in reducing composite exacerbation outcomes with ICS and LABA controller and quick relief therapy (low SOE). However, these outcomes were downgraded for indirectness given the dosing used in the study was lower than approved doses and what would be considered “low dose” according to the EPR-3.

ICS and LABA controller and quick relief versus ICS and LABA controller at a higher comparative ICS dose reduces the risk of composite exacerbations (high SOE) in patients 12 years of age and older. This population was primarily either symptomatic or a mixture of patients with and without symptoms at baseline, without further specification of persistent asthma severity. No difference was found for death (moderate SOE), ACQ-5 score (high SOE), FEV1 (moderate SOE), Asthma Quality of Life Questionnaire (AQLQ)-(S) score (moderate SOE), or rescue medication use (high SOE). No evidence was found for patients 5 to 11y old. Finally ICS and LABA controller and quick relief therapy, when compared to physician adjusted asthma therapy reflecting standard of care controller options (at a minimum daily ICS), ICS and LABA controller and quick relief therapy reduces risk of composite exacerbation (moderate SOE) but not the risk of the individual components (low SOE). Patients in the ICS and LABA controller and quick relief group had a greater chance of achieving a minimally important difference in ACQ-5 score (moderate SOE) and used fewer rescue medication inhalations (moderate SOE) while no difference was found in FEV1 (low SOE), or FEV1 percent predicted (low SOE). SOE was reduced in this evidence base due to effect estimates that were imprecise and inconsistent, in addition to evidence with risk of bias given the open-label design being subject to performance and detection bias.

### Key Question 2

The role of LAMA therapy in asthma management was addressed in KQ2a–c and specific to a population 12 years of age and older with uncontrolled, persistent asthma. Although the age requirement of included studies could have been as young as 12y old, almost all data were derived from trials requiring participants to be at least 18 years old. The mean ages ranged from the 30’s to 50’s. Most studies defined “uncontrolled” with use of the ACQ, requiring a score of 1.5 or greater for inclusion. Almost the entire evidence base reflects a single LAMA (tiotropium) delivered via a soft mist inhaler as opposed to dry powder inhaler. Many of the trials for KQ2a and KQ2b overlapped as they were three arm trials. We found LAMA to be more effective than placebo as add-on to ICS, supported by the reduction in risk of exacerbation requiring systemic corticosteroids (high SOE) and the peak, trough and area under the curve (AUC) of both FEV1 and FVC (all high SOE). No difference was found for asthma control composite scores, quality of life, or rescue medication use. Add-on LAMA to ICS versus doubling ICS dose did not significantly differ in effect on outcomes of exacerbation, asthma control scores, FEV1 trough, or AQLQ, all with low SOE. LAMA compared to LABA, as add-on to ICS, was no different in any evaluated outcomes including exacerbations, death, asthma control scores, spirometry, quality of life, or rescue medication use. SOE was high for more outcomes than not, and limitations downgrading SOE to low or moderate were due to precision and consistency. Few studies, limited to outcomes of FEV1 and rescue medication use, evaluated other controllers than LABA as a comparator to add-on LAMA. FEV1 and rescue medication use was improved with either montelukast or doxyfylline versus LAMA although SOE was low due to risk of bias and consistency. LAMA added to ICS and LABA in comparison to ICS and LABA did not result in a significant difference on effect of exacerbation risk although most measures of lung function, particularly FEV1 AUC and peak trough and AUC of FVC, were improved. The chance of a patient achieving a minimally important difference in ACQ-7 and AQLQ scores was also increased with LAMA added to ICS and LABA.

## Limitations

This review sought to evaluate different ICS dosing strategies and LAMA therapy in persistent asthmatics of various ages, depending on the KQ. Comparisons were class-based and thus this review does not inform the impact of specific doses on outcomes, rather more globally addresses classes and broad dosing strategies (i.e. intermittent dosing of ICS). Although effectiveness is an important part of decision-making, this report did not include harms associated with drug therapies, which should also be taking in to consideration. The majority of patients included in trials, when race was reported, were Caucasian and thus application of data to other races is limited. KQ1 included young pediatric populations, and evidence overall was sparse in those under 5 years old making it difficult to draw conclusions, if at all. Even within the age category of 12 years of age and older, regardless of KQ, data centered around mean ages of 30 to 50y thus extremes of age are underrepresented in the evidence base. Lastly, review of LAMA in patients under 12 years of age was outside of the scope of this review although clinicians should recognize recent approval of tiotropium in the pediatric population as young as 6 years of age. Inclusion criteria of studies rarely provided enough information to determine persistent asthma severity thus we relied on study reported severity, which in the majority of trials was not present. In addition, control of asthma was infrequently reported. In the ICS evidence base, it was more common to find trials describing presence of symptoms during run-in than a clearer measure of asthma control. In the LAMA evidence base, we only included trials evaluating a population with uncontrolled asthma, which most often was defined using the ACQ score. However, this is only one of many criteria of impairment or risk that can be applied to determine asthma control.

Overall, most studies in this review were of low risk of bias. However, particularly in KQ1c, studies were found to have increased risk of bias do to their open-label design and risk of performance and detection bias.

Although we sought to evaluate any LAMA in KQ2a–c, regardless of Food and Drug Administration approval status, the evidence base is driven almost exclusively by tiotropium, administered as a soft mist inhaler. In addition, the evidence base comparing LAMA to other controllers, as add-on to ICS, was limited in number and size of trials and also to very few outcomes, making it challenging to draw conclusions comparing LAMA to other controllers outside of LABA when added to ICS.

Many studies reported exacerbations requiring systemic corticosteroids; however, other exacerbation types, such as those requiring ER visits or hospitalizations, which are important health outcomes, were far less frequently reported. In addition, the evidence base for some KQ relied on composite outcomes that grouped components that likely vary in importance, making results difficult to interpret. Outside of exacerbations and spirometry, measures of asthma control composite scores, quality of life and health care utilization other than rescue inhaler use were infrequently reported.

Little data exists regarding subgroups that are of interest in this field, not limited to but including asthma severity and control. Although we sought to collect and analyze such data when possible, we were only able to perform a subgroup analysis for the dose of tiotropium in in LAMA-related KQs. Additional data reported relevant to subgroups of interest came from analyses of original trials included in this review.

## Future Research Needs

Additional research would be valuable in the area of intermittent ICS dosing, particularly that which was evaluated in KQ1a and 1b where currently the evidence base is limited in size, not only overall but also per comparator/outcome evaluated. In addition, there seems to be a relatively lower amount of published evidence related to intermittent ICS dosing in comparison to other KQ addressed in this report such as the use of ICS and LABA as quick relief and controller therapy or the role of LAMA therapy in asthma. This may unfortunately lead to mis-interpretation of evidence suggesting lack of benefit to intermittent therapy when in fact there is a limited data set currently from which to draw conclusions. Given most outcomes were rated with low strength of evidence, future research could change the direction or magnitude of effect or the strength of evidence the consistency and precision in effect estimates improve. For KQ1b, there appears to be several trials evaluating yellow-zone triggered ICS therapy, although evidence of other “intermittent ICS” strategies is limited and may offer different effects. We are aware of at least two ongoing trials (NCT 02066129 and NCT 02298205) registered with www.clinicaltrials.gov that will provide some additional evidence to these research questions in the future.

Since there are several LAMAs other than tiotropium on the US market, it would be valuable to understand their efficacy in asthma management. We are aware of several ongoing clinical trials (NCT 02676089, NCT 02676076, NCT 02433834, NCT 02382510) related to other LAMAs (e.g. glycopyrronium and investigational LAMAs such as TRN-157) in asthma management which may provide future evidence in this area. The same holds true for other combinations of ICS/LABA. Future studies comparing LAMA to controllers other than LABAs would also be of value since currently the evidence base is largest for comparing LAMA to LABA.

Future studies would benefit from consistently defining the severity and control of asthma in the recruited population. There are many potential reasons a patient may be considered to have asthma that is not controlled and this may provide insight into preference for a particular treatment. Future studies should focus on these various causes of having “uncontrolled” asthma as part of investigation for alternative treatments. Knowing more about the severity and control of enrolled participants would also enhance applicability of evidence. Future trials should also consider other subgroups of interest, including racial and ethnic subgroups, and routinely report such results numerically to help decision makers make more individualized treatment decisions. Future studies would also benefit from analyzing and reporting individual components of exacerbation composite outcomes so that various end users can make decisions based on which outcome is most important to them. In addition, studies would benefit from more routine use of validated tools for quality of life and asthma control measurement in addition to incorporation of health resource utilization outcomes so the impact of therapy outside of exacerbation risk can be more thoroughly evaluated.

## Conclusions

Compared to rescue SABA use, adding intermittent ICS use appears to benefit children less than 5 years old with recurrent wheezing in the setting of an RTI. In patients 12 years of age and older with persistent asthma, differences in intermittent ICS versus controller use of ICS were not detected, although few studies provided evidence for this KQ leading to primarily low strength of evidence ratings. Using ICS and LABA as both a controller and quick relief therapy showed benefits over use as a controller medication alone (ICS or ICS and LABA controller). In patients 12 years of age and older with uncontrolled, persistent asthma, adding LAMA to ICS controller or adding LAMA to ICS plus LABA controller compared to ICS or ICS plus LABA alone improves some outcomes. However, adding LAMA to ICS controller compared to adding LABA to ICS controller produced no difference in outcomes.