# Appendix F Forest Plots

Figure F-1 Asthma-related acute care visit: intermittent ICS with as-needed SABA vs. as-needed SABA

This figure depicts the meta-analysis of the impact of intermittent inhaled corticosteroid with as needed short-acting beta agonists versus as needed short-acting beta agonists on asthma related acute care visits in patients with asthma. Three trials were included in this analysis. The first trial by Svedmyr and colleagues in 1999 provided a risk ratio of 0.83 with a 95 percent confidence interval of 0.44 to 1.58. The second trial by Bacharier and colleagues in 2008 provided a risk ratio of 0.98 with a 95 percent confidence interval of 0.71 to 1.34. The third trial by Ducharme and colleagues in 2009 provided a risk ratio of 0.88 with a 95 percent confidence interval of 0.72 to 1.07. The combined effect of these three trials showed a risk ratio of 0.90 with a 95 percent confidence interval of 0.77 to 1.05. The I-squared value was 0 percent with a p-value of 0.83.

Figure F-2 Hospital admissions due to asthma: intermittent ICS with as-needed SABA vs. as-needed SABA

This figure depicts the meta-analysis of the impact of intermittent inhaled corticosteroid with as needed short-acting beta agonists versus as needed short-acting beta agonists on hospital admission due to asthma in patients with asthma. Three trials were included in this analysis. The first trial by Svedmyr and colleagues in 1999 provided a risk ratio of 2.50 with a 95 percent confidence interval of 0.53 to 11.74. The second trial by Bacharier and colleagues in 2008 provided a risk ratio of 0.24 with a 95 percent confidence interval of 0.05 to 1.29. The third trial by Ducharme and colleagues in 2009 provided a risk ratio of 0.72 with a 95 percent confidence interval of 0.35 to 1.48. The combined effect of these three trials showed a risk ratio of 0.77 with a 95 percent confidence interval of 0.06 to 9.68. The I-squared value was 51 percent with a p-value of 0.13.

Figure F-3 All-cause death: ICS and LABA controller and quick reliever vs. ICS and LABA controller (same dose)

This figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at the same dose on all-cause death in patients with asthma. Four trials were included in this analysis. The first trial by Vogelmeier and colleagues in 2005 provided an odds ratio of 0.14 with a 95 percent confidence interval of 0.01 to 2.18. The second trial by Rabe and colleagues in 2006 provided an odds ratio of 0.53 with a 95 percent confidence interval of 0.05 to 5.08. The third trial by Atienza and colleagues in 2013 provided an odds ratio of 0.99 with a 95 percent confidence interval of 0.06 to 15.89. The fourth trial by Patel and colleagues in 2013 did not report any outcomes in either group and was not factored into the pooled estimate. The combined effect of these four trials showed an odds ratio of 0.43 with a 95 percent confidence interval of 0.04 to 4.49. The I-squared value was 0 percent with a p-value of 0.59.

Figure F-4 Change in ACQ-5 mean score from baseline: ICS and LABA controller and quick reliever vs. ICS and LABA controller (same dose)

This figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at the same dose on change in Asthma Control Questionnaire 5 mean score from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Rabe and colleagues in 2006 provided a mean difference of −0.15 with a 95 percent confidence interval of −0.21 to −0.09. The second trial by Atienza and colleagues in 2013 provided a mean difference of −0.12 with a 95 percent confidence interval of −0.18 to −0.07. The third trial by Hozawa and colleagues in 2014 provided a mean difference of −0.37 with a 95 percent confidence interval of −0.58 to −0.16. The combined effect of these three trials showed a mean difference of −0.16 with a 95 percent confidence interval of −0.39 to 0.06. The I-squared value was 60 percent with a p-value of 0.08.

Figure F-5 Change in on-treatment FEV1 from baseline: ICS and LABA controller and quick reliever vs. ICS and LABA controller (same dose)

This figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at the same dose on change in on-treatment forced expiratory value in one second from baseline in patients with asthma. Five trials were included in this analysis. The first trial by Rabe and colleagues in 2006 provided a mean difference of 0.08 with a 95 percent confidence interval of 0.06 to 0.10. The second trial by Atienza and colleagues in 2013 provided a mean difference of 0.04 with a 95 percent confidence interval of 0.02 to 0.06. The third trial by Papi and colleagues in 2013 provided a mean difference of 0.00 with a 95 percent confidence interval of −0.04 to 0.04. The fourth trial by Patel and colleagues in 2013 provided a mean difference of 0.15 with a 95 percent confidence interval of −0.06 to 0.36. The fifth trial by Takeyama and colleagues in 2014 provided a mean difference of 0.04 with a 95 percent confidence interval of 0.02 to 0.06. The combined effect of these five trials showed a mean difference of 0.04 with a 95 percent confidence interval of 0.00 to 0.09. The I-squared value was 70 percent with a p-value of 0.01.

Figure F-6 Change in rescue medication use from baseline, mean inhalations per day: ICS and LABA controller and quick reliever vs. ICS and LABA controller (same dose)

This figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at the same dose on change in rescue medication use from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Rabe and colleagues in 2006 provided a mean difference of −0.20 with a 95 percent confidence interval of −0.28 to −0.12. The second trial by Atienza and colleagues in 2013 provided a mean difference of −0.25 with a 95 percent confidence interval of −0.35 to −0.15. The third trial by Papi and colleagues in 2013 provided a mean difference of −0.02 with a 95 percent confidence interval of −0.13 to 0.09. The combined effect of these three trials showed a mean difference of −0.16 with a 95 percent confidence interval of −0.45 to 0.14. The I-squared value was 78 percent with a p-value of 0.01.

Figure F-7 All-cause death: ICS and LABA controller and quick reliever vs. ICS and LABA controller (higher dose)

This figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus controller therapy at a higher dose on all cause death in patients with asthma. Four trial arms were included in this analysis. The first trial arm by Bousquet and colleagues in 2007 provided an odds ratio of 7.39 with a 95 percent confidence interval of 0.15 to 372.38. The second trial arm by Kuna and colleagues in 2007 is the first of two trial arms reported in that publication and provided an odds ratio of 7.39 with a 95 percent confidence interval of 0.15 to 372.38. The third trial arm by Kuna and colleagues in 2007 is the second of two comparator trial arms reported in that publication and provided an odds ratio of 1.00 with a 95 percent confidence interval of 0.06 to 16.00. The fourth trial arm by Pavord and colleagues in 2009 did not report any outcomes in either group and was not factored into the pooled estimate. The combined effect of these four trial arms showed an odds ratio of 2.72 with a 95 percent confidence interval of 0.38 to 19.31. The I-squared value was 0 percent with a p-value of 0.61.

Figure F-8 All-cause death: ICS and LABA controller and quick reliever vs. CBP

This figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus conventional best practice on all-cause death in patients with asthma. Four trials were included in this analysis. The first trial by Sears and colleagues in 2008 provided an odds ratio of 0.51 with a 95 percent confidence interval of 0.05 to 4.90. The second trial by Louis and colleagues in 2009 provided an odds ratio of 7.54 with a 95 percent confidence interval of 0.47 to 120.72. The third trial by Quirce and colleagues in 2011 did not report any outcomes in either group and was not factored into the pooled estimate. The fourth trial by Soes-Peterson and colleagues in 2011 provided an odds ratio of 7.33 with a 95 percent confidence interval of 0.15 to 369.58. The combined effect of these four trials showed an odds ratio of 2.20 with a 95 percent confidence interval of 0.32 to 14.96. The I-squared value was 26 percent with a p-value of 0.26.

Figure F-9 Change in ACQ-5 mean score from baseline: ICS and LABA controller and quick reliever vs. CBP

This figure depicts the meta-analysis of the impact of controller plus quick reliever therapy versus conventional best practice on change in mean asthma control questionnaire 5 scores from baseline in patients with asthma. Five trials were included in this analysis. The first trial by Sears and colleagues in 2008 provided a mean difference of −0.02 with a 95 percent confidence interval of −0.10 to 0.06. The second trial by Louis and colleagues in 2009 provided a mean difference of −0.12 with a 95 percent confidence interval of −0.20 to −0.04. The third trial by Quirce and colleagues in 2011 provided a mean difference of −0.12 with a 95 percent confidence interval of −0.23 to −0.01. The fourth trial by Soes-Peterson and colleagues in 2011 provided a mean difference of −0.09 with a 95 percent confidence interval of −0.15 to −0.03. The fifth trial by Riemersma and colleagues in 2012 provided a mean difference of −0.06 with a 95 percent confidence interval of −0.31 to 0.19. The combined effect of these five trials showed a mean difference of −0.09 with a 95 percent confidence interval of −0.14 to −0.03. The I-squared value was 0 percent with a p-value of 0.49.

Figure F-10 Change in ACQ-7 score from baseline: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in Asthma Control Questionairre 7 score from baseline in patients with asthma. Four trials were included in this analysis. The first trial by Paggiaro and colleagues in 2016 provided a mean difference of 0.03 with a 95 percent confidence interval of −0.07 to 0.14. The second trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of −0.21 with a 95 percent confidence interval of −0.30 to −0.12. The third trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of −0.07 with a 95 percent confidence interval of −0.16 to 0.02. The fourth trial by Hamelmann and colleagues in 2016 provided a mean difference of −0.17 with a 95 percent confidence interval of −0.30 to −0.04. The combined effect of these four trials showed a mean difference of −0.10 with a 95 percent confidence interval of −0.28 to 0.07. The I-squared value was 78 percent with a p-value of 0.0035.

Figure F-11 ACQ-7 responder: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the risk of being an Asthma Control Questionairre 7 responder in patients with asthma. Five trials were included in this analysis. The first trial by Ohta and colleagues in 2015 provided a risk ratio of 0.98 with a 95 percent confidence interval of 0.83 to 1.16. The second trial by Paggiaro and colleagues in 2016 provided a risk ratio of 1.00 with a 95 percent confidence interval of 0.86 to 1.18. The third trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a risk ratio of 1.21 with a 95 percent confidence interval of 1.07 to 1.38. The fourth trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a risk ratio of 1.03 with a 95 percent confidence interval of 0.92 to 1.15. The fifth trial by Hamelmann and colleagues in 2016 provided a risk ratio of 1.16 with a 95 percent confidence interval of 1.02 to 1.31. The combined effect of these five trials showed a risk difference of 1.08 with a 95 percent confidence interval of 0.96 to 1.21. The I-squared value was 41.9 percent with a p-value of 0.1418.

Figure F-12 Change in FEV1 peak from baseline: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in peak forced expiratory volume in 1 second from baseline in patients with asthma. Four trials were included in this analysis. The first trial by Paggiaro and colleagues in 2016 provided a mean difference of 0.14 with a 95 percent confidence interval of 0.08 to 0.21. The second trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.22 with a 95 percent confidence interval of 0.17 to 0.27. The third trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.19 with a 95 percent confidence interval of 0.15 to 0.24. The fourth trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.16 with a 95 percent confidence interval of 0.06 to 0.25. The combined effect of these four trials showed a mean difference of 0.18 with a 95 percent confidence interval of 0.13 to 0.24. The I-squared value was 20.7 percent with a p-value of 0.2859.

Figure F-13 Change in FEV1 trough from baseline: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in trough forced expiratory volume in 1 second from baseline in patients with asthma. Seven trials were included in this analysis. The first trial by Bateman and colleagues in 2011 provided a mean difference of 0.15 with a 95 percent confidence interval of 0.07 to 0.23. The second trial by Lee and colleagues in 2015 provided a mean difference of 0.11 with a 95 percent confidence interval of 0.01 to 0.21. The third trial by Ohta and colleagues in 2015 provided a mean difference of 0.06 with a 95 percent confidence interval of −0.02 to 0.15. The fourth trial by Paggiaro and colleagues in 2016 provided a mean difference of 0.12 with a 95 percent confidence interval of 0.05 to 0.18. The fifth trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.17 with a 95 percent confidence interval of 0.11 to 0.22. The sixth trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.16 with a 95 percent confidence interval of 0.10 to 0.21. The seventh trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.10 with a 95 percent confidence interval of 0.00 to 0.20. The combined effect of these seven trials showed a mean difference of 0.13 with a 95 percent confidence interval of 0.10 to 0.27. The I-squared value was 2.6 percent with a p-value of 0.4056.

Figure F-14 Change in FEV1 AUC from baseline: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in forced expiratory volume in 1 second area under the curve from baseline in patients with asthma. Four trials were included in this analysis. The first trial by Paggiaro and colleagues in 2016 provided a mean difference of 0.14 with a 95 percent confidence interval of 0.08 to 0.20. The second trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.21 with a 95 percent confidence interval of 0.16 to 0.26. The third trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.18 with a 95 percent confidence interval of 0.14 to 0.23. The fourth trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.16 with a 95 percent confidence interval of 0.07 to 0.24. The combined effect of these four trials showed a mean difference of 0.18 with a 95 percent confidence interval of 0.13 to 0.23. The I-squared value was 22.6 percent with a p-value of 0.2750.

Figure F-15 Change in FVC peak from baseline: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in peak forced vital capacity from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.14 with a 95 percent confidence interval of 0.09 to 0.19. The second trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.10 with a 95 percent confidence interval of 0.05 to 0.15. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.08 with a 95 percent confidence interval of −0.02 to 0.18. The combined effect of these three trials showed a mean difference of 0.11 with a 95 percent confidence interval of 0.05 to 0.18. The I-squared value was 0 percent with a p-value of 0.4621.

Figure F-16 Change in FVC trough from baseline: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in trough forced vital capacity from baseline in patients with asthma. Five trials were included in this analysis. The first trial by Bateman and colleagues in 2011 provided a mean difference of 0.14 with a 95 percent confidence interval of 0.04 to 0.23. The second trial by Ohta and colleagues in 2015 provided a mean difference of 0.02 with a 95 percent confidence interval of −0.07 to 0.12. The third trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.10 with a 95 percent confidence interval of 0.04 to 0.16. The fourth trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.08 with a 95 percent confidence interval of 0.02 to 0.15. The fifth trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.05 with a 95 percent confidence interval of −0.06 to 0.16. The combined effect of these five trials showed a mean difference of 0.08 with a 95 percent confidence interval of 0.04 to 0.13. The I-squared value was 0 percent with a p-value of 0.5012.

Figure F-17 Change in FVC AUC from baseline: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in forced vital capacity area under the curve from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.13 with a 95 percent confidence interval of 0.08 to 0.19. The second trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.10 with a 95 percent confidence interval of 0.04 to 0.16. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.08 with a 95 percent confidence interval of −0.02 to 0.18. The combined effect of these three trials showed a mean difference of 0.11 with a 95 percent confidence interval of 0.05 to 0.17. The I-squared value was 0 percent with a p-value of 0.5541.

Figure F-18 Difference in rescue medication mean puffs in 24 hours: LAMA vs. placebo as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in rescue medication mean puffs in 24 hours from baseline in patients with asthma. Seven trials were included in this analysis. The first trial by Bateman and colleagues in 2011 provided a mean difference of −0.37 with a 95 percent confidence interval of −0.90 to 0.16. The second trial by Ohta and colleagues in 2015 provided a mean difference of −0.01 with a 95 percent confidence interval of −0.26 to 0.25. The third trial by Paggiaro and colleagues in 2016 provided a mean difference of 0.09 with a 95 percent confidence interval of −0.13 to 0.32. The fourth trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of −0.01 with a 95 percent confidence interval of −0.26 to 0.23. The fifth trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of −0.03 with a 95 percent confidence interval of −0.25 to 0.19. The sixth trial by Lee and colleagues in 2015 provided a mean difference of −0.29 with a 95 percent confidence interval of −0.69 to 0.10. The seventh trial by Hamelmann and colleagues in 2016 provided a mean difference of −0.29 with a 95 percent confidence interval of −0.53 to −0.05. The combined effect of these seven trials showed a mean difference of −0.08 with a 95 percent confidence interval of −0.23 to 0.07. The I-squared value was 27.8 percent with a p-value of 0.2161.

Figure F-19 All-cause death: LAMA vs. LABA as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on all-cause death in patients with asthma. Four trials were included in this analysis. The first trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication did not report any outcomes in either group and was not factored into the pooled estimate. The second trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication did not report any outcomes in either group and was not factored into the pooled estimate. The third trial by Lee and colleagues in 2015 did not report any outcomes in either group and was not factored into the pooled estimate. The fourth trial by Wechsler and colleagues in 2015 provided an odds ratio of 7.50 with a 95 percent confidence interval of 0.78 to 72.27. The combined effect of these four trials showed an odds ratio of 7.50 with a 95 percent confidence interval of 0.78 to 72.27. The I-squared value could not be calculated since only a single study contributed data to the pooled estimate.

Figure F-20 Asthma-specific death: LAMA vs. LABA as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on asthma-related death in patients with asthma. Four trials were included in this analysis. The first trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication did not report any outcomes in either group and was not factored into the pooled estimate. The second trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication did not report any outcomes in either group and was not factored into the pooled estimate. The third trial by Lee and colleagues in 2015 did not report any outcomes in either group and was not factored into the pooled estimate. The fourth trial by Wechsler and colleagues in 2015 provided an odds ratio of 7.49 with a 95 percent confidence interval of 0.47 to 119.83. The combined effect of these four trials showed an odds ratio of 7.49 with a 95 percent confidence interval of 0.47 to 119.83. The I-squared value could not be calculated since only a single study contributed data to the pooled estimate.

Figure F-21 Change in FEV1 trough from baseline: LAMA vs. LABA as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on the change in trough forced expiratory volume in 1 second from baseline in patients with asthma. Six trials were included in this analysis. The first study by Peters and colleagues in 2010 provided a mean difference of 0.12 with a 95 percent confidence interval of −0.15 to 0.39. The second trial by Bateman and colleagues in 2011 provided a mean difference of −0.02 with a 95 percent confidence interval of −0.10 to 0.06. The third trial by Lee and colleagues in 2015 provided a mean difference of −0.05 with a 95 percent confidence interval of −0.15 to 0.05. The fourth trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.05 with a 95 percent confidence interval of 0.00 to 0.10. The fifth trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.05 with a 95 percent confidence interval of 0.00 to 0.10. The sixth trial by Wechsler and colleagues in 2015 provided a mean difference of −0.02 with a 95 percent confidence interval of −0.09 to 0.04. The combined effect of these six trials showed a mean difference of 0.02 with a 95 percent confidence interval of −0.03 to 0.06. The I-squared value was 31.5 percent with a p-value of 0.1993.

Figure F-22 Change in FEV1 % predicted from baseline: LAMA vs. LABA as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on the change in percent predicted forced expiratory volume in 1 second from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Rajanandh and colleagues in 2014 provided a mean difference of −7.34 with a 95 percent confidence interval of −8.30 to −6.38. The second trial by Rajanandh and colleagues in 2015 provided a mean difference of −4.46 with a 95 percent confidence interval of −6.71 to −2.21. The third trial by Wechsler and colleagues in 2015 provided a mean difference of −0.63 with a 95 percent confidence interval of −4.41 to 3.15. The combined effect of these three trials showed a mean difference of −4.54 with a 95 percent confidence interval of −12.69 to 3.61. The I-squared value was 87 percent with a p-value of 0.0005.

Figure F-23 Change in FVC trough from baseline: LAMA vs. LABA as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on the change in trough forced vital capacity from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Bateman and colleagues in 2011 provided a mean difference of 0.01 with a 95 percent confidence interval of −0.08 to 0.11. The second trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.03 with a 95 percent confidence interval of −0.03 to 0.10. The third trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.02 with a 95 percent confidence interval of −0.05 to 0.08. The combined effect of these three trials showed a mean difference of 0.02 with a 95 percent confidence interval of 0.00 to 0.05. The I-squared value was 0 percent with a p-value of 0.9237.

Figure F-24 Change in AQLQ score from baseline: LAMA vs. LABA as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on the change in asthma quality of life questionaire from baseline in patients with asthma. Four trials were included in this analysis. The first trial by Peters and colleagues in 2010 provided a mean difference ot −0.22 with a 95 percent confidence interval of −0.60 to 0.16. The second trial by Wechsler in 2015 provided a mean difference of 0.05 with a 95 percent confidence interval of −0.23 to 0.33. The third trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of −0.07 with a 95 percent confidence interval of −0.20 to 0.06. The fourth trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of −0.05 with a 95 percent confidence interval of −0.18 to 0.08. The combined effect of these four trials showed a mean difference of −0.06 with a 95 percent confidence interval of −0.15 to 0.03. The I-squared value was 0 percent with a p-value of 0.7178.

Figure F-25 Difference in rescue medication mean puffs in 24 hours: LAMA vs. LABA as add-on to ICS

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus long-acting beta-agonists on the change in rescue medication mean puffs in 24 hours from baseline in patients with asthma. Seven trials were included in this analysis. The first trial by Bateman and colleagues in 2011 provided a mean difference of 0.20 with a 95 percent confidence interval of −0.32 to 0.72. The second trial by Rajanandh and colleagues in 2014 provided a mean difference of 1.38 with a 95 percent confidence interval of 0.89 to 1.87. The third trial by Rajanandh and colleagues in 2015 provided a mean difference of 2.03 with a 95 percent confidence interval of 1.72 to 2.34. The fourth trial by Wechsler and colleagues in 2015 provided a mean difference of −0.05 with a 95 percent confidence interval of −0.71 to 0.61. The fifth trial by Kerstjens and colleagues in 2015 is the first of two trials reported in that publication and provided a mean difference of 0.44 with a 95 percent confidence interval of 0.20 to 0.68. The sixth trial by Kerstjens and colleagues in 2015 is the second of two trials reported in that publication and provided a mean difference of 0.09 with a 95 percent confidence interval of −0.13 to 0.31. The seventh trial by Lee and colleagues in 2015 provided a mean difference of 0.14 with a 95 percent confidence interval of −0.25 to 0.53. The combined effect of these seven trials showed a mean difference of 0.61 with a 95 percent confidence interval of −0.12 to 1.35. The I-squared value was 95.2 percent with a p-value of less than 0.0001.

Figure F-26 Change in ACQ-7 score from baseline: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in Asthma Control Questionnaire 7 score from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of −0.12 with a 95 percent confidence interval of −0.27 to 0.09. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of −0.13 with a 95 percent confidence interval of −0.27 to 0.01. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.05 with a 95 percent confidence interval of −0.11 to 0.20. The combined effect of these three trials showed a mean difference of −0.07 with a 95 percent confidence interval of −0.31 to 0.17. The I-squared value was 39.5 percent with a p-value of 0.1917.

Figure F-27 Change in FEV1 peak from baseline: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in peak forced expiratory volume in 1 second from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of 0.07 with a 95 percent confidence interval of 0.00 to 0.14. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of 0.15 with a 95 percent confidence interval of 0.08 to 0.22. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.10 with a 95 percent confidence interval of −0.01 to 0.21. The combined effect of these three trials showed a mean difference of 0.11 with a 95 percent confidence interval of 0.00 to 0.22. The I-squared value was 18.4 percent with a p-value of 0.2936.

Figure F-28 Change in FEV1 trough from baseline: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in trough forced expiratory volume in 1 second from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of 0.04 with a 95 percent confidence interval of −0.03 to 0.11. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of 0.09 with a 95 percent confidence interval of 0.03 to 0.16. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.08 with a 95 percent confidence interval of −0.03 to 0.20. The combined effect of these three trials showed a mean difference of 0.07 with a 95 percent confidence interval of 0.00 to 0.14. The I-squared value was 0 percent with a p-value of 0.5656.

Figure F-29 Change in FEV1 AUC from baseline: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in forced expiratory volume in 1 second area under the curve from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of 0.07 with a 95 percent confidence interval of 0.00 to 0.14. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of 0.14 with a 95 percent confidence interval of 0.07 to 0.20. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.10 with a 95 percent confidence interval of 0.00 to 0.20. The combined effect of these three trials showed a mean difference of 0.10 with a 95 percent confidence interval of 0.01 to 0.19. The I-squared value was 0 percent with a p-value of 0.3976.

Figure F-30 Change in FVC peak from baseline: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in peak forced vital capacity from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of 0.12 with a 95 percent confidence interval of 0.03 to 0.22. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of 0.12 with a 95 percent confidence interval of 0.02 to 0.21. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.08 with a 95 percent confidence interval of −0.04 to 0.19. The combined effect of these three trials showed a mean difference of 0.11 with a 95 percent confidence interval of 0.05 to 0.17. The I-squared value was 0 percent with a p-value of 0.8061.

Figure F-31 Change in FVC trough from baseline: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in trough forced vital capacity from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of 0.11 with a 95 percent confidence interval of 0.02 to 0.20. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of 0.07 with a 95 percent confidence interval of −0.02 to 0.16. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of 0.08 with a 95 percent confidence interval of −0.04 to 0.20. The combined effect of these three trials showed a mean difference of 0.09 with a 95 percent confidence interval of 0.03 to 0.15. The I-squared value was 0 percent with a p-value of 0.798.

Figure F-32 Change in FVC AUC from baseline: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in forced vital capacity area under the curve from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of 0.12 with a 95 percent confidence interval of 0.04 to 0.21. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of 0.11 with a 95 percent confidence interval of 0.02 to 0.20. The third trial by Hamelmann and colleagues in 2012 provided a mean difference of 0.07 with a 95 percent confidence interval of −0.04 to 0.18. The combined effect of these three trials showed a mean difference of 0.10 with a 95 percent confidence interval of 0.04 to 0.17. The I-squared value was 0 percent with a p-value of 0.7566.

Figure F-33 Difference in rescue medication mean puffs in 24 hours: LAMA added to ICS and LABA vs. ICS and LABA

This figure depicts the meta-analysis of the impact of long-acting muscarinic agents versus placebo on the change in rescue medication mean puffs in 24 hours from baseline in patients with asthma. Three trials were included in this analysis. The first trial by Kerstjens and colleagues in 2012 is the first of two trials reported in that publication and provided a mean difference of −0.09 with a 95 percent confidence interval of −0.47 to 0.29. The second trial by Kerstjens and colleagues in 2012 is the second of two trials reported in that publication and provided a mean difference of −0.26 with a 95 percent confidence interval of −0.71 to 0.18. The third trial by Hamelmann and colleagues in 2016 provided a mean difference of −0.03 with a 95 percent confidence interval of −0.32 to 0.26. The combined effect of these three trials showed a mean difference of −0.10 with a 95 percent confidence interval of −0.37 to 0.18. The I-squared value was 0 percent with a p-value of 0.6884.