# Appendix E Strength of Evidence Assessments

Table E-1 Strength of evidence KQ1a, intermittent ICS with as-needed SABA vs. as-needed SABA

Outcome | N of studies (n of patients) | Study limitations | Consistency | Directness | Precision | Publication bias | Strength of evidence (rational)
Exacerbations
Requiring oral corticosteroid | 3 (324) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 3 (324) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related acute care visit | 3 (324) | Low | Consistent | Direct | Precise | Undetected | High
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry
FEV1 peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
PACQLQ score | 2 (270) | Low | Unknown consistency (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Healthcare utilization
Daytime rescue medication use, mean puffs/day | 1 (166) | Low | Unknown consistency (single study) | Direct | Precise | Undetected | Low
Nighttime rescue medication use, mean puffs/night | 1 (166) | Low | Unknown consistency (single study) | Direct | Precise | Undetected | Low
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n=patient sample size; N=number of studies; NA=not applicable; PACQLQ=Pediatric Asthma Caregiver’s Quality of Life Questionnaire

Table E-2 Strength of evidence KQ1a, intermittent ICS with as-needed SABA vs. ICS controller with as-needed SABA

Outcome | N of studies (n of patients) | Study limitations | Consistency | Directness | Precision | Publication bias | Strength of evidence (rationale)
Exacerbations
Requiring oral corticosteroid | 1 (278) | Low | Unknown consistency (single study) | Direct | Precise | Undetected | Low (unknown consistency)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 1 (278) | Low | Unknown consistency (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related acute care visits | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry
FEV1 peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
PACQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization
Daytime rescue medication use, mean puffs/day | 1 (220) | Low | Unknown consistency (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Nighttime rescue medication use, mean puffs/night | 1 (220) | Low | Unknown consistency (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable; PACQLQ=Pediatric Asthma Caregiver’s Quality of Life Questionnaire

Table E-3 Strength of evidence KQ1a, intermittent ICS vs. no therapy

Outcome | N of studies (n of patients) | Study limitations | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 1 (26) | Low | Unknown consistency (single study) | Direct | Imprecise | Undetected | Insufficient
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ED visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 1 (26) | Low | Unknown consistency (single study) | Direct | Imprecise | Undetected | Insufficient
Asthma-related ER visit | 1 (26) | Low | Unknown consistency (single study) | Direct | Imprecise | Undetected | Insufficient
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related acute care visits | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry
FEV1 peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
PACQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization
Daytime rescue medication use, mean puffs/day | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Nighttime rescue medication use, mean puffs/night | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable; PACQLQ=Pediatric Asthma Caregiver’s Quality of Life Questionnaire;

Table E-4 Strength of evidence KQ1b, intermittent ICS and ICS controller vs. ICS controller

Outcome | N of studies (n of patients) | Study limitations | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations ≥12y
Requiring oral corticosteroid (full population) | 3 (908) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Requiring oral corticosteroid (of those that started study inhaler) | 3 (399) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring oral corticosteroid, unscheduled doctor visit, ER, or unstable asthma^a^ | 1 (98) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Asthma-related hospitalization | 1 (115) | Medium | Unknown (single study) | Direct | Imprecise | Undetected | Insufficient (risk of bias, unknonw consistency, imprecise)
Asthma-related ER visits | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 2 (505) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Asthma-related acute care visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Unstable asthma^a^ | 1 (98) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
2 or 3 exacerbations requiring oral corticosteroid (full population) | 1 (403) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
2 or 3 exacerbations requiring oral corticosteroid (of those starting the study inhaler) | 1 (403) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Fall in PEF <70% from baseline | 1 (134) | Unclear | Unknown (single study) | Direct | Imprecise | Undeteced | Low (unknown consistency, imprecise)
Exacerbations 4 to 11y
Requiring oral corticosteroid | 1 (143) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Insufficient (unknonw consistency, indirect)
Requiring hospitalization | 1 (29) | Unclear | Unknown (single study) | Direct | Imprecise | Undetected | Insufficient (unknonw consistency, imprecise)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization or ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Treatment failure^b^ | 1 (143) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Insufficient (unknonw consistency, indirect, imprecise)
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry ≥12y
FEV1 peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry 4 to 11y
FEV1 % predicted | 1 (29) | Unclear | Unknown (single study) | Direct | Imprecise | Undetected | Insufficient (Unclear ROB, unknown consistency, imprecise)
Quality of life ≥12y
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
PACQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life 4 to 11y
PAQLQ score | 1 (143) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Healthcare utilization ≥12y
Daytime rescue medication use mean puffs/day | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Nighttime rescue medication use mean puffs/night | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization 4 to 11y
Albuterol puffs/day | 1 (143) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Insufficient (unknonw consistency, indirect, imprecise)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable; PACQLQ=Pediatric Asthma Caregiver’s Quality of Life Questionnaire; PAQLQ=Pediatric Asthma Quality of Life Questionnaire; y=years

a Defined as absence of stability, where stability was defined as morning peak expiratory flow 90% or more of mean baseline value on either of the two previous days, <4 inhalations of inhaled corticosteroid per day over the past 2 days, no nocturnal awakenings in the prior 2 nights and a total symptom score not exceeding mean baseline value more than 2 ordinal values over the previous 2 days

b Defined as any of following: (1) Hospitalization due to asthma; (2) Hypoxic seizure due to asthma; (3) Intubation due to asthma; (4) Requirement for a second burst of prednisone within any 6 months period; (5) Significant adverse event related to the use of a study medication. The only criterion for assignment of treatment failure during the trial was the requirement for a second burst of prednisone within any 6 month period

Table E-4 Strength of evidence KQ1b, intermittent ICS vs. ICS controller

Outcome | N of studies (n of patients) | Study limitations | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations ≥12y
Requiring oral corticosteroid | 1 (149) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Requiring hospitalization | 1 (149) | Low | Unknown (single study) | Direct | Precise | Undetected | Insufficient (no events occurred)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related urgent care visit | 1 (227) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Mild^c^ or severe^d^ exacerbation | 1 (228) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Severe exacerbation^d^ | 1 (228) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Exacerbations 4 to 11y
Requiring oral corticosteroid | 1 (143) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Insufficient (unknown consistency, indirect, imprecise)
Treatment failure^a^ | 1 (143) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Insufficient (unknown consistency, indirect, imprecise)
Mortality
All-cause mortality | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific death | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 1 (149) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
ACQ-7 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 score | 1 (227) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry ≥12y
FEV1 peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 trough | 2 (564) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted | 3 (713) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
FVC peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC trough | 1 (228) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknonw consistency)
FVC AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC % predicted | 1 (228) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistenct, imprecsie)
Asthma control-spirometry 4 to 11y
FEV1 % predicted | 1 (143) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Insufficient (unknown consistency, indirect, imprecise)
Quality of life ≥12y
AQLQ score | 2 (376) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
PACQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life 4 to 11y
PAQLQ score | 1 (143) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Healthcare utilization ≥12y
Albuterol puffs/day | 2 (564) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization 4 to 11y
Albuterol puffs/day | 1 (143) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable; PACQLQ=Pediatric Asthma Caregiver’s Quality of Life Questionnaire; PAQLQ=Pediatric Asthma Quality of Life Questionnaire; y=years

a Defined as any of following: (1) Hospitalization due to asthma; (2) Hypoxic seizure due to asthma; (3) Intubation due to asthma; (4) Requirement for a second burst of prednisone within any 6 months period; (5) Significant adverse event related to the use of a study medication. The only criterion for assignment of treatment failure during the trial was the requirement for a second burst of prednisone within any 6 month period

c Defined as awakening at night owing to asthma or as a decrease in the morning peak expiratory flow rate to more than 20% below the baseline value, the use of more than three additional puffs per day of rescue medication (either albuterol or beclomethasone and albuterol) as compared with during the baseline for 2 or more consecutive days, or both. Single, isolated days on which mild exacerbation occurred were not counted

d Defined as a decrease in the morning peak expiratory flow rate to more than 30% below the baseline value on 2 consecutive days or more than 8 puffs per day of rescue medication for 3 consecutive days or the need for treatment with oral corticosteroids, as judged by the investigator

Table E-5 Strength of evidence KQ1c, ICS and LABA controller and quick relief vs. ICS controller (same dose)

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization or ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring systemic corticosteroid, hospitalization, or ER visit | 1 (1890) | Low | Unknown (single study) | Direct | Precise | Undetected | Moderate (unknown consistency)
Requiring systemic corticosteroid, hospitalization, ER visit, or PEF<70% | 2 (2586) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Mortality
All-cause | 1 (1890) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Insufficient (unknown consistency, imprecise)
Asthma-specific | 1 (1890) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry
FEV1 | 1 (1890) | Low | Unknown (single study) | Direct | Precise | Undetected | Moderate (unknown consistency)
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of Life
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare Utilization
Mean PRN inhalations/day | 1 (697) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Mean PRN inhalations/week | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n=patient sample size; N=number of studies; NA=not applicable; PRN=pro re nata (i.e., as-needed

Table E-6 Strength of evidence KQ1c, ICS and LABA controller and quick relief vs. ICS controller (higher dose)

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations ≥12 years
Requiring systemic corticosteroid | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ED visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring systemic corticosteroid, hospitalization, ER visit, or PEF<70% (increase in ICS or other medication as well for 4 to 11 year olds) | 1 (1851) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Requiring systemic corticosteroids, hospitalization, or ER visit (increase in ICS or other medication as well for 4 to 11 year olds) | 1 (1851) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization or ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Exacerbations 4 to 11 years
Requiring systemic corticosteroid, hospitalization, ER visit, increase in ICS or other medication, or PEF <70% | 1 (224) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Low (unknown consistency, indirect)
Requiring systemic corticosteroid, hospitalization, or ER visit | 1 (224) | Low | Unknown (single study) | Indirect | Imprecise | Undetected | Low (unknown consistency, indirect)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization or ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Mild exacerbation | 1 (224) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry
FEV1 | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of Life
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization
Mean PRN inhalations/day | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Mean PRN inhalations/week | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n=patient sample size; N=number of studies; NA=not applicable; PRN=pro re nata (i.e., as-needed)

Table E-7 Strength of evidence KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (same dose)

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations ≥12y
Requiring systemic corticosteroid | 2 (3792) | Low | Consistent | Direct | Precise | Undetected | High
Requiring hospitalization | 2 (2224) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Requiring ER visit | 1 (2091) | Low | Unknown (single study) | Direct | Precise | Undetected | Moderate (unknown consistency)
Requiring ICU/ventilation | 1 (1701) | Low | Unknown (single study) | Direct | Precise | Undetected | Insufficient (no events occurred)
Requiring systemic corticosteroid, hospitalization, or ER visit | 5 (8483) | Low | Consistent | Direct | Precise | Undetected | High
Requiring hospitalization or ER visit | 5 (8313) | Low | Consistent | Direct | Precise | Undetected | High
Asthma-related outpatient visits | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring systemic corticosteroid, hospitalization, ER visit, or unscheduled visit | 1 (2143) | Medium | Unknown (single study) | Direct | Precise | Undetected | Moderate (unknown consistency)
Mild exacerbation | 3 (6037) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (unknown consistency)
Exacerbations 4 to 11y
Requiring systemic corticosteroid, hospitalization, ER visit, increase in ICS or other medication, or PEF <70% | 1 (341) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Exacerbations requiring hospitalization, systemic corticosteroids, ER, or increase in ICS or other medications | 1 (341) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Mild exacerbations | 1 (341) | Low | Unknown (single study) | Indirect | Precise | Undetected | Low (unknown consistency, indirect)
Mortality ≥12y
All-cause | 4 (6782) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Asthma-specific | 4 (6782) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma control-composite measures ≥ 12y
ACT | 1 (63) | Unclear | Unknown (single study) | Direct | Precise | Undetected | Insufficient (unknown consistency)
ACQ-5 score | 3 (4353) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
ACQ-5 responder | 1 (2091) | Low | Unknown (single study) | Direct | Precise | Undetected | Moderate (unknown consistency)
Asthma control-spirometry ≥12y
FEV1 | 5 (6343) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
FEV1 % predicted | 2 (304) | Medium | Consistent | Direct | Precise | Undetected | Moderate (risk of bias)
FVC | 1 (1701) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Quality of life ≥12y
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Healthcare utilization ≥12y
Mean PRN inhalations/day | 3 (6006) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Mean PRN inhalations/week | 2 (93) | Medium | Consistent | Direct | Imprecise | Undetected | Low (risk of bias, imprecise)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no data)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICS=inhaled corticosteroid; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable; PEF=peak expiratory flow; PRN=pro re nata (i.e., as-needed); y=year

Table E-8 Strength of evidence KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (higher dose)

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 1 (2304) | Low | Unknown (single study) | Direct | Precise | Undetected | Moderate (unknown consistency)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring systemic corticosteroid, hospitalization, or ER visit | 3 (6742) | Low | Consistent | Direct | Precise | Undetected | High
Requiring hospitalization or ER visit | 3 (6742) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Mild exacerbation | 2 (3321) | Low | Unknown^a^ | Direct | Precise | Undetected | Moderate (unknown consistency)
Mortality
All-cause | 4 (5757) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Asthma-specific | 4 (5757) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
ACQ-5 score | 3 (6559) | Low | Consistent | Direct | Precise | Undetected | High
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma control-spirometry
FEV1 | 2 (4424) | Low | Unknown^a^ | Direct | Precise | Undetected | Moderate (unknown consistency)
FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Quality of life
AQLQ(S) score | 2 (4270) | Low | Unknown^a^ | Direct | Precise | Undetected | Moderate (unknown consistency)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Healthcare utilization
Mean PRN inhalations/day | 3 (6559) | Low | Consistent | Direct | Precise | Undetected | High
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no data)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AQLQ(S)=standardized Asthma Quality of Life Questionnaire; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n=patient sample size; N=number of studies; NA=not applicable; PRN=pro re nata (i.e., as-needed)

a A single 3-arm trial contributed two unique comparisons for this outcome. Thus, the consistency with an independent trial population is unknown

Table E-9 Strength of evidence KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (lower dose)

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
ACQ-5 score | 1 (30) | Medium | Unknown (single study) | Direct | Imprecise | Undetected | Insufficient (risk of bias, unknown consistency, imprecise)
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma control-spirometry
FEV1 % predicted | 1 (30) | Medium | Unknown (single study) | Direct | Precise | Undetected | Insufficient (risk of bias, unknown consistency, imprecise)
FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Quality of life
AQLQ(S) score | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Healthcare utilization
Mean PRN inhalations/week | 1 (30) | Medium | Unknown (single study) | Direct | Imprecise | Undetected | Insufficient (risk of bias, unknown consistency, imprecise)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no data)

Table E-10 Strength of evidence KQ1c, ICS and LABA controller and quick relief vs. CBP

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 4 (4935) | Medium | Consistent | Direct | Imprecise | Undetected | Low (risk of bias, imprecise)
Requiring hospitalization | 4 (4935) | Medium | Consistent | Direct | Imprecise | Undetected | Low (risk of bias, imprecise)
Requiring ER visit | 4 (4935) | Medium | Consistent | Direct | Imprecise | Undetected | Low (risk of bias, imprecise)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Requiring systemic corticosteroid, hospitalization, or ER visit | 6 (6354) | Medium | Consistent | Direct | Precise | Undetected | Moderate (risk of bias)
Mortality
All-cause | 4 (4935) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Asthma-specific | 4 (4935) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
ACQ-5 score | 5 (4996) | Medium | Consistent | Direct | Precise | Undetected | Moderate (risk of bias)
ACQ-5 responder | 2 (2166) | Medium | Consistent | Direct | Precise | Undetected | Moderate (risk of bias)
Asthma control-spirometry
FEV1 | 1 (271) | Medium | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
FEV1 % predicted | 1 (102) | Medium | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Quality of life
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no data)
Healthcare utilization
Mean PRN inhalations/day | 2 (2404) | Medium | Consistent | Direct | Precise | Undetected | Moderate (risk of bias)
≥1 day w/PRN inhalation | 2 (1562) | Medium | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no data)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable; PRN=pro re nata (i.e., as-needed)

Table E-11 Strength of evidence KQ 2a, LAMA as add-on to ICS vs. doubling ICS dose

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 1 (210) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma worsening | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring oral corticosteroid or increase in ICS or other asthma medication | 1 (210) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-6 score | 1 (127) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
ACQ-6 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry
FEV1 peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 trough | 1 (118) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
FEV1 AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 1 (122) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization
Rescue medication use, puffs/24 hours | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICS=inhaled corticosteroid; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable;

Table E-12 Strength of evidence KQ2a, LAMA vs. placebo as add-on to ICS

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 5 (3036) | Low | Consistent | Direct | Precise | Undetected | High
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ED visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma worsening | 4 (2420) | Low | Consistent | Direct | Precise | Undetected | High
Mortality
All-cause mortality | 6 (3065) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma-specific deaths | 6 (3065) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-6 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-6 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 4 (2304) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
ACQ-7 responder | 5 (2680) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
Asthma control-spirometry
FEV1 peak | 4 (2310) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 trough | 7 (3173) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 AUC | 3 (2310) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 % predicted | 1 (457) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
FVC peak | 3 (1853) | Low | Consistent | Direct | Precise | Undetected | High
FVC trough | 5 (2390) | Low | Consistent | Direct | Precise | Undetected | High
FVC AUC | 3 1859) | Low | Consistent | Direct | Precise | Undetected | High
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 2 (1461) | Low | Consistent | Direct | Precise | Undetected | High
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ-mini score | 1 (253) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
AQLQ-S 12+ responder | 1 (397) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
Healthcare utilization
Rescue medication use, puffs/24 hours | 7 (3104) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AQLQ-S=Standardized Asthma Quality of Life Questionnaire; AUC=area under curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; ICU=intensive care unit; n= patient sample size; N=number of studies; NA=not applicable

Table E-13 Strength of evidence KQ2b, LAMA vs. LABA as add-on to ICS

Outcome | N of studies (n of patients) | Risk of bias | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 4 (2574) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma worsening | 1 (1577) | Low | Unknown (single study) | Direct | Precise | Undetected | Moderate (unknown consistency)
Requiring oral corticosteroid or increase in ICS or other asthma medication | 1 (210) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
Mortality
All-cause | 4 (3572) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Asthma-specific | 4 (3572) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-6 score | 1 (126) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
ACQ-6 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 2 (1577) | Low | Consistent | Direct | Precise | Undetected | High
ACQ-7 responder | 2 (1577) | Low | Consistent | Direct | Precise | Undetected | High
Asthma control-spirometry
FEV1 peak | 2 (1483) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 trough | 6 (3261) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 AUC | 2 (1483) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 % predicted | 3 (542) | Medium | Inconsistent | Direct | Precise | Undetected | Low (risk of bias, inconsistent)
FVC peak | 2 (1483) | Low | Consistent | Direct | Precise | Undetected | High
FVC trough | 2 (1745) | Low | Consistent | Direct | Precise | Undetected | High
FVC AUC | 2 (1483) | Low | Consistent | Direct | Precise | Undetected | High
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 4 (1982) | Low | Consistent | Direct | Precise | Undetected | High
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ-mini score | 1 (262) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
AQLQ-S 12+ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization
Rescue medication use, puffs/24 hours | 7 (2450) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AQLQ-S= Standardized Asthma Quality of Life Questionnaire; AUC=area under curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; h=hour; ICU=intensive care unit; LAMA=long acting muscarinic antagonist; n= patient sample size; N=number of studies; NA=not applicable

Table E-14 Strength of evidence KQ2a, LAMA vs. controller other than LABA as add-on to ICS

Outcome | N of studies (n of patients) | Study limitations | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma worsening | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Mortality
All-cause | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-specific | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-composite measures
ACT | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-6 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-6 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-7 responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma control-spirometry
FEV1 peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1 % predicted LAMA vs. montelukast | 2 (214) | Medium | Consistent | Direct | Precise | Undetected | Moderate (risk of bias)
FEV1 % predicted LAMA vs. doxofylline | 2 (209) | Medium | Consistent | Direct | Precise | Undetected | Moderate (risk of bias)
FVC peak | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC trough | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC AUC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ-mini score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
AQLQ-S 12+ responder | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Healthcare utilization
Rescue medication use, puffs/24 hours LAMA vs. montelukast | 2 (214) | Medium | Inconsistent | Direct | Precise | Undetected | Low (risk of bias, inconsistent)
Rescue medication use, puffs/24 hours LAMA vs. doxofylline | 2 (209) | Medium | Inconsistent | Direct | Precise | Undetected | Low (risk of bias inconsistent)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AQLQ-S= Standardized Asthma Quality of Life Questionnaire; AUC=area under curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; h=hour; ICU=intensive care unit; LAMA=long acting muscarinic antagonist; n=patient sample size; N=number of studies; NA=not applicable

Table E-15 Strength of evidence KQ2c, LAMA and ICS and LABA vs. ICS and LABA

Outcome | N of studies (n of patients) | Study limitations | Consistency | Directness | Precision | Publication bias | Strength of evidence
Exacerbations
Requiring systemic corticosteroid | 3 (1299) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Requiring hospitalization | 2 (907) | Low | Consistent | Direct | Imprecise | Undetected | Moderate (imprecise)
Requiring ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Requiring ICU/ventilation | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related hospitalization | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related ER visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma-related outpatient visit | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Asthma worsening | 3 (1299) | Low | Consistent | Direct | Precise | Undetected | High
Mortality
All-cause | 3 (1299) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma-specific | 3 (1299) | Low | Consistent | Direct | Precise | Undetected | Insufficient (no events occurred)
Asthma control-composite measures
ACT | 1 (63) | Unclear | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
ACQ-5 score | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
ACQ-5 responder | 1 (907) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Low (unknown consistency, imprecise)
ACQ-6 score | 1 (338) | Low | Unknown (single study) | Direct | Precise | Undetected | Low (unknown consistency)
ACQ-6 responder | 2 (1299) | Low | Inconsistent | Direct | Imprecise | Undetected | Low (inconsistent, imprecise)
ACQ-7 score | 3 (1301) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
ACQ-7 responder | 2 (1299) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
Asthma control-spirometry
FEV1 peak | 3 (1295) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
FEV1 trough | 3 (1295) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
FEV1 AUC | 3 (1295) | Low | Consistent | Direct | Precise | Undetected | High
FEV1 % predicted | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
FVC peak | 3 (1295) | Low | Consistent | Direct | Precise | Undetected | High
FVC trough | 3 (1295) | Low | Consistent | Direct | Precise | Undetected | High
FVC AUC | 3 (1295) | Low | Consistent | Direct | Precise | Undetected | High
FEV1/FVC | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)
Quality of life
AQLQ score | 2 (907) | Low | Consistent | Direct | Precise | Undetected | High
AQLQ responder | 1 (907) | Low | Unknown (single study) | Direct | Imprecise | Undetected | Moderate (unknown consistency imprecise)
Healthcare utilization
Rescue medication use, puffs/24 hours | 3 (1302) | Low | Inconsistent | Direct | Precise | Undetected | Moderate (inconsistent)
Resource use | 0 | NA | NA | NA | NA | NA | Insufficient (no evidence)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under curve; ER=emergency room; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; h=hour; ICU=intensive care unit; n=patient sample size; N=number of studies; NA=not applicable