# Appendix D Risk of Bias Assessment

Table D-1 Risk of bias assessment for KQ1a

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Svedmyr, 1999^48^ | Unclear | Unclear | Unclear | Unclear | High | Unclear | Low | Unclear
Ghirga, 2002^46^ | Unclear | Unclear | High | High | Low | Unclear | Low | Medium
Bacharier, 2008^44^ | Low | Low | Low | Low | Low | Unclear | Low | Low
Ducharme, 2009^45^ | Low | Low | Low | Low | High | Low | Low | Low
Papi, 2009^47^ | Unclear | Unclear | Low | Low | Low | Low | Low | Low
Zeiger, 2011^49^ | Low | Low | Low | Low | Low | Low | Low | Low

Table D-2 Risk of bias assessment for KQ1b

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Lahdensuo, 1996^59^ | Low | Low | Unclear | Unclear | Low | Unclear^a^ | Low | Medium
Foresi, 2000^48^ | Unclear | Unclear | Unclear | Unclear | Low | Unclear^a^ | Low | Unclear
Colland, 2004^46^ | Unclear | Unclear | Unclear | Unclear | Low | Unclear^a^ | Low | Unclear
FitzGerald, 2004^47^ | Low | Unclear | Low | Low | High | Unclear^a^ | Low | Low
Harrison, 2004^51^ | Low | Low | Low | Low | Low | Unclear^a^ | Low | Low
Boushey, 2005^43^ | Low | Unclear | Low | Low | Low | Unclear^a^ | Low | Low
Papi, 2007^55^ | Low | Low | Low | Low | Low | Low | Low | Low
Turpeinen, 2007^56^ | Low | Unclear | Low | Low | Low | Unclear^a^ | Low | Low
Oborne, 2009^58^ | Low | Low | Low | Low | Low | Low | Low | Low
Martinez, 2011^52^ | Low | Low | Low | Low | Low | Low^b^ | Low | Low
Calhoun, 2012^44^ | Unclear | Low | Low | Low | Low | Low | Low | Low

a Endpoints are not specified as pre-planned, and could not identify published protocol (or clinicaltrials.gov)

b All outcomes awarded a “Yes” with the exception of Asthma Control Test, which is listed as an endpoint on clinicaltrials.gov but results on this outcome is not reported (unclear)

Table D-3 Risk of bias assessment for KQ1c, ICS and LABA controller and quick relief vs. ICS controller (same dose)

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Scicchitano, 2004^88^ | Low | Low | Low | Low | Low | Unclear^a^ | Low | Low
Rabe, 2006^86^ | Unclear | Unclear | Low | Low | Low | Unclear^a^ | Low | Low
Sovani, 2008^91^ | Low | Low | High | High | High | Unclear^a^ | Low | High

a Endpoints are not specified as pre-planned, and could not identify published protocol (or clinicaltrials.gov)

Table D-4 Risk of bias assessment for KQ1c, ICS and LABA controller and quick relief vs. ICS controller (higher dose)

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
O’Byrne, 2005^75^ | Low | Unclear | Low | Low | Low | Low | Low | Low

Table D-5 Risk of bias assessment for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (same dose)

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
O’Byrne, 2005^75^ | Low | Unclear | Low | Low | Low | Low | Low | Low
Vogelmeier, 2005^96^ | Low | Low | High | High | Low | Unclear^a^ | Low | Medium^b^
Rabe, 2006^85^ | Low | Low | Low | Low | Low | Unclear^c^ | Low | Low
Atienza, 2013^62^ | Low | Low | Low | Low | Low | Low | Low | Low
Papi, 2013^76^ | Low | Low | Unclear | Unclear | Low | Low | Low | Low
Patel, 2013^78^ | Low | Low | High | High | Low | Low | Low | Medium^b^
Hozawa, 2014^70^ | Unclear | Unclear | High | High | Low | Unclear^c^ | Low | Medium
Takeyama, 2014^93^ | Unclear | Unclear | Unclear | Unclear | Unclear | Unclear^c^ | Low | Unclear
Stallberg, 2008^92^ | Low | Low | High | High | Low | Low | Low | Medium

a All outcomes were awarded an “unclear” with the exception of exacerbations, which is listed as being determined a priori (yes)

b All outcomes were awarded “medium” with the exception of death (low)

c Endpoints are not specified as pre-planned, and could not identify published protocol (or clinicaltrials.gov)

Table D-6 Risk of bias assessment for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (higher dose)

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Bousquet, 2007^68^ | Low | Low | Low | Low | Low | Low | Low | Low
Kuna, 2007^73^ | Low | Low | Low | Low | Low | Unclear^a^ | Low | Low
Pavord, 2009^81^ | Low | Unclear | Low | Low | Low | Low | Low | Low
Lundborg, 2006^107^ | Low | Unclear | High | High | Low | Unclear^a^ | Low | Medium
Stallberg, 2008^92^ | Low | Low | High | High | Low | Low | Low | Medium

a Endpoints are not specified as pre-planned, and could not identify published protocol (or clinicaltrials.gov)

Table D-7 Risk of bias assessment for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (lower dose)

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Hozawa, 2016^xx^ | Unclear | Unclear | High | High | Low | Unclear^a^ | Low | Medium

a Endpoints are not specified as pre-planned, and could not identify published protocol (or clinicaltrials.gov)

Table D-8 Risk of bias assessment for KQ1c, ICS and LABA controller and quick relief vs. CBP

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Sears, 2008^89^ | Unclear | Unclear | High | High | Low | Low | Low | Medium^a^
Stallberg, 2008^92^ | Low | Low | High | High | Low | Low | Low | Medium
Louis, 2009^74^ | Unclear | Unclear | High | High | Low | Low^b^ | Low | Medium^a^
Quirce, 2011^83^ | Unclear | Unclear | High | High | Low | Unclear^c^ | Low | Medium^a^
Soes-Peterson, 2011^90^ | Unclear | Unclear | High | High | Low | Low | Low | Medium^a^
Riemersma, 2012^87^ | Unclear | Unclear | High | High | Low | Low | Low | Medium

a All outcomes were awarded “medium” with the exception of death (low)

b All outcomes awarded a “yes,” with the exception of the Asthma Control Questionnaire and forced expiratory volume. These were reported but not specified as endpoints on clinicaltrials.gov (unclear)

c There is inconsistency between original and current secondary outcomes on clinicaltrials.gov (unclear). The primary endpoint is reported consistently across original and current secondary outcomes on clinicaltrials.gov (yes)

Table D-9 Risk of bias assessment for non-randomized studies, KQ1c

Study, Year | Representativeness of exposed cohort | Selection of non-exposed cohort | Ascertainment of exposure | Outcome of interest not present at start of study | Comparability of cohorts | Assessment of outcome | Follow-up long enough | Adequacy of follow-up of cohorts | Overall risk of bias
Loh, 2008^106^ | Low | Low | Low | N/A | High^a^ | Low | Low | Low | Medium
Kardos, 2013^71^ | Low | Low | Low | N/A | Low^b^ | Medium | Low | Low | Low

a No information about matching of patient cohorts either for inclusion or analysis

b Cohorts controlled/matched for analysis, but not inclusion

Table D-10 Risk of bias assessment for KQ2a

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Peters, 2010^19^ | Unclear | Unclear | Low | Low | Low | Low | Low | Low
Bateman, 2011^108^ | Low | Low | Low | Low | Low | Low | Low | Low
Kerstjens, 2015^109^ (Study 1) | Low | Low | Low | Low | Low | Low | Low | Low
Kerstjens, 2015^109^ (Study 2) | Low | Low | Low | Low | Low | Low | Low | Low
Lee, 2015^110^ | Low | Low | Unclear | Unclear | Low | Low | Low | Unclear
Ohta, 2015^111^ | Low | Low | Low | Low | Low | Low^a^ | Low | Low
Hamelmann, 2016^113^ | Low | Unclear | Low | Low | Low | Low^b^ | Low | Low
Paggiaro, 2016^112^ | Low | Low | Low | Low | Low | Low | Low | Low

a Exacerbations were not reported but are an objective in the clinicaltrials.gov protocol (no)

b Spirometry is not reported at the end of the treatment period and there is inconsistency on the timing of spirometry assessment on clinicaltrials.gov (unclear)

Table D-11 Risk of bias assessment for KQ2b

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Peters, 2010^19^ | Unclear | Unclear | Low | Low | Low | Low | Low | Low
Bateman, 2011^108^ | Low | Low | Low | Low | Low | Low | Low | Low
Rajanandh, 2014^136^ | Low | Low | High | High | High | Unclear^a^ | Low | High
Kerstjens, 2015^109^ (Study 1) | Low | Low | Low | Low | Low | Low | Low | Low
Kerstjens, 2015^109^ (Study 2) | Low | Low | Low | Low | Low | Low | Low | Low
Lee, 2015^110^ | Low | Low | Unclear | Unclear | Low | Low | Low | Unclear
Rajanandh, 2015^137^ | Low | Low | High | High | Low | Unclear^b^ | Low | Medium
Wechsler, 2015^138^ | Low | Low | High | Low^c^ | Low | Low | Low | Low

a Endpoints are not specified as pre-planned, and could not identify published protocol (or clinicaltrials.gov)

b Endpoints are not specified as pre-planned, and could not identify published protocol (or clinicaltrials.gov)

c Blinded adjudication was used for exacerbation, hospitalization and death endpoints (yes). It is unclear if this blinding was present for the remaining outcomes (unclear)

Table D-12 Risk of bias assessment for KQ2c

Study, Year | Sequence Generation | Allocation concealment | Blinding of participants, personnel | Blinding of Outcome assessors | Incomplete outcome data | Selective outcome reporting | Other sources of bias | Overall risk of bias
Kerstjens, 2012^140^ (Study 1) | Low | Low | Low | Low | Low | Low | Low | Low
Kerstjens, 2012^140^ (Study 2) | Low | Low | Low | Low | Low | Low | Low | Low
Wang, 2015^141^ | Unclear | Unclear | Unclear | Unclear | Low | Unclear^a^ | Low | Unclear
Hamelmann, 2016^142^ | Low | Low | Low | Low | Low | Low | Low | Low

a Endpoints are not specified as pre-planned, and no published protocol (or clinicaltrials.gov) is available