# Appendix C Study Characteristics

Table C-1 Study and population characteristics for KQ1a

Study, Year, Acronym n, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age [mean (SD)] | Males (%) | Parent w/asthma (%) | Atopy (%) | 2^nd^ hand smoke (%) | Systemic corticosteroid in last 12m (%) | Hospitalized in last 12m (%) | ICS dose during study (μg/d) [mean (SD)]
Svedmyr, 1999^48^ n=55 RCT, 12m or 6 treatments Unclear | 1–3 years of age w/≥3 episodes of wheezing w/URTI, asthma symptoms during last 2 airway infections and no symptoms in-between URTI; physician’s diagnosis of wheezy bronchitis or asthma SABA and theophylline use allowed when needed; fixed dose cromoglycate was allowed^a^ | Budesonide 400μg QID x3d then 400μg BID x7d (MDI), initiated by the parent at first sign of URTI n=28 | 25m (12 to 47)^b^ | 60.7 | NR | 25.0^c^ | 7.1^d^ | NR | 1.2 (0 to 4)^b,e^ | NR
Svedmyr, 1999^48^ n=55 RCT, 12m or 6 treatments Unclear | | Placebo MDI x10d initiated by the parent at first sign of URTI n=27 | 26m (13 to 47)^b^ | 77.8 | NR | 22.2^c^ | 7.4^d^ | NR | 1.1 (0 to 3)^b,e^ | NR
Ghirga, 2002^46^ n=26 RCT, until 4 URTIs^f^ Medium | 7–12 months old, history of recurrent wheezing during URTI w/at least 2–3 airway infections causing wheezing | Beclomethasone 400μg TID (neb) x5d initiated by parent w/very early phase of URTI before any sign of wheezing^g^ n=13 | 8.2m (1.6) | 69.2 | NR | NR | NR | NR | NR | NR
Ghirga, 2002^46^ n=26 RCT, until 4 URTIs^f^ Medium | 7–12 months old, history of recurrent wheezing during URTI w/at least 2–3 airway infections causing wheezing | No preventative treatment w/URTI n=13 | 8.2m (1.6) | 69.2 | NR | NR | NR | NR | NR | NR
Bacharier, 2008^44^ AIMS n=143 RCT, 12m Low | 12–59 months old w/≥2 episodes of wheezing in context of RTI within past year^h^, 1 in the past 6 months and 1 documented by a healthcare provider All patients received albuterol QID while awake + PRN for 48h then PRN; oral corticosteroids were available at home^i^ | Budesonide 1mg BID (neb) x7d initiated by parent at the first sign of RTI n=96 | 36.7m (13.5) | 72.9 | 41.7 | 44.8^j^ | 4.2^k^ | 1=21.9 2=26.0 3=8.3 4+=3.1 | 8 | NR
Bacharier, 2008^44^ AIMS n=143 RCT, 12m Low | | Placebo x7d initiated at the first sign of RTI n=47 | 35.7m (13.7) | 48.9 | 53.2 | 44.7^j^ | 1.7^k^ | 1=27.7 2=17.0 3=4.3 4+=4.3 | | NR
Ducharme, 2009^45^ n=129 RCT, 12m Low | 1–6 years old w/≥3 wheezing episodes in lifetime seemingly triggered exclusively by URTI with no symptoms in between, with at least 1 course of rescue systemic corticosteroid in prior 6m or 2 in prior 12m All patients received albuterol 200–400μg q4h PRN for cough, wheeze and dyspnea | Fluticasone 750μg BID (MDI) initiated by parent at first sign of URTI until 48h without cough or wheeze n=62 | 2.60y (1.09) | 52 | 19^l^ | 10^m^ | In utero: 18 In home: 23 | 2.3 (1.1)^n^ | 47 | 50 (39 to 91)^o^
Ducharme, 2009^45^ n=129 RCT, 12m Low | | Placebo initiated by parent at first sign of URTI until 48h without cough or wheeze n=67 | 2.86y (1.20) | 69 | 18^l^ | 12^m^ | In utero: 13 In home: 21 | 2.4 (1.4)^n^ | 52 | NR
Papi, 2009^47^ BEST-children n=276 RCT, 12w Low | 1–4 years old with frequent wheeze (≥3 episodes requiring medical attention) referred to specialist centers because of further episode of wheezing in addition to the 3 required | Beclomethasone/salbutamol 800/1600μg PRN (neb) for symptom relief n=110 | 2.26y (0.79) | 61.8 | NR | NR | NR | NR | NR | 15.1 (21.5)
Papi, 2009^47^ BEST-children n=276 RCT, 12w Low | 1–4 years old with frequent wheeze (≥3 episodes requiring medical attention) referred to specialist centers because of further episode of wheezing in addition to the 3 required | Beclomethasone 400μg BID (neb) + salbutamol 2500μg PRN (neb) for symptom relief n=110 | 2.35y (0.81) | 58.2 | NR | NR | NR | NR | NR | 66.8 (6.8)^p^
Papi, 2009^47^ BEST-children n=276 RCT, 12w Low | 1–4 years old with frequent wheeze (≥3 episodes requiring medical attention) referred to specialist centers because of further episode of wheezing in addition to the 3 required | Salbutamol 2500μg PRN (neb) for symptom relief n=56 | 2.29y (0.78) | 60.7 | NR | NR | NR | NR | NR | NR
Zeiger, 2011^49^ MIST n=278 RCT, 52w Low | 12–53 months old w/positive mAPI and history of ≥4 wheezing episodes in the prior year with ≥1 physician diagnosed or ≥3 wheezing episodes in the prior year with ≥3 months of asthma controller therapy in the prior year All patients received albuterol QID while awake for the first 48h + PRN | Placebo once daily (neb) + budesonide 1mg BID (neb) x7d at RTI onset n=139 | 2.9y (0.9) | 73.4 | 64.9 | 59.9^q^ | 39.6^r^ | 79.1 | 18.7 | 45.7 (38.9 to 52.8)
Zeiger, 2011^49^ MIST n=278 RCT, 52w Low | | Budesonide 500μg (neb) once daily + placebo neb for RTI n=139 | 2.9y (0.9) | 64.7 | 63.7 | 56.8^q^ | 42.4^r^ | 71.9 | 19.4 | 149.9 (140.1 to 159.6)

Abbreviations: BID=twice daily; CI=confidence interval; d=day; h=hour; ICS=inhaled corticosteroid; m=month; IQR=interquartile range; mAPI=modified Asthma Predictive Index; MDI=metered dose inhaler; mg=milligram; n=patient sample size; neb=nebulized; NR=not reported; PRN=pro re nata (i.e., as needed); Q=every; QID=four times daily; RCT=randomized controlled trial; RTI=respiratory tract infection; SABA=short-acting β_2_-agonist; SD=standard deviation; TID=three times daily; URTI=upper respiratory tract infection; μg=microgram; y=year

a Treatment with cromoglycate was 17.9% in the budesonide arm and 22.2% in the placebo arm

b Data reported as mean (range)

c Represents positive skin prick test

d Represents parents smoking indoors

e Represents number of hospital admissions due to asthma

f Patients were not enrolled for a finite time period, but completed the study after 4 URTIs

g At least 2 of 3 URTI signs were to be present before starting medication (nasal discharge, coughing and fever). Treatment was stopped if all signs of URTI disappeared within 24h

h In an effort to include children with prior moderate-to-severe wheezing episodes, children were required to have experienced either 2 urgent care visits for acute wheezing within the past year, 2 wheezing episodes for which oral corticosteroids were prescribed, or 1 episode requiring urgent care and 1 episode requiring oral corticosteroids

i A course of prednisolone was considered if at any point the child had symptoms that did not improve after 3 SABA treatments administered every 15 minutes, if the child needed SABA more than 6 neb treatments or more than 12 puffs/d for >24h, moderate-severe cough or wheeze for at least 5 of the preceding 7 days was present or at physician discretion. The prednisolone course was 2mg/kg/d (maximum 60mg/d) x2d followed by 1mg/kg/d (maximum 30mg/d) x2 d

j Represents positive aeroallergen skin test

k Represents exposure at home or daycare

l Represents maternal asthma

m Represents food or drug allergy, allergies to aeroallergens documented by positive skin test or IgE were excluded

n Represents courses of systemic corticosteroids in the past year, data reported as mean (SD)

o Represents cumulative dose of fluticasone used (mg) per patient-month of observation, data reported as median (IQR)

p Beclomethasone dipropionate equivalent dose in mg

q Represents sensitivity to any aeroallergen

r Represents smoke exposure from birth

s Represents cumulative dose (mg) over study course, data reported as mean (95% CI)

Table C-2 Study level outcomes for KQ1a, intermittent ICS with as-needed SABA vs. ICS controller with as-needed SABA

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma Control | Quality of Life | Healthcare Utilization
Svedmyr, 1999^48^ n=55 RCT, 12m or 6 treatments | Age: 0–4y ICS dose: Budesonide 400μg QIDx3d then BIDx7d vs. PRN SABA | Required oral corticosteroid course: RR 0.90 (0.44 to 1.85) Asthma-related ER visit: RR 0.83 (0.44 to 1.58) Hospital admission due to asthma: RR 2.50 (0.53 to 11.74) Number of ER admissions for asthma: 16 vs. 23 Number of hospital admissions for asthma: 6 vs. 2 Total number of oral corticosteroid courses: 14 vs. 17 | NR | Composite measures: NR Spirometry: NR | NR | NR
Bacharier, 2008^44^ n=143 RCT, 12m | Age: 0–4y ICS dose: Budesonide 1.0mg BID (high) x7d vs. PRN SABA | Required oral corticosteroid course: RR 0.70 (0.49 to 1.00) Asthma-related urgent/ER visit: RR 0.98 (0.71 to 1.34) Number of urgent care/ER visits per patient: −0.5 (−1.16 to 0.16) Hospital admission due to asthma: RR 0.24 (0.05 to 1.29) Average courses of oral corticosteroid/participant: MD −0.2 (0.6 to 0.26) Days of oral corticosteroid use/participant: MD −0.1 (−1.87 to 1.67) | NR | Composite measures: NR Spirometry: NR | PACQLQ score: MD −0.1 (−0.36 to 0.34) | NR
Ducharme, 2009^45^ n=129 RCT, 12m | Age: 0–4y ICS dose: Fluticasone 750μg BID with URTI vs. PRN SABA | Required a course of oral corticosteroid: RR 0.60 (0.42 to 0.87) URTI w/asthma symptoms: OR 0.64 (0.36 to 1.13) URTI requiring systemic corticosteroid: OR 0.49 (0.3 to 0.83) Asthma-related acute care visit: RR 0.88 (0.72 to 1.07) Hospital admission due to asthma: RR 0.72 (0.35 to 1.48) URTI requiring hospitalization: OR 0.67 (0.29 to 1.38) URTI requiring acute care visit: OR 0.79 (0.53 to 1.19) Number of asthma-related acute care visits: 107 vs. 146 Number of asthma-related hospitalizations: 11 vs. 18 | NR | Composite measures: NR Spirometry: NR | PACQLQ score during URTI: MD 0.49 (0.1 to 0.86) | Total number of SABA puffs per URTI [median (IQR)]: 36 (23 to 61) vs. 44 (25 to 78) Total number of days per URTI SABA used [median (IQR)]: 5 (3 to 8) vs. 6 (4 to 10) Duration of SABA use: Rate ratio: 0.85 (0.74 to 0.98) Cumulative number of SABA inhalations: Rate ratio 0.80 (0.68 to 0.94)
Papi, 2009^47^ n=166 RCT, 12w | Age: 0–4y ICS dose: Beclomethasone 800 μg PRN vs. PRN SABA | Progressive increase in SOB, cough or wheeze: 23 total exacerbations, 14 required oral corticosteroid | NR | Composite measures: NR Spirometry: NR | NR | Cumulative salbutamol dose (mg): 30.1 (43.0) vs. 56.3 (84.2), p<0.001 Daytime rescue medication use: MD −0.08 (−0.21 to 0.05) Nighttime rescue medication use: MD −0.04 (−0.11 to 0.03)

Abbreviations: BID=twice daily; EPR=Expert Panel Review (Guidelines for Diagnosis and Management of Asthma); ER=emergency room; HR=hazard ratio; ICS=inhaled corticosteroid; IQR=interquartile range; IRR= incident rate ratio; m=months; MD=mean difference; mg=milligram; n=patient sample size; NR=not reported; OR=odds ratio; PACQLQ=Pediatric Asthma Caregiver’s Quality of Life Questionnaire; PRN=pro re nata (i.e., as-needed); RCT=randomized controlled trial; RR=relative risk; SABA=short-acting β_2_-agonist; SOB=short of breath; μg=microgram; QID=four times daily; URTI=upper respiratory tract infection; w=weeks

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. ICS dose is categorized, when possible, using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations. Number of hospitalizations, hospital days, and ER visits not specified to be due to exacerbation are listed in the healthcare utilization column

Table C-3 Study level outcomes for KQ1a, intermittent ICS with as-needed SABA vs. ICS controller with as-needed SABA

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma Control | Quality of Life | Healthcare Utilization
Papi, 2009^47^ n=220 RCT, 12w | Age: 0–4y ICS dose: Beclomethasone 800 μg PRN vs. 400μg BID | Progressive increase in SOB, cough or wheeze: 23 total exacerbations, 14 required oral corticosteroid | NR | Composite measures: NR Spirometry: NR | NR | Cumulative salbutamol dose (mg): 30.1 (43.0) vs. 34.2 (42.3) Daytime rescue medication use: MD 0.07 (−0.4 to 1.8) Nighttime rescue medication use: MD −0.02 (−0.7 to 0.3)
Zeiger, 2011^49^ n=278 RCT, 52w | Age: 0–4y ICS dose: Budesonide 1.0mg BID (high)x7d vs. 0.5mg (low) daily | Exacerbation requiring prednisolone: HR 0.97 (0.76 to 1.22) IRR 0.99 (0.71 to 1.35) Second exacerbation requiring prednisolone: HR 0.79 (0.49 to 1.32) Exacerbation occurring during RTI: RR 0.99 (0.92 to 1.08) Proportion of RTI in which prednisolone was administered: MD 0.02 (−0.05 to 0.09) Asthma related hospitalization: RR 1.25 (0.34 to 4.56) Asthma related urgent care visit: IRR 0.99 (0.72 to 1.35) | All-cause: No events occurred | Composite measures: NR Spirometry: NR | NR | % days w/albuterol use: MD 0.4 (−1.00 to 2.00)

Abbreviations: BID=twice a day; d=day; EPR=Expert Panel Review (Guidelines for Diagnosis and Management of Asthma); ER=emergency room; HR=hazard ratio; ICS=inhaled corticosteroid; IRR=incident rate ratio; MD=mean difference; mg=milligram; n=patient sample size; NR=not reported; RCT=randomized controlled trial; RR=relative risk; RTI=respiratory tract infection; SOB=short of breath; μg=microgram; w=week; y=year

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. ICS dose is categorized, when possible, using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations. Number of hospitalizations, hospital days, and ER visits not specified to be due to exacerbation are listed in the healthcare utilization column

Table C-4 Study level outcomes for KQ1a, intermittent ICS versus no therapy

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma Control | Quality of Life | Healthcare Utilization
Ghirga, 2002^46^ N=26 RCT, NR | Age: 0–4y ICS dose: Beclomethasone 400μg TIDx5d vs. no preventative therapy | Received oral corticosteroid: RR 0.54 (0.12 to 2.44) Asthma-related hospitalizations: No events occurred Asthma-related ER visits: RR 0.27 (0.04 to 2.10) | NR | Composite measures: NR Spirometry: NR | NR | NR

Abbreviations: d=day; EPR=Expert Panel Review (Guidelines for Diagnosis and Management of Asthma); ER=emergency room; HR=hazard ratio; ICS=inhaled corticosteroid; IRR=incident rate ratio; n=patient sample size; NR=not reported; RCT=randomized controlled trial; RR=relative risk; TID=three times a day; μg=microgram; y=year

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. ICS dose is categorized, when possible, using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations. Number of hospitalizations, hospital days, and ER visits not specified to be due to exacerbation are listed in the healthcare utilization column

Table C-5 Study and population characteristics for KQ1b, intermittent ICS and ICS controller vs. ICS controller

Study, Year, N, Acronym, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Lahdensuo, 1996^67^ n=115 RCT, 12m Medium | ≥18y with mild to moderately severe asthma on budesonide (400–1600μg/d) or beclomethasone (500–2000μg/d) during the prior 6m All patients used SABA as rescue PRN. Other concomitant asthma therapies were continued^a^ | Budesonide 200μg/dose (DPI) self-adjusted: PEF <85% double ICS dose x 2w; PEF<70% initiate oral prednisolone 40mg/d x7d; otherwise maintain stable dose n=56 | 40.6 (14.2) | 26.8 | 8.2 (8.4) | 2.84 (0.74) | 82.4 (15.8) | NR | 979 (375)
Lahdensuo, 1996^67^ n=115 RCT, 12m Medium | | Budesonide (DPI/MDI) or beclomethasone (MDI) traditional treatment with usual evaluation by physician for adjustments n=59 | 42.8 (15.2) | 47.5 | 6.8 (7.6) | 2.96 (0.89) | 81.7 (16.6) | NR | 962 (392), 1167 (408)^b^
Foresi, 2000^56^ n=134 RCT, 6m Unclear | 18–65 years old with moderate perennial asthma, treated with beclomethasone 500–1000μg/d for at least 4w, daily requirement of inhaled β_2_-agoniost, wheeze, cough, chest tightness, SOB at rest that interfered with normal activities during 2w pre-study period Inhaled β_2_-agoniost was allowed PRN and treatment with LABA and theophylline were kept constant^c^ | Budesonide 100μg BID + 200μg QID x 7d if PEF <70%. If PEF remained <70% after 2 days then prednisolone PO 30mg x3–10d added by investigator n=67 | 39.0 (13.5) | 41.8 | <5y=28.4 5–10y= 19.4 >10y=52.2 | NR | 75.6 (9.9) | NR | NR
Foresi, 2000^56^ n=134 RCT, 6m Unclear | | Budesonide 400μg BID+ placebo if PEF <70%. If PEF remained <70% prednisolone initiated as above n=67 | 36.6 (13.1) | 46.3 | <5y=25.4 5 to 10y= 28.4 >10y=46.3 | NR | 73.2 (11.0) | NR | NR
Colland, 2004^54^ n=29 RCT, 1y Unclear | 4 to 11 years old with moderate asthma, ICS naïve with an indication to begin ICS maintenance treatment All patients received beclomethasone or budesonide 400μg, or fluticasone 200–250μg divided over 2 doses (spacer/DPI) | Self-initiated doubling of daily ICS dose x1w with occurrence of prodromal signs n=14 | 6 (4–10)^d^ | 71.4 | NR | NR | 100 (13) | NR | NR
Colland, 2004^54^ n=29 RCT, 1y Unclear | | Daily maintenance medications with no adjustments n=15 | 7 (4–11)^d^ | 60 | NR | NR | 105 (17) | NR | NR
FitzGerald, 2004^55^ n=98 RCT, 6m Low | ≥13 years old with asthma on a stable dose of ≤1200μg beclomethasone or equivalent daily for 1m prior to study, ≥1 exacerbation in prior 12m All patients received budesonide 100–400μg BID depending on their prior maintenance therapy+ terbutaline PRN. Mean budesonide at baseline was 634.7 μg/d. Theophylline was allowed during the study^e^ | Add study inhaler which provided doubling of daily ICS dose x14d if prompted by MiniDoc (PEF<80% + additional required symptoms present); PEF<60% prompted by MiniDoc to take oral methylprednisolone 32mg/d x7d^f^ n=46 | 31.6 (14.6) | 30 | >1y=93 | 2.9 (0.8) | NR | NR | NR
FitzGerald, 2004^55^ n=98 RCT, 6m Low | | Add placebo inhaler x14d if prompted by MiniDoc (PEF<80% + additional required symptoms present); PEF<60% prompted by MiniDoc to take oral methylprednisolone as above n=52 | 32.7 (11.9) | 25 | >1yr=90 | 2.8 (0.6) | NR | NR | NR
Harrison, 2004^59^ n=390 RCT, 12m Low | ≥16 years old with asthma taking ICS (100–2000μg/d) regularly, taken oral corticosteroids or temporarily doubled dose in prior 12m due to an exacerbation, stable during run-in based on PEF and symptoms All patients continued usual treatment throughout the study. Mean ICS dose 708–711μg/d, 34.3–37.5% on LABA at baseline | Add study inhaler which provided doubling of daily ICS dose x14d if AM PEF≤85% or daytime symptom score increased by 1 point from run-in value; if PEF≤60% or asthma control deteriorated to point of usual corticosteroid therapy then oral prednisolone 30mg daily x10d was started n=192 | 50 (13) | 36 | NR | 2.4 (0.8) | 79 (19.6) | NR | NR
Harrison, 2004^59^ n=390 RCT, 12m Low | | Add placebo inhaler x14d for PEF≤85% or symptom score increase. If PEF≤60% or asthma control deteriorated to point of usual corticosteroid therapy then oral prednisolone as above n=198 | 48 (14) | 29 | NR | 2.4 (0.8) | 81 (21.1) | NR | NR
Oborne, 2009^66^ n=403 RCT, 12m Low | ≥16y old with asthma, taking 200–1000μg/d beclomethasone or equivalent, have taken oral corticosteroids or doubled ICS dose in prior 12m for exacerbation Patients self-adjusted therapy according to action plan-AM PEF ≤70% for 1 day or ≤85% for two or more days, in presences of symptom worsening or URTI: start study inhaler for 7d in addition to normal asthma treatment^g^, continue for another 7d if PEF did not return to baseline AM PEF≤40%, general practitioner advised so, or asthma was at the point of usually starting systemic corticosteroids: start prednisone 30mg PO daily | Add study inhaler x7–14d which provided a quadrupling of daily ICS dose, otherwise usual ICS dose daily n=197 | 53 (14) | 41 | NR | 2.4 (0.7) | 83.7 (19) | NR | NR
Oborne, 2009^66^ n=403 RCT, 12m Low | | Add placebo inhaler x7–14d + usual daily ICS dose otherwise n=206 | 55 (13) | 37 | NR | 2.4 (0.7) | 83.2 (18) | NR | NR
Martinez, 2011^60^ TREXA n=143 RCT, 44w Low | 6–18y of age w/history of mild persistent asthma during prior 2y, qualifying for interruption or discontinuation of controller therapy because illness was well controlled per EPR, asthma remained controlled during run-in on beclomethasone 40μg BID; either naïve to controller therapy with 1–2 exacerbations in prior year, treated in prior 8w on monotherapy other than ICS, or if illness was controlled for prior 8w on low-dose ICS monotherapy (≤160μg/d beclomethasone equivalent)^h^ All patients used PRN inhalers every time they would have used albuterol for symptom relief or to treat decreased in PEF, number of puffs was self-determined. All patients received prednisone x4d for asthma exacerbation | Beclomethasone 40μg BID (MDI) with PRN use of beclomethasone 40μg (MDI) + albuterol 90μg (MDI) PRN n=71 | 11.4 (3.1) | 55 | NR | NR | 101.5 (11.7) | NR | NR
Martinez, 2011^60^ TREXA n=143 RCT, 44w Low | | Beclomethasone 40 μg BID (MDI) with PRN use of placebo inhaler + albuterol 90μg (MDI) n=72 | 10.8 (3.5) | 58 | NR | NR | 100.1 (10.8) | NR | NR

Abbreviations: AM=morning; BID=twice daily; d=day; DPI=dry powder inhaler; EPR=Expert Panel Review (Guidelines for Diagnosis and Management of Asthma); FEV_1_=forced expiratory volume in one second; GP=general practitioner; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; m=month; MDI=metered dose inhaler; n=patient sample size; NR=not reported; PO=by mouth; PRN=pro re nata (i.e., as-needed); PEF=peak expiratory flow; QID=four times daily; RCT=randomized controlled trial; SABA=short-acting β_2_-agonist; SD=standard deviation; w=weeks; y=years

a Concurrent therapies during the trial in the self-adjusted arm included inhaled anticholinergics (5.4%), methylxanthines (16.1%) and nedocromil (3.6%). Concurrent therapies during the trial in the traditional treatment arm included inhaled anticholinergics (3.6%), methylxanthines (18.6%) and nedocromil (3.4%)

b First and second set of values represent budesonide and beclomethasone, respectively

c LABA and theophylline use during the trial in the budesonide 100μg BID + additional use arm were 37.3% and 11.9%, respectively. LABA and theophylline use during the trial in the budesonide 100μg BID + placebo arm were 49.3% and 26.9%, respectively, and in the 400μg BID + placebo arm were 41.8% and 13.4%, respectively

d Data reported as mean (range)

e Theophylline use in the doubled dose and maintenance dose arms were 0% and 3.8%, respectively

f MinDoc programmed with alert asthma symptom score (three ordinal values above the mean baseline total symptom score on 2 consecutive days) and alerted the patient in the event of an asthma exacerbation. Patient reported exacerbation to study personnel and given instructions to take additional inhaler

g LABA use in the quadrupled dose and maintenance dose arms were 38% and 39%, respectively

h Inhaled corticosteroid and leukotriene receptor inhibitor/antagonist use in the previous year in the rescue arm was 72% and 20%, respectively. Previous year use of inhaled ICS and leukotriene receptor inhibitor/antagonist in the combined arm were 76% and 16%, respectively, and in the daily arm were 82% and 10%

Table C-6 Study and population characteristics for KQ1b, intermittent ICS vs. ICS controller

Study, Year, N, Acronym, Study design, Duration Risk of Bias | Study population | Intervention Comparisons | Age (y) [mean, (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Boushey, 2005^51^ IMPACT n=149 RCT, 52w Low | 18–65 years of age w/mild persistent asthma (self-treatment with β_2_-agonist>2d per week, nighttime awakenings related to asthma >2d per month, or variability in the PEF of 20–30%). All patients self-adjusted according to action plan^a^- Green zone: Continue as usual, albuterol PRN Yellow zone: Start budesonide 800μg BID x10d Red zone: Start prednisone 0.5mg/kg PO x5d Extra red zone: albuterol, prednisone and go to ER or call 911 | Placebo inhaler BID + placebo tablets BID n=76 | 32.0 (10.5) | 43 | 19.5 (11.8) | 3.2 (0.7) | 87.8 (12.7) | NR | NR
Boushey, 2005^51^ IMPACT n=149 RCT, 52w Low | | Budesonide 200μg BID (DPI)+ placebo tablets BID n=73 | 33.2 (9.5) | 38 | 17.1 (11.0) | 3.2 (0.8) | 90.5 (12.6) | NR | NR
Papi, 2007^63^ BEST-adult n=337 RCT, 6m Low | 18–65 years old with mild persistent asthma according to EPR2 for at least 6m, adequately controlled at the end of run-in on beclomethasone 250μg BID. No written action plan, orally instructed to use PRN inhaler for symptom relief. | Placebo inhaler BID + Beclomethasone/albuterol 250/100μg PRN n=122 | 36.8 (13.1) | 41.0 | NR | 3.0 (0.8) | 88.5 (11.3) | 0.4 (0.7) | 18,480 (25250)^b^
Papi, 2007^63^ BEST-adult n=337 RCT, 6m Low | | Beclomethasone/albuterol 250/100μg BID + albuterol 100μg PRN n=109 | 39.9 (14.4) | 39.4 | NR | 2.9 (0.7) | 87.2 (10.7) | 0.5 (0.7) | 77,070 (17550)^b^
Papi, 2007^63^ BEST-adult n=337 RCT, 6m Low | | Beclomethasone 250μg BID + albuterol 100μg PRN n=106 | 37.9 (13.5) | 42.5 | NR | 3.0 (0.7) | 88.8 (11.1) | 0.4 (0.7) | 76,970 (17350)^b^
Turpeinen, 2007^64^ HELSINKI n=116 RCT, 18m Low | 5–10 years old with symptoms such as wheezing, prolonged cough or SOB suggesting asthma for at least 1m. According to symptoms and lung function majority of children could be categorized as mild persistent asthma. All patients received terbutaline PRN and physician determined replacement of study medication with budesonide 400μg BID x2w during exacerbations.^c^ | Budesonide 400μg BID x1m, 200μg BID x5m, placebo x12m n=58 | 6.7 (5–10)^d^ | 66 | 11.3 (2.0 to 76.4)^d,e^ | 1.32 (0.72 to 2.36)^d^ | 82 (52–107)^d^ | 0.55 (0–3.7)^d^ | NR
Turpeinen, 2007^64^ HELSINKI n=116 RCT, 18m Low | | Budesonide 400μg BID x1m, 200μg BID x5m, 100μg BID x12m n=58 | 7.0 (5 to 10)^d^ | 59 | 12.8 (1.1 to 70.5)^d,e^ | 1.43 (0.89 to 2.15)^d^ | 87 (57–111)^d^ | 0.47 (0–4.0)^d^ | NR
Martinez, 2011^60^ TREXA n=143 RCT, 44w Low | 6–18y of age w/history of mild persistent asthma during prior 2y, qualifying for interruption or discontinuation of controller therapy because illness was well controlled per EPR, asthma remained controlled during run-in on beclomethasone 40μg BID; either naïve to controller therapy with 1–2 exacerbations in prior year, treated in prior 8w on monotherapy other than ICS, or if illness was controlled for prior 8w on low-dose ICS monotherapy (≤160μg/d beclomethasone equivalent).^f^ All patients used PRN inhalers every time they would have used albuterol for symptom relief or to treat decreased in PEF, number of puffs was self-determined. All patients received prednisone x4d for asthma exacerbation | Placebo inhaler BID with PRN use of beclomethasone 40μg (MDI) + albuterol 90μg (MDI) n=71 | 10.4 (2.8) | 52 | NR | NR | 101.4 (12.1) | NR | NR
Martinez, 2011^60^ TREXA n=143 RCT, 44w Low | | Beclomethasone 40 μg BID (MDI) with PRN use of placebo inhaler + albuterol 90μg (MDI) n=72 | 10.8 (3.5) | 58 | NR | NR | 100.1 (10.8) | NR | NR
Calhoun, 2012^52^ BASALT n=227 RCT, 9m Low | ≥18y and older with mild to moderate asthma, need for daily controller therapy based on receiving prescription in prior 12m or symptoms more than twice/w and not on controller, if on ICS ≤1000μg fluticasone or equivalent stable for at least 2w, completely controlled asthma during run-in on beclomethasone 80μg BID, based on asthma evaluation questionnaire and FEV>70% predicted. All patients received unrestricted albuterol (MDI). Investigators were allowed to add open-label budesonide 80μg BID x14d if needed. | Budesonide 40μg (MDI) used on a puff-per-puff basis every time the patient uses albuterol (MDI) n=113 | 36.0 (12.2) | 26.5 | 21.3 (12.1) | 2.90 (0.69) | 85.6 (11.0) | 0 (0–0.31)^g^ | 832 (NR)^h^
Calhoun, 2012^52^ BASALT n=227 RCT, 9m Low | | Budesonide 80μg BID (MDI) adjusted by physician every 6w based on NHLBI guidelines n=114 | 34.2 (11.9) | 36.8 | 20.4 (10.4) | 3.03 (0.72) | 87.7 (12.1) | 0.04 (0–0.29)^g^ | 1610 (NR)^h^

Abbreviations: BID=twice daily; d=day; DPI=dry powder inhaler; EPR=Expert Panel Review (Guidelines for Diagnosis and Management of Asthma); ER=emergency room; FEV_1_=forced expiratory volume in one second; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; m=months; MDI=metered dose inhaler; n=patient sample size; NHLBI=National Heart, Lung and Blood Institute; NR=not reported; PO=by mouth; PRN=pro re nata (i.e., as-needed); PEF=peak expiratory flow; QID=four times daily; RCT=randomized controlled trial; SD=standard deviation; SOB=shortness of breath; w=weeks; y=years

a Green zone: symptoms and albuterol use stable; Yellow zone: Awakening from asthma 3+ times in a 2-week period or on 2 consecutive nights, or using albuterol for relief of symptoms 4+ times/day for 2 or more consecutive days, or albuterol has been relieving symptoms for less than 4h each treatment over a 12-hour period, or using albuterol for relief of symptoms daily for 7 days, and this use exceeds 2 times the weekly use of albuterol in the baseline period, or exercise induces unusual breathlessness; Red zone: For the previous 24 hours, daily life activities cause SOB or breathlessness is present at rest, or albuterol has been relieving symptoms for <2h after each treatment over an 8h period; Extra red zone: Severe SOB at rest, or difficulty talking because of SOB, or albuterol has been relieving symptoms for less than 1h after each treatment over a 4h period, or does not relieve symptoms after 2 treatments repeated within a single hour

b Cumulative doses of beclomethasone inhaled during the entire 6-month treatment period

c Exacerbations defined as an increase in symptoms not controlled by 6 doses/24h of terbutaline that caused the parent to contact the clinic

d Data reported as mean (range)

e Data reported in months

f Inhaled ICS and leukotriene receptor inhibitor/antagonist use in the previous year in the rescue arm was 72% and 20%, respectively. Previous year use of inhaled corticosteroids and leukotriene receptor inhibitor/antagonist in the combined arm were 76% and 16%, respectively, and in the daily arm were 82% and 10%

g Data reported as median (interquartile range)

h Represents mean monthly dose

Table C-7 Study level outcomes for KQ1b, intermittent ICS and ICS controller vs. ICS controller

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma control | Quality of life | Healthcare utilization
Lahdensuo, 1996^67^ n=115 RCT, 12m | Age: 12y+ Severity/control: Mild to moderately severe asthma Intermittent ICS: Doubling regular dose | Relative measures Requiring oral corticosteroid: RR 0.51 (0.29 to 0.88) Exacerbation (undefined): RR 0.48 (0.33 to 0.71) Asthma-related hospitalization: RR 0.70 (0.12 to 4.05) Unscheduled outpatient visit: RR 0.53 (0.29 to 0.96) Count data Number of hospitalizations: 2 vs. 3 | NR | Composite measures: NR Spirometry: NR | NR | NR
Foresi, 2000^56^ n=134 RCT, 6m | Age: 12y+ Severity/control: Moderate persistent asthma/symptomatic Intermittent ICS: Quadrupling regular dose | Relative measures Fall in PEF <70% from baseline: RR 1.09 (0.52 to 2.30) Count data Total number of oral corticosteroid days: 37 vs. 47 | NR | Composite measures: NR Spirometry: NR | NR | NR
Colland, 2004^54^ n=29 RCT, 12m | Age: 5–11y Severity/control: Moderate persistent asthma/symptomatic Intermittent ICS: Doubling regular dose | Relative measures Requiring hospitalization: Peto’s OR 0.14 (0.003 to 7.31) Count data NR | NR | Composite measures: NR Spirometry: FEV1 % predicted: MD 5 (-6.01 to 16.01) | NR | NR
Fitzgerald, 2004^55^ n=98 RCT, 6m | Age: 12y+ Severity/control: Persistent asthma Intermittent ICS: Doubling regular dose | Relative measures Requiring oral corticosteroid (of those who initiated study inhaler) RR: 0.85 (0.39 to 1.83) Requiring oral corticosteroid, unscheduled doctors visit, ER, or unstable asthma: RR 1.03 (0.63 to 1.65) Unstable asthma^c^: RR 0.57 (0.23 to 1.38) Count data NR | NR | Composite measures: NR Spirometry: NR | NR | NR
Harrison, 2004^59^ n=390 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma/stable during run-in Intermittent ICS: Doubling regular dose | Relative measures Requiring oral corticosteroid (full population): RR 0.95 (0.55 to 1.63) Requiring oral corticosteroid (of those who initiated study inhaler) RR: 0.76 (0.44 to 1.32) Count data NR | NR | Composite measures: NR Spirometry: NR | NR | Asthma-related general practitioner visits: RR 1.14 (0.71 to 1.83)
Oborne, 2009^66^ n=403 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma Intermittent ICS: Quadrupling regular dose | Relative measures Requiring oral corticosteroid (full population): RR 0.64 (0.37 to 1.11) Requiring oral corticosteroid (of those who initiated study inhaler) RR: 0.43 (0.24 to 0.78) 2 to 3 exacerbations requiring oral corticosteroid (full population): RR 0.63 (0.15 to 2.59) 2 to 3 exacerbations requiring oral corticosteroid (of those who initiated study inhaler): RR 0.34 (0.07 to 1.76) Count data NR | NR | Composite measures: NR Spirometry: NR | NR | NR
Martinez, 2011^60^ n=143 RCT, 12m | Age: Mixed, (5–11y and 12y+) Severity/control: Mild persistent asthma/well controlled Intermittent ICS: ICS used with albuterol | Relative measures Requiring oral corticosteroid: RR 1.12 (0.67 to 1.86) Treatment failure^d^: RR 2.03 (0.39 to 10.72) | NR | Composite measures: NR Spirometry: FEV1 % predicted: MD 0.57 (−2.24 to 3.38) | PAQLQ score: MD −0.003 (−0.25 to 0.25) | Albuterol puffs/day: MD 0.04 (−0.33 to 0.40)

Abbreviations: d=days; ER=emergency room; EPR-3=Expert Panel Review-3; FEV1=forced expiratory volume in one second; HR=hazard ratio; ICS=inhaled corticosteroid; IRR= incident rate ratio; m=months; MD=mean difference; n=patient sample size; NR=not reported; OR=odds ratio; PAQLQ=Pediatric Asthma Quality of Life Questionnaire; RCT=randomized controlled trial; RR=relative risk; y=year

a Categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. Intermittent ICS indicates how the usual ICS dose was altered in the intervention arm

b Relative measures are presented first and include, when reported by the study RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations.

c Defined as the absence of stability, where stability is defined as morning peak expiratory flow 90% or more of mean baseline value on either of the two previous days, <4 inhalations of inhaled corticosteroid per day over the past 2 days, no nocturnal awakenings in the prior 2 nights and a total symptom score not exceeding mean baseline value more than 2 ordinal values over the previous 2 days

d Defined as any of following: (1) Hospitalization due to asthma; (2) Hypoxic seizure due to asthma; (3) Intubation due to asthma; (4) Requirement for a second burst of prednisone within any 6 months period; (5) Significant adverse event related to the use of a study medication. The only criterion for assignment of treatment failure during the trial was the requirement for a second burst of prednisone within any six-month period

Table C-8 Study level outcomes for KQ1b, intermittent ICS vs. ICS controller

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma Control | Quality of Life | Healthcare Utilization
Boushey, 2005^51^ n=149 RCT, 52w | Age: 12y+ Severity/control: Mild persistent Intermittent ICS: Yellow zone budesonide 800μg BIDx10d | Requiring oral corticosteroid: RR 0.70 (0.30 to 1.64) Requiring hospitalization: No events occurred | NR | Composite measures: ACQ-7 score: MD 0.1 (−0.12 to 0.32) Spirometry: FEV1 pre-albuterol (% change): MD −3.3 (−6.51 to −0.09) FEV1 post-albuterol (% change): MD −0.7 (−2.1 to 0.7) | AQLQ(S) score: MD −0.2 (−0.48 to 0.08) | NR
Papi, 2007^63^ n=337 RCT, 6m | Age: 12y+ Severity/control: Mild persistent asthma/controlled Intermittent ICS: Beclomethasone/albuterol 250/100μg PRN symptom relief | Mild^c^ or severe^d^ exacerbation: RR 0.87 (0.29 to 2.61) Severe exacerbation: Peto’s OR 0.11 (0.01 to 1.11) | NR | Composite measures: NR Spirometry: FEV1, trough MD 0.09 (−0.01 to 0.18) FEV1 % predicted: MD 2.04 (−0.71 to 4.79) FVC, trough MD 0.07 (−0.03 to 0.18) FVC % predicted MD 1.72 (−1.04 to 4.48) | NR | Rescue albuterol use, inhalations/d MD 0.07 (−0.13 to 0.26)
Turpeinen, 2007^64^ n=116 RCT, 18m | Age: 5–11y Severity/control: Majority mild persistent/symptomatic Intermittent ICS: Budesonide 400mg BIDx14d upon symptoms determined by pediatrician to be exacerbation | Exacerbation rate^e^: MD −0.72 (−1.27 to −0.17) | NR | NR | NR | NR
Martinez, 2011^60^ n=143 RCT, 44w | Age: Mixed (5–11, 12y+) Severity/control: Mild persistent/ well controlled Intermittent ICS: Beclomethasone 40μg+albuterol 90μg PRN symptom relief prompting albuterol use or to treat decrease PEF | Requiring oral corticosteroid: RR 1.27 (0.78 to 2.07) Treatment failure^f^: RR 3.04 (0.64 to 14.57) | NR | Composite measures: NR Spirometry: FEV1 % predicted: MD −1.30 (−4.24 to 1.64) | PAQLQ score: MD 0.04 (−0.25 to 0.33) | Rescue albuterol use, inhalations/d: MD 0.003 (−0.24 to 0.25)
Calhoun, 2012^52,g^ n=227 RCT, 9m | Age: 12y+ Severity/control: Mild to moderate persistent/well or partially well controlled Intermittent ICS: Beclomethasone 80μg PRN symptom relief prompting albuterol use | Exacerbation^h^: IRR 2.0 (0.87 to 4.61) Urgent care visit for asthma: RR 0.25 (0.05 to 1.16) Treatment failure^i^: HR 1.6 (0.86 to 2.98) IRR 1.7 (0.96 to 3.00) | NR | Composite measures: ACQ−5 MD −0.01 (−0.17 to 0.15) Spirometry: FEV1 trough pre albuterol: MD 0.01 (−0.13 to 0.15) FEV1 trough post albuterol: MD −0.01 (−0.06 to 0.04) FEV1 % predicted pre albuterol: MD 0.01 (−1.89 to 1.91) FEV1 % predicted post albuterol: MD −0.48 (−1.97 to 1.01) | AQLQ(S) score: MD 0.01 (−0.19 to 0.21) | Rescue albuterol use, inhalations/d: MD −0.04 (−0.11 to 0.03)

Abbreviations: ACQ=Asthma Control Questionnaire; AQLQ=Asthma Quality of Life Questionnaire; AQLQ(S)=Standardized Asthma Quality of Life Questionnaire; BID=twice daily; d=days; ER=emergency room; FEV1=forced expiratory volume in one second; FVC=forced vital capacity; HR=hazard ratio; ICS=inhaled corticosteroid; IRR= incident rate ratio; m=months; MD=mean difference; mg=milligrams; n=patient sample size; NR=not reported; OR=odds ratio; PAQLQ=Pediatric Asthma Quality of Life Questionnaire; PEF=peak expiratory flow; PRN=pro re nata (i.e., as-needed); RCT=randomized controlled trial; RR=relative risk; μg=micrograms; w=weeks; y=year

a Age is categorized using study inclusion criteria and the age categories used in Expert Panel Review-3 (EPR-3) of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. Intermittent ICS indicates how the usual ICS dose was altered in the intervention arm

b Relative measures are presented first and include, when reported by the study, relative risk (RR), hazard ratio (HR) for time to the event, and incident rate ratio (IRR) for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations

c Defined as awakening at night owing to asthma or as a decrease in the morning peak expiratory flow rate to more than 20% below the baseline value, the use of more than three additional puffs per day of rescue medication (either albuterol or beclomethasone and albuterol) as compared with during the baseline for 2 or more consecutive days, or both. Single, isolated days on which mild exacerbation occurred were not counted

d Defined as a decrease in the morning peak expiratory flow rate to more than 30% below the baseline value on 2 consecutive days or more than eight puffs per day of rescue medication for 3 consecutive days or the need for treatment with oral corticosteroids, as judged by the investigator

e Defined as the mean number of exacerbations divided by the number of patients in the group. An asthma exacerbation was defined as an increase in symptoms that were not controlled with six doses of rescue terbutaline per 24 h that caused the parent to contact the clinic. At clinic pediatrician determined if exacerbation occurred and prescribed budesonide inhaler

f Defined as any of following: (1) Hospitalization due to asthma; (2) Hypoxic seizure due to asthma; (3) Intubation due to asthma; (4) Requirement for a second burst of prednisone within any 6 months period; (5) Significant adverse event related to the use of a study medication. The only criterion for assignment of treatment failure during the trial was the requirement for a second burst of prednisone within any six-month period

g Study reported 97.5% confidence intervals which were converted to 95% confidence intervals

h Defined as unscheduled medical contact for increased asthma symptoms that results in use of oral corticosteroids, increased inhaled corticosteroids, or additional medications for asthma

i Defined as any of the following: (1) Asthma exacerbation; (2) An at-home measurement of prebronchodilator AM PEF <65% of baseline on 2 consecutive mornings, postbronchodilator PEF <80% of baseline despite 60 minutes of rescue treatment, or an increase in albuterol use of more than 8 puffs per 24 hours over baseline use for 48 hours or more than 16 puffs per 24 hours for more than 48 hours; (3) In-clinic measurements of prebronchodilator FEV1 on 2 consecutive sets of spirometric determinations measured 24 to 72 hours apart that are less than 80% of baseline, physician judgement for patient safety, patient dissatisfaction with asthma control achieved by study regimen or requirement for open-label ICS or another new asthma medication without the addition of systemic corticosteroids

Table C-9 Study and population characteristics for KQ1c, ICS and LABA controller and quick relief vs. ICS controller (same dose)

Study, Year, n, Acronym, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Scicchitano, 2004^96^ n=1890 RCT, 12m Low | 12–80 years of age with moderate to severe (83% with severe according to GINA guidelines), symptomatic asthma on ICS 400–1600μg/d, FEV1 50–90% predicted, history of at least 1 exacerbation in prior year ICS dose at entry: 744–748μg/d Taking LABA at entry: 35% | Budesonide/formoterol 320/9μg in the evening + 160/4.5μg PRN (DPI) n=947 | 43 (12 to 79)^a^ | 41 | 12 (1 to 65)^a^ | NR | 70 (46 to 102)^a^ | 1.9 (0 to 15.6)^a^ | 466 (NR)
Scicchitano, 2004^96^ n=1890 RCT, 12m Low | | Budesonide 160μg BID (DPI) + terbutaline PRN (DPI) n=943 | 43 (11 to 80)^a^ | 43 | 12 (1 to 71)^a^ | NR | 70 (37 to 95)^a^ | 2.0 (0 to 9.2)^a^ | 640 (NR)
Rabe, 2006^94^ n=697 RCT, 6m Low | 12–80 years of age with mild to moderate asthma on ICS 200–500μg/d, FEV1 60–100% predicted, symptomatic with ≥7 SABA inhalations during last 10 run-in days ICS dose at entry: 343–353μg/d LABA at entry: 10–13% | Budesonide/formoterol 160/9μg in the evening + 80/4.5mcg PRN (DPI) n=355 | 38 (12 to 79)^a^ | 41 | 10 (1 to 70)^b^ | NR | 75 (51 to 123)^a^ | NR | 240 (NR)
Rabe, 2006^94^ n=697 RCT, 6m Low | | Budesonide 160μg in the evening (DPI) + terbutaline PRN (DPI) n=342 | 38 (11 to 78)^a^ | 36 | 10 (1 to 61)^b^ | NR | 75 (52 to 109)^a^ | NR | 320 (NR)
Sovani, 2008^99^ n=71 RCT, 6m High | 18–70 years of age with asthma on ICS 400–1000μg/d of beclomethasone or equivalent, with evidence of poor asthma control (in prior year ≥2 courses of prednisolone or 10 SABA canisters, and taking ≥4 SABA puffs in ≥4d/week in prior month ICS dose at entry:565–611μg/d | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=36 | 40.3 (12.8) | 47.2 | 23.1 (12) | 2.9 (0.84) | 88.1 (19.3) | NR | 448 (NR)
Sovani, 2008^99^ n=71 RCT, 6m High | | Budesonide 160μg BID (DPI) + SABA PRN n=35 | 40.3 (12.3) | 42.9 | 22.6 (14) | 2.65 (0.82) | 82.3 (18.7) | NR | 252 (NR)

Abbreviations: BID=twice daily; d=day; DPI=dry powder inhaler; FEV_1_=forced expiratory volume in one second; GINA= Global Initiative for Asthma; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; m=months; n=patient sample size; NR=not reported; PRN=pro re nata (i.e., as-needed); RCT=randomized controlled trial; SABA=short-acting β_2_-agonist; SD=standard deviation; μg=microgram; w=week; y=year

a Data reported as mean (range)

b Data reported as median (range)

Table C-10 Study and population characteristics for KQ1c, ICS and LABA controller and quick relief vs. ICS controller (higher dose)

Study, Year, n, Acronym, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
O’Byrne, 2005^83^ n=1851 STAY RCT, 12m Low | 4–80 years of age with asthma treated with 400–1000μg/d of ICS (200–500μg/d if 4–11 years old), history of 1 or more exacerbation in prior year, FEV1 60–100% predicted, 12+ (8+ if 4–11y) SABA inhalations during last 10d of run-in. ICS dose at entry: 598–620μg/d Taking LABA at entry: 27–29% | Budesonide/formoterol 80/4.5μg BID + PRN (DPI) n=925 | 35 (4 to 77)^a^ | 45.5 | 9 (0 to 63)^b^ | 2.13 (0.65 to 4.28)^a^ | 73 (43 to 108)^a^ | 1.74 (0 to 8.0)^a,c^ | 235.5 (NR)^d^
O’Byrne, 2005^83^ n=1851 STAY RCT, 12m Low | | Budesonide 320μg BID (DPI) + terbutaline 0.4mg PRN (DPI) n=926 | 36 (4 to 79)^a^ | 44.9 | 9 (0 to 96)^b^ | 2.14 (0.64 to 4.02)^a^ | 73 (49 to 100)^a^ | 1.69 (0 to 7)^a,c^ | 641.5 (NR)^d^
O’Byrne, 2005^83^ n=1851 STAY RCT, 12m Low | 4–11 year old subgroup with asthma treated with 200–500μg/d of ICS, history of 1 or more exacerbation in prior year, FEV1 60–100% predicted, 8+ SABA inhalations during last 10d of run-in. ICS dose at entry:319–321μg/d | Budesonide/formoterol 80/4.5μg QD + PRN (DPI) n=118 | 8 (4 to 11)^a^ | 72.0 | 3 (1 to 10)^b^ | 1.6 (0.9 to 2.7)^a^ | 76 (57 to 108)^a^ | 1.7 (0.7 to 5.9)^a^ | 125.6 (NR)
O’Byrne, 2005^83^ n=1851 STAY RCT, 12m Low | | Budesonide 320μg QD (DPI) + terbutaline 0.4mg PRN (DPI) n=106 | 8 (4 to 11)^a^ | 66.4 | 3 (0 to 10)^b^ | 1.6 (0.7 to 3.1)^a^ | 76 (60 to 100)^a^ | 1.6 (0.1 to 4.0)^a^ | 320.1 (NR)

Abbreviations: BID=twice daily; d=day; DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; m=months; n=patient sample size; NR=not reported; PRN=pro re nata (i.e., as-needed); QD=daily; RCT=randomized controlled trial; SABA=short-acting β_2_-agonist; SD=standard deviation; μg=microgram; y=years

a Data reported as mean (range)

b Data reported as median (range)

c Represents inhalations/d (vs. night)

d Represents patients 12y+

Table C-11 Study and population characteristics for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (same dose)

Study, Year, n, Acronym, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
O’Byrne, 2005^75,83^, STAY n=1834 RCT, 12m Low | 4–80 years of age with asthma treated with 400–1000μg/d of ICS (200–500μg/d if 4–11 years old), history of 1 or more exacerbation in prior year, FEV1 60–100% predicted, 12+ (8+ if 4–11y) SABA inhalations during last 10d of run-in ICS dose at entry: 598–620μg/d Taking LABA at entry: 27–29% | Budesonide/formoterol 80/4.5μg BID + PRN (DPI) n=925 | 35 (4 to 77)^a^ | 45.5 | 9 (0 to 63)^b^ | 2.13 (0.65 to 4.28)^a^ | 73 (43 to 108)^a^ | 1.74 (0 to 8.0)^a,c^ | 235.5 (NR)^d^
O’Byrne, 2005^75,83^, STAY n=1834 RCT, 12m Low | | Budesonide/formoterol 80/4.5μg BID (DPI) + terbutaline 0.4mg PRN (DPI) n=909 | 36 (4 to 79)^a^ | 43.3 | 9 (0 to 65)^b^ | 2.10 (0.62 to 4.50)^a^ | 73 (46 to 108)^a^ | 1.69 (0 to 9.4)^a,c^ | 165.5 (NR)^d^
O’Byrne, 2005^75,83^, STAY n=1834 RCT, 12m Low | 4–11 year old subgroup with asthma treated with 200–500μg/d of ICS, history of 1 or more exacerbation in prior year, FEV1 60–100% predicted, 8+ SABA inhalations during last 10d of run-in ICS dose at entry: 302–319μg/d | Budesonide/formoterol 80/4.5μg QD + PRN (DPI) n=118 | 8 (4 to 11)^a^ | 72.0 | 3 (1 to 10)^b^ | 1.6 (0.9 to 2.7)^a^ | 76 (57 to 108)^a^ | 1.7 (0.7 to 5.9)^a^ | 125.6 (NR)
O’Byrne, 2005^75,83^, STAY n=1834 RCT, 12m Low | | Budesonide/formoterol 80/4.5μg QD (DPI) + terbutaline 0.4mg PRN (DPI) n=117 | 8 (4 to 11)^a^ | 70.1 | 3 (0 to 11)^b^ | 1.5 (0.7 to 2.9)^a^ | 76 (54 to 99)^a^ | 1.6 (0.3 to 5.6)^a^ | 81.8 (NR)
Vogelmeier, 2005^104^ COSMOS n=2143 RCT, 12m Medium | ≥12 years of age with asthma, taking ≥500μg/d of budesonide or fluticasone (or ≥1000μg/d for other ICS), FEV1 40–90% predicted, at least 1 severe exacerbation in prior year, rescue medication use ≥4 of 7 days in run-in ICS dose at entry: 881–888μg/d LABA use at entry: 38% Doses of randomized therapies could be titrated and additional controllers added during trial if needed^f^ | Budesonide/formoterol 320/9μg BID + 160/4.5μg/d PRN (DPI) n=1067 | 45 (12 to 80)^a^ | 42.3 | 13 (1to 75)^a^ | NR | 73 (39 to 115)^a^ | 2.6 (0.2 to 10.7)^a^ | 1019 (NR)^e^
Vogelmeier, 2005^104^ COSMOS n=2143 RCT, 12m Medium | | Fluticasone/salmeterol 250/50μg BID (DPI) + salbutamol PRN (DPI/MDI) n=1076 | 45 (12 to 84)^a^ | 39.9 | 12 (0 to 74)^a^ | NR | 73 (28 to 100)^a^ | 2.7 (0.3 to 33.7)^a^ | 1166 (NR)^e^
Rabe, 2006^93^ n=3394 RCT, 12m Low | ≥12 years of age with asthma on ICS, FEV1 50–100% predicted, at least 1 severe asthma exacerbation in prior year, symptomatic during run-in ICs dose at entry: 751–758μg/d LABA use at entry: 59% | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=1113 | 42 (12 to 89)^a^ | 39 | 9 (0 to 64)^b^ | 2.21 (0.61 to 4.68)^a^ | 72 (30 to 110)^a^ | 1.8 (0 to 8.9)^a^ | NR
Rabe, 2006^93^ n=3394 RCT, 12m Low | ≥12 years of age with asthma on ICS, FEV1 50–100% predicted, at least 1 severe asthma exacerbation in prior year, symptomatic during run-in ICs dose at entry: 751–758μg/d LABA use at entry: 59% | Budesonide/formoterol 160/4.5μg BID (DPI) + formoterol 4.5μg (DPI) PRN n=1140 | 42 (12 to 81)^a^ | 40 | 10 (1 to 77)^b^ | 2.20 (0.74 to 4.58)^a^ | 72 (38 to 115)^a^ | 1.9 (0 to 9.1)^a^ | NR
Rabe, 2006^93^ n=3394 RCT, 12m Low | ≥12 years of age with asthma on ICS, FEV1 50–100% predicted, at least 1 severe asthma exacerbation in prior year, symptomatic during run-in ICs dose at entry: 751–758μg/d LABA use at entry: 59% | Budesonide/formoterol 160/4.5μg BID (DPI) + terbutaline 0.4mg n=1141 | 43 (12 to 83)^a^ | 39 | 10 (1 to 69)^b^ | 2.16 (0.68 to 4.58)^a^ | 72 (39 to 100)^a^ | 1.9 (0.3 to 9.7)^a^ | NR
Atienza, 2013^70^ n=2091 RCT, 12m Low | ≥16 years of age with persistent asthma, FEV1≥50% predicted, not adequately controlled despite maintenance ICS, at least 1 exacerbation in prior year, SABA use ≥5 of last 7 run-in days ICs dose at entry:659–662μg/d LABA use at entry: 61–62% | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=1049 | 45.7 (14.5) | 31.2 | 12 (1 to 67)^b^ | 1.93 (0.64) | 70.18 (14.65) | 2.41 (1.55) | 514 (NR)
Atienza, 2013^70^ n=2091 RCT, 12m Low | | Budesonide/formoterol 160/4.5μg BID (DPI) + terbutaline 0.4mg PRN (DPI) n=1042 | 45.6 (14.5) | 33.6 | 12 (1 to 74)^b^ | 1.93 (0.65) | 69.64 (13.75) | 2.43 (1.58) | 320 (NR)
Papi, 2013^84^ n=1701 RCT, 48w Low | ≥18 years of age with asthma not fully controlled on ICS alone (≥1000μg/d beclomethasone equivalents) or ICS (≥500μg/d beclomethasone equivalents) +LABA, FEV1 ≥60% predicted, at least 1 severe exacerbation in prior year ICS dose at entry: 1128–1139 beclomethasone equivalents LABA use at entry: 79–83% | Beclomethasone/formoterol 84.6/5μg BID + PRN (MDI) n=852 | 49 (18 to 83)^a^ | 39 | 9 (0.5 to 62.0)^g^ | 2.21 (0.88 to 5.04)^a^ | 74 (29 to 127) | 0.98 (0.00 to 8.71) | 701 (293)^e^
Papi, 2013^84^ n=1701 RCT, 48w Low | | Beclomethasone/formoterol 84.6/5μg BID (MDI) + salbutamol 100μg PRN (MDI) n=849 | 47 (18 to 77)^a^ | 38 | 9 (0.5 to 61.0)^g^ | 2.27 (1.00–4.74)^a^ | 75 (50 to 127) | 0.97 (0.00 to 9.43) | 489 (48)^e^
Patel, 2013^86^ SMART n=303 RCT, 24w Medium | 16–65 years of age with asthma on ICS, at least 1 exacerbation requiring steroids in prior year ICS dose at entry: 804–812μg/d LABA use at entry: 61–68% | Budesonide/formoterol 320/9μg BID + PRN (MDI) n=151 | 41.3 (13.7) | 32 | 26.7 (14.5) | 2.62 (0.91)^h^ | 81.6 (18.9)^h^ | NR | 943.5 (1502.5)
Patel, 2013^86^ SMART n=303 RCT, 24w Medium | 16–65 years of age with asthma on ICS, at least 1 exacerbation requiring steroids in prior year ICS dose at entry: 804–812μg/d LABA use at entry: 61–68% | Budesonide/formoterol 320/9μg BID (MDI) + salbutamol 100–200μg PRN n=152 | 42.6 (14.5) | 30 | 26.2 (14.6) | 2.50 (0.78)^h^ | 80.4 (20.5)^h^ | NR | 684.3 (390.5)
Hozawa, 2014^78^ n=30 RCT, 8w Medium | ≥20 years of age with asthma not well controlled (ACQ>0.75) on medium dose ICS (budesonide 800μg/d, fluticasone or mometasone 400μg/d) without another controller, SABA use 2–6 times/w | Budesonide/formoterol 320/9μg BID + 160/4.5μg PRN (DPI) n=15 | 41.9 (8.7) | 33.3 | 6.9 (3.6) | NR | NR | NR | NR
Hozawa, 2014^78^ n=30 RCT, 8w Medium | ≥20 years of age with asthma not well controlled (ACQ>0.75) on medium dose ICS (budesonide 800μg/d, fluticasone or mometasone 400μg/d) without another controller, SABA use 2–6 times/w | Fluticasone/salmeterol 250/50μg BID (DPI) + procaterol 20μg PRN n=15 | 41.3 (9.9) | 33.3 | 6.7 (3.1) | NR | NR | NR | NR
Takeyma, 2014^101^ n=63 RCT, 1y Unclear | 16–80 years of age with moderate to severe persistent asthma, on ICS (budesonide 320–640μg/d or fluticasone 200–500μg/d) +LABA, at least 1 exacerbation in prior year, ACT score<20, reliever use ≥5 times per week, FEV1 60–100% predicted ICS dose at entry: 574–610μg/d | Budesonide/formoterol 320/9μg BID + 160/4.5μg PRN n=32 | 41 (NR) | 40.6 | NR | 1.86 (0.33) | 68.3 (8.7) | NR | NR
Takeyma, 2014^101^ n=63 RCT, 1y Unclear | | Budesonide/formoterol 320/9μg BID + salbutamol 100μg PRN n=31 | 39 (NR) | 32.3 | NR | 1.89 (0.40) | 70.4 (10.2) | NR | NR
Stallberg, 2008^100^ SHARE n=1343 RCT, 12m Medium | ≥12 years of age with persistent asthma on free combination ICS+LABA or symptomatic despite ICS alone, on ICS ≥400μg/d ICS dose at entry: 636–650μg/d LABA use at entry: 51–52% Randomized therapy stratified by baseline ICS dose^i^ | Budesonide/formoterol 160/9μg or 320/9μg QD + PRN OR 80/4.5μg or 160/4.5μg BID + PRN n=887 | 43 (NR) | 40 | NR | NR | NR | NR | 291 (NR)
Stallberg, 2008^100^ SHARE n=1343 RCT, 12m Medium | | Budesonide/formoterol 160/9μg or 320/9μg BID + terbutaline PRN n=456 | 45 (NR) | 44 | NR | NR | NR | NR | 368 (NR)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; BID=twice daily; CI=confidence interval; d=day; DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; m=month; MDI=metered dose inhaler; n=patient sample size; NR=not reported; PRN=pro re nata (i.e., as-needed); QD=daily; RCT=randomized controlled trial; SABA=short-acting β_2_-agonist; SD=standard deviation; μg=microgram; w=week; y=year

a Data reported as mean (range)

b Data reported as median (range)

c Represents inhalations/d (vs. night)

d Represents patients 12y+

e Beclomethasone dipropionate equivalent dose in μg

f In the control group (fluticasone/salmeterol BID + salbutamol PRN), 27% and 14% of patients completed the study on the maximum 1000/100μg/d dose and lowest dose of fluticasone/salmeterol, respectively

g Data reported as median (95% CI)

h Represents values on treatment

i Patients previously treated with ICS 400–500μg/d received budesonide/formoterol 80/4.5μg dose and those previously treated with ICS >500μg/d received budesonide/formoterol 160/4.5μg dose

Table C-12 Study and population characteristics for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (higher dose)

Study, Year, N, Acronym, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Bousquet, 2007^76^ AHEAD n=2309 RCT, 6m Low | ≥12 years of age with persistent asthma on ICS alone (800–1600μg/d) or ICS (400–1000μg/d) +LABA, symptomatic with use of SABA during run-in ≥5 of 7 days, FEV1≥50% predicted ICs dose at entry: 705–720μg/d LABA use at entry: 54–56% | Budesonide/formoterol 320/9μg BID + PRN (DPI) n=1154 | 40 (12 to 80)^a^ | 38 | 14 (1 to 67)^b^ | 2.08 (0.60 to 4.65)^a^ | 70.2 (45 to 114)^a^ | NR | 792 (NR), 1238 (NR)^c^
Bousquet, 2007^76^ AHEAD n=2309 RCT, 6m Low | | Fluticasone/salmeterol 500/50μg BID (DPI) + terbutaline 0.4mg PRN (DPI) n=1155 | 39 (12 to 80)^a^ | 38 | 13 (1 to 77)^b^ | 2.10 (0.72 to 4.89)^a^ | 71.0 (45 to 222)^a^ | NR | 1000 (NR), 2000 (NR)^c^
Kuna, 2007^81^ COMPASS n=3335 RCT, 6m Low | ≥12 years of age with asthma on ICS ≥500μg/d fluticasone or budesonide (or ≥1000μg/d of other ICS), FEV1 ≥50% predicted, at least 1 exacerbation in prior year, SABA used ≥5 of last 7 run-in days ICS dose at entry: 740–750μg/d LABA use at entry:46–47% | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=1107 | 38 (17) | 43 | NR | NR | 72 (14) | NR | 483 (NR), 755 (NR)^c^
Kuna, 2007^81^ COMPASS n=3335 RCT, 6m Low | | Budesonide/formoterol 320/9μg BID + terbutaline PRN (DPI) n=1105 | 38 (17) | 41 | NR | NR | 73 (14) | NR | 640 (NR), 1000 (NR)^c^
Kuna, 2007^81^ COMPASS n=3335 RCT, 6m Low | | Fluticasone/salmeterol 250/50 μg BID (MDI) + terbutaline PRN (DPI) n=1123 | 38 (17) | 43 | NR | NR | 73 (14) | NR | 500 (NR), 1000 (NR)^c^
Pavord, 2009^89^ n=127 RCT, 1yr Low | 18–65 years of age with asthma on ICS alone 800–1600μg/d or ICS 400–1000μg/d +LABA, FEV1≥60% predicted. SABA or symptoms ≥4 of last 7 run-in days with mean morning PEF 50–85% ICS dose at entry: 741–867μg/d LABA use at entry: 81–84% | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=64 | 39 (19 to 63)^a^ | 55 | 20 (1 to 62)^b^ | 2.9 (1.2 to 4.7)^a^ | 81.4 (58 to 121)^a^ | 1.5 (0–6.0)^a^ | NR
Pavord, 2009^89^ n=127 RCT, 1yr Low | | Budesonide/formoterol 320/9μg BID (MDI) + budesonide 400μg BID (DPI) + terbutaline 0.5mg PRN (DPI) n=63 | 41 (20–65)^a^ | 54 | 21 (1 to 54)^b^ | 2.8 (1.4 to 4.3)^a^ | 80.6 (60 to 110)^a^ | 1.2 (0 to 7.4)^a^ | NR
Lundborg, 2006^115^ N=491 RCT, 26w Medium | ≥6 years of age with asthma not well controlled on ICS alone (25–36%) or well controlled on ICS+LABA (64–75%), treated with ICS 500–1200μg/d (250–600μg/d for 6–11y), FEV1 ≥60% predicted ICS dose at entry: 4–11y 419–435μg/d; 12y+ 708–721μg/d; Allowed to continue disodium cromoglycate and montelukast at stable pre-study dose^e^ | Budesonide/formoterol 160/4.5μg QD + PRN (DPI) (80/4.5μg/d used for 4–11y) n=162 | 39.7 (19.6) | 43 | NR | 3.0 (0.9)^d^ | 95.7 (13.7)^d^ | NR | 339.0 (NR)^f^, 129.0 (NR)^g^
Lundborg, 2006^115^ N=491 RCT, 26w Medium | | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) (80/4.5μg/d used for 4–11y) n=165 | 38.2 (20.6) | 49 | NR | 3.0 (0.9) | 96.2 (14.7) | NR | 405.2 (NR)^f^, 194.1 (NR)^g^
Lundborg, 2006^115^ N=491 RCT, 26w Medium | | Budesonide/formoterol 320/9μg BID + formoterol 4.5μg PRN n=164 | 40.8 (19.9) | 49 | NR | 3.0 (0.9) | 96.5 (15.2) | NR | 637.5 (NR)/325.8 (NR)
Stallberg, 2008^100^ SHARE N=1343 RCT, 12m Medium | ≥12 years of age with persistent asthma on free combination ICS+LABA or symptomatic despite ICS alone, on ICS ≥400μg/d ICS dose at entry: 636–650μg/d LABA use at entry: 51–52% Randomized therapy stratified by baseline ICS dose^h^ | Budesonide/formoterol 160/9μg or 320/9μg QD + PRN OR 80/4.5μg or 160/4.5μg BID + PRN n=887 | 43 (NR) | 40 | NR | NR | NR | NR | 291 (NR)
Stallberg, 2008^100^ SHARE N=1343 RCT, 12m Medium | | Budesonide/formoterol 160/9μg or 320/9μg BID + terbutaline PRN n=456 | 45 (NR) | 44 | NR | NR | NR | NR | 368 (NR)

Abbreviations: BID=twice daily; d=day; DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; m=month; MDI-metered dose inhaler; n=patient sample size; NR=not reported; PEF=peak expiratory flow; PRN=pro re nata (i.e., as-needed); QD=daily; RCT=randomized controlled trial; SABA=short-acting β_2_-agonist; SD=standard deviation; μg=microgram; w=week; y=year

a Data reported as mean (range)

b Data reported as median (range)

c Beclomethasone dipropionate equivalent dose in μg

d Represents values post-bronchodilator

e Percentage of patients continued on concurrent disodium cromoglycate and montelukast not reported

f Represents values from adults (≥12y)

g Represents values from children (6–11y)

h Patients previously treated with ICS 400–500μg/d received budesonide/formoterol 80/4.5μg dose and those previously treated with ICS >500μg/d received budesonide/formoterol 160/4.5μg dose

Table C-13 Study and population characteristics for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (lower dose)

Study, Year, N, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Hozawa, 2016^117^ n=30 RCT, 4w Medium | ≥20 years of age with persistent asthma on ICS alone (BUD 800mcg/d, FP or MF 400mg/d), symptomatic with use of SABA 2 to 6 times/w and ACQ≥1.5 ICS dose at entry: 705–720μg/d | Budesonide/formoterol 320/9μg BID + PRN (DPI) n=15 | 41.7 (5.9) | 46.7 | 8.7 (3.2) | NR | 88.5 (5.6) | NR | 688.8mcg (NR)
Hozawa, 2016^117^ n=30 RCT, 4w Medium | ≥20 years of age with persistent asthma on ICS alone (BUD 800mcg/d, FP or MF 400mg/d), symptomatic with use of SABA 2 to 6 times/w and ACQ≥1.5 ICS dose at entry: 705–720μg/d | Fluticasone/vilanterol 100/25μg QD (DPI) + procaterol 20mcg PRN n=15 | 40.4 (7.6) | 40.0 | 8.0 (2.7) | NR | 90.2 (6.4) | NR | NR

Abbreviations: BID=twice daily; d=day; DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; ICS=inhaled corticosteroid; L=liter; n=patient sample size; NR=not reported; PRN=pro re nata (i.e., as-needed); QD=daily; RCT=randomized controlled trial; SABA=short-acting β_2_-agonist; SD=standard deviation; μg=microgram; w=week; y=year

Table C-14 Study and population characteristics for KQ1c, ICS and LABA controller and quick relief vs. CBP

Study, Year, n, Acronym, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Loh, 2008^114^ n=38 Retrospective observational cohort study, 3m Medium | ≥14 years of age with moderate to severe asthma and inadequately controlled despite step 3 or 4 (52.6% step 3, 47.4% step 4, per GINA guidelines) treatment ICS dose at entry: 400–1200 μg/d LABA at entry: 100% | Budesonide/formoterol maintenance + PRN (DPI) n=22 | 49 (36 to 65)^a^ | 13.6 | NR | 1.16 (0.71 to 2.35)^a^ | 41 (21 to 74)^a^ | NR | 1200 (200–1400)^a^
Loh, 2008^114^ n=38 Retrospective observational cohort study, 3m Medium | | Budesonide/formoterol maintenance (DPI) + SABA PRN (MDI/DPI) n=16 | 50 (14 to 66)^a^ | 43.8 | NR | 1.41 (0.52 to 2.79)^a^ | 48 (20 to 91)^a^ | NR | NR
Sears, 2008^97^ n=1538 RCT, 6m Medium | ≥12 years of age with mild-severe persistent asthma (18% mild, 43% moderate, 39% severe per GINA guidelines) on ICS ≥400μg/d and sub-optimal control or on daily maintenance ICS+LABA ICS dose at entry: 566–572μg/d LABA use at entry:73–75% | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=772 | 42.1 (16.4) | 42.2 | NR | NR | NR | 1.25 (1.67) | 748 with (0 to 2710)^b,c^
Sears, 2008^97^ n=1538 RCT, 6m Medium | | Conventional best practice^d^ n=766 | 43.1 (16.0) | 37.5 | NR | NR | NR | 1.22 (1.69) | 1015 (30 to 4000)^b,c^
Stallberg, 2008^100^ SHARE n=1776 RCT, 12m | ≥12 years of age with persistent asthma on free combination ICS+LABA or symptomatic despite ICS alone, on ICS ≥400μg/d | Budesonide/formoterol 160/9μg or 320/9μg QD + PRN OR 80/4.5μg or 160/4.5μg BID + PRN n=887 | 43 (NR) | 40 | NR | NR | NR | NR | 291 (NR)
Medium | ICS dose at entry: 636–650μg/d LABA use at entry: 51–52% Randomized therapy stratified by baseline ICS dose^e^ | Budesonide 100–400μg (DPI) + formoterol 4.5 or 9μg (DPI) at a dose judged by investigator + terbutaline PRN^f^ n=433 | 43 (NR) | 41 | NR | NR | NR | NR | 550 (NR)
Louis, 2009^82^ SALTO n=908 RCT, 26w Medium | ≥12 years of age with persistent asthma, symptomatic on ICS alone ≥500μg/d beclomethasone equivalents or without regard to symptoms on ICS+ another controller therapy ICS dose at entry:570–589μg/d | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=450 | 43.4 (NR) | 44.0 | 21.0 (0 to 86)^a^ | NR | NR | 1.09 (0–15)^b^ | 749 (NR)^c^
Louis, 2009^82^ SALTO n=908 RCT, 26w Medium | ≥12 years of age with persistent asthma, symptomatic on ICS alone ≥500μg/d beclomethasone equivalents or without regard to symptoms on ICS+ another controller therapy ICS dose at entry:570–589μg/d | Conventional best practice^g^ n=458 | 42.9 (NR) | 41.0 | 20.2 (0 to 78)^a^ | NR | NR | 1.02 (0–11)^b^ | 1059 (NR)^c^
Quirce, 2011^91^ n=654 RCT, 26w Medium | ≥18 years of age with persistent asthma (mild 26%, moderate 32%, severe 42%) on ICS±LABA, ICS ≥400μg/d budesonide or equivalent, history of suboptimal control per investigator, SABA use ≥3 occasion in prior week ICS dose at entry: 1028–1040μg/d beclomethasone equivalents LABA use at entry: 80–81% | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=328 | 43.7 (18–89)^b^ | 33.5 | 9.7 (0.3 to 57.4)^a^ | NR | NR | 1.6 (1.2) | 799 (NR)^c^
Quirce, 2011^91^ n=654 RCT, 26w Medium | | Conventional best practice^h^ n=326 | 44.3 (8–82)^b^ | 38 | 11.2 (0.3 to 60.6)^a^ | NR | NR | 1.6 (1.2) | 1184 (NR)^c^
Soes-Peterson, 2011^98^ MONO n=1854 RCT, 26w Medium | ≥12 years of age with persistent asthma on ICS ≥320μg/d ±LABA, including patients on ICS alone with history of suboptimal asthma control indicating need for additional treatment ICS dose at entry: 1018–1051μg/d beclomethasone equivalents LABA use at entry: 74–75% | Budesonide/formoterol 160/4.5μg BID + PRN (DPI) n=921 | 43.0 (15.9) | 39.3 | NR | NR | NR | 1.1 (1.4) | 753 (0 to 2500)^b,c^
Soes-Peterson, 2011^98^ MONO n=1854 RCT, 26w Medium | | Conventional best standard^i^ n=914 | 42.0 (15.9) | 41.4 | NR | NR | NR | 1.1 (1.5) | 1092 (42 to 6000)^b,c^
Riemersma, 2012^95^ n=102 RCT, 12m Medium | ≥18 years of age with mild to moderate persistent, stable asthma on daily ICS, FEV1≥60% predicted, 36% well-controlled (ACQ≤0.75) ICS dose at entry: 757–851μg/d beclomethasone equivalents | Budesonide/formoterol 80/4.5μg QD + PRN n=54 | 44.7 (13.2) | 41 | NR | NR | 96.0 (16.0) | 0.6 (1.3) | 326 (NR)^c^
Riemersma, 2012^95^ n=102 RCT, 12m Medium | ≥18 years of age with mild to moderate persistent, stable asthma on daily ICS, FEV1≥60% predicted, 36% well-controlled (ACQ≤0.75) ICS dose at entry: 757–851μg/d beclomethasone equivalents | Usual care^j^ n=48 | 40.6 (12.0) | 35 | NR | NR | 101.5 (17.5) | 0.4 (0.7) | 798 (NR)^c^
Kardos, 2013^79^ n=482 Prospective observational cohort study, 6m Low | ≥18 years of age requiring step 3 or 4 (78% step 3, 22% step 4, per GINA guidelines) treatment and with history of at least 1 severe exacerbation in prior 24 months (but not in the previous month) LABA at entry: 100% | Budesonide/formoterol maintenance + PRN at a dose judged by investigator^k^ n=310 | 49.1 (15.2) | 38.4 | NR | 2.64 (0.87) | NR | NR | 615 (318)^l^
Kardos, 2013^79^ n=482 Prospective observational cohort study, 6m Low | | ICS + LABA maintenance + SABA PRN at a dose judged by the investigator^m^ n=172 | 51.4 (15.4) | 34.3 | NR | 2.45 (0.73) | NR | NR | 678 (380)^l^

Abbreviations: ACQ=Asthma Control Questionnaire; BID=twice daily; d=day; DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; GEMA=Guía Española para el Manejo del Asma; GINA= Global Initiative for Asthma; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; LAMA=long-acting muscarinic antagonist; LTRA=leukotriene receptor antagonist; m=months; MDI=meter-dose inhaler; n=patient sample size; NR=not reported; PRN=pro re nata (i.e., as-needed); QD=daily; RCT=randomized controlled trial; SABA=short-acting β_2_-agonist; SD=standard deviation; w=week; y=year

a Data reported as median (range)

b Data reported as mean (range)

c Beclomethasone dipropionate equivalent dose in μg

d Therapy managed by investigator following Canadian Asthma Consensus Guidelines and could involve ICS+LABA combination products but not combination products used as single maintenance and reliever therapy. During the trial, 18% of patients were on ICS alone and 82% of patients were on ICS+LABA

e Patients previously treated with ICS 400–500μg/d received budesonide/formoterol 80/4.5μg dose and those previously treated with ICS >500μg/d received budesonide/formoterol 160/4.5μg dose

f Therapy used at appropriate dose according to asthma severity as judged by the investigator. Doses could be adjusted up or down within the range but budesonide could not be completely withdrawn

g Physician’s choice of stepwise maintenance therapy with multiple controller therapies allowed. However, an ICS+LABA combination single maintenance and reliever therapy and oral steroids were not allowed. Investigators were encouraged to use the GINA guidelines. Prescribed maintenance medications included ICS+LABA combination inhaler (86%), LTRA (27%), separate ICS inhaler (7%), separate LABA inhaler (7%), inhaled LAMA (4%), xanthines (3%) and mucolytics (1%)

h Active stepped and individualized treatment in accordance with GINA and GEMA guidelines. Patients had to be treated with at least ICS as maintenance treatment and could be treated with any asthma medication except ICS+LABA combination single maintenance and reliever therapy and oral steroids. During the trial, 91% of patients were treated with ICS+LABA either in single or separate inhalers, 27% with LTRAs, 2% with inhaled anticholinergics and 2.5% with mucolytics

i Any guideline-defined treatment was allowed, except ICS+LABA combination single maintenance and reliever therapy. During the trial, 81% of patients were treated with LABA in addition to their ICS, 11% used LTRAs and 88% used SABAs for rescue

j Continued medication as before randomization and treated as usual by general practitioner

k Investigators were provided with the package insert for budesonide/formoterol including dosage and Symbicort maintenance and reliever therapy treatment principles. No other restrictions were applied. No concomitant therapies were disallowed (with the exception of systemic corticosteroids and β-blockers), but investigators were asked to take into account relevant information from the budesonide/formoterol summary of product characteristics

l Represents prescribed inhaled corticosteroid dose

m Only directions given to investigators regarding the comparator group was that these patients had to be treated with inhaled corticosteroids plus long-acting β_2_-agonist and as-needed short-acting β_2_-agonist via separate inhalers and should be treated according to the relevant information in the product package inserts

Table C-15 Study level outcomes for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller and quick relief vs. ICS controller (same dose)

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma control | Quality of life | Healthcare utilization
Scicchitano, 2004^86^ n=1890 RCT, 12m | Age: 12y+ Severity/control: Moderate to severe persistent asthma/symptomatic ICS daily dose: Low vs. low | Relative measures Requiring systemic corticosteroids, hospitalization, or ER visit: RR 0.64 (0.53 to 0.78) HR 0.61 (0.49 to 0.75) IRR 0.55 (0.46 to 0.66) Requiring systemic corticosteroids, hospitalization, ER visit, or PEF <70%: RR 0.65 (0.55 to 0.78) HR 0.61 (0.50 to 0.74) Mild exacerbation: HR 0.68 (0.61 to 0.75) Count data Hospitalization or ER visit: 15 vs. 25 Total number of oral corticosteroid days: 1776 vs. 3177 | All-cause: Peto’s OR 0.51 (0.05 to 4.92) Asthma-specific: No events occurred | Composite measures: NR Spirometry: FEV1 MD 0.1 (0.07 to 0.13) | NR | Rescue medication, inhalations/d: 0.9 vs. 1.42, p<0.001
Rabe, 2006^94^ n=697 RCT, 6m | Age: 12y+ Severity/control: Mild to moderate persistent asthma/symptomatic ICS daily dose: Low vs. low | Relative measures Requiring systemic corticosteroids, hospitalization, ER visit, or PEF <70%: RR 0.49 (0.32 to 0.76) Count data Total number of oral corticosteroid days: 114 vs. 498 | NR | Composite measures: NR Spirometry: FEV1, change from baseline 0.21 vs. 0.06, p<0.001 | NR | Rescue medication, inhalations/d: MD −0.34 (−0.51 to −0.17)
Sovani, 2008^99^ n=71 RCT, 6m | Age: 12y+ Severity/control: Persistent asthma/poor asthma control ICS daily dose: Low vs. low | Relative Measures NR Count data Number of oral corticosteroid courses: 6 vs. 6 | NR | Composite measures: ACQ-7 score: MD 0.15 (−0.5 to 0.7) Spirometry: FEV1 MD 0.01 (−0.2 to 2.00) | AQLQ-mini score: MD 0.35 (−0.3 to 1.00) | NR

Abbreviations: ACQ=Asthma Control Questionnaire; AQLQ=Asthma Quality of Life Questionnaire; d=day; EPR=Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ER=emergency room; FEV1=forced expiratory volume in one second; HR=hazard ratio; ICS=inhaled corticosteroid; IRR= incident rate ratio; m=month; MD=mean difference; n=patient sample size; NR=not reported; OR=odds ratio; PEF=peak expiratory flow; RCT=randomized controlled trial; RR=relative risk; y=year

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations

Table C-16 Study level outcomes for KQ1c, ICS and LABA controller and quick relief vs. ICS controller (higher dose)

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma control | Quality of life | Healthcare utilization
O’Byrne, 2005^75,83^ n=1851 RCT, 12m | Age: Mixed (5–11y and 12+y) Severity/control: Persistent asthma/symptomatic during run-in^c^ ICS daily dose: Low vs. high | Full population Relative measures Composite systemic corticosteroids, hospitalization, ER visit, or increase in ICS or other medication for 4–11y: RR 0.58 (0.46 to 0.72) HR 0.55 (0.43 to 0.70) IRR 0.54 (0.44 to 0.66) Composite systemic corticosteroids, hospitalization, ER visit, or increase in ICS or other medication for 4–11y, PEF<70%: RR 0.57 (0.48 to 0.69) HR 0.53 (0.43 to 0.65) IRR 0.53 (0.44 to 0.64) Mild exacerbation: IRR 0.64 (0.57 to 0.73) Count data Requiring hospitalization or ER visit: 25 vs. 29 Average courses of corticosteroid/y: 0.19 vs. 0.38 | NR | Composite measures: NR Spirometry: NR | NR | NR
| | 4–11y subgroup (n=224) Relative measures Composite hospitalization, ER visit, systemic corticosteroid, or increase in ICS or other treatment: RR 0.43 (0.21 to 0.87) Composite systemic corticosteroid, hospitalization, ER visit, increase in ICS or other treatment, or PEF <70%: RR 0.55 (0.32 to 0.94) HR 0.49 (0.27 to 0.90) Mild exacerbation: RR 0.86 (0.72 to 1.04) Count data Requiring hospitalization or ER: 1 vs. 8 Average courses of corticosteroid/y: 0.05 vs. 0.25 Total number of days requiring oral cortisteroids: 32 vs. 141 | NR | Composite measures: NR Spirometry: NR | NR | NR

Abbreviations: EPR=Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ER=emergency room; HR=hazard ratio; ICS=inhaled corticosteroid; IRR= incident rate ratio; m=month; n=patient sample size; NR=not reported; PEF=peak expiratory flow; RCT=randomized controlled trial; RR=relative risk; y=year

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations

c Defined as 12+ short-acting β_2_-agonist inhalations during last 10 days of the run-in or 8+ short-acting β_2_-agonist inhalations during last 10 days of the run-in for 4–11y olds

Table C-17 Study level outcomes for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (same dose)

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations^b^ | Mortality | Asthma control | Quality of life | Healthcare utilization
O’Byrne, 2005^75,83^ n=1834 RCT, 12m | Age: Mixed (5–11y and 12y+) Severity/control: Persistent asthma/symptomatic during run-in^c^ ICS daily dose: Low vs. low | Full population Relative measures Composite systemic corticosteroid, hospitalization, ER visit, or increase in ICS or other medication for 4–11y: RR 0.52 (0.42 to 0.65) HR 0.50 (0.40 to 0.63) IRR 0.47 (0.39 to 0.57) Composite systemic corticosteroid, hospitalization, ER visit, increase in ICS or other medication for 4–11y, PEF <70%: RR 0.59 (0.49 to 0.71) HR 0.55 (0.44 to 0.67) IRR 0.53 (0.44 to 0.65) Mild exacerbation: IRR 0.70 (0.62 to 0.80) Count data Requiring hospitalization or ER visit: 25 vs. 32 Average courses of corticosteroid/yr: 0.19 vs. 0.42 | NR | Composite measures: NR Spirometry: NR | NR | NR
| | 4–11y subgroup (n=235) Relative measures Composite hospitalization, ER visit, systemic corticosteroid, or increase in ICS or other treatment: RR 0.28 (0.14 to 0.53) Composite systemic corticosteroid, hospitalization, ER visit, increase in ICS or other treatment, or PEF <70%: RR 0.38 (0.23 to 0.63) HR 0.34 (0.19 to 0.60) Mild exacerbation: RR 0.75 (0.64 to 0.88) Count data Requiring hospitalization or ER visit: 1 vs. 8 Average courses of corticosteroid/y: 0.05 vs. 0.30 Total number of days requiring oral corticosteroid: 32 vs. 230 | NR | Composite measures: NR Spirometry: NR | NR | NR
Vogelmeier, 2005^104^ n=2143 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma/symptomatic during run-in^d^ ICS daily dose: Medium vs. medium | Relative Measures Composite systemic cortisteroid, hospitalization, or ER visit: RR 0.80 (0.64 to 0.99) HR 0.77 (0.61 to 0.97) Composite hospitalization, ER, systemic corticosteroid, or unscheduled visit: RR 0.79 (0.65 to 0.95) HR 0.75 (0.61 to 0.93) IRR 0.88 (0.56 to 0.91) Requiring hospitalization or ER visit: RR 0.68 (0.43 to 1.06) Count data: Hospitalization or ER visit: 44 vs. 50 Unscheduled visit: 39 vs. 62 Asthma-related hospital day: 59 vs. 94 Asthma-related ER visit: 38 vs. 45 Unscheduled visit: 117 vs. 154 Total number of oral corticosteroid day: 1980 vs. 2978 | All-cause: Peto’s OR 0.14 (0.01 to 2.18) Asthma-specific: No events occurred | Composite measures: NR Spirometry: NR | NR | NR
Rabe, 2006^93^ n=3394 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma/symptomatic during run-in ICS daily dose: Low vs. low | Relative Measures Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.60 (0.50 to 0.72) HR 0.55 (0.45 to 0.68) IRR 0.52 (0.44 to 0.62) Requiring hospitalization or ER visit: RR 0.61 (0.44 to 0.85) HR 0.57 (0.41 to 0.81) IRR 0.61 (0.45 to 0.82) Mild exacerbation: RR 0.94 (0.90 to 0.99) HR 0.88 (0.80 to 0.97) IRR 0.82 (0.74 to 0.91) Count Data Hospitalization or ER visit: 70 vs. 115 | All-cause: Peto’s OR 0.53 (0.05 to 5.08) Asthma-specific: No events occurred | Composite measures: ACQ-5 score: MD −0.15 (−0.21 to −0.08) Spirometry: FEV1: MD 0.08 (0.05 to 0.10) | NR | Rescue medication use, inhalations/d: MD −0.20 (−0.28 to −0.12)
Atienza, 2013^70^ n=2091 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma/not adequately controlled, symptomatic during run-in^e^ ICS daily dose: Low vs. low | Relative Measures Requiring systemic corticosteroids: RR 0.77 (0.62 to 0.95) HR 0.74 (0.59 to 0.93) IRR 0.73 (0.60 to 0.88) Requiring hospitalization: RR 0.33 (0.17 to 0.65) HR 0.33 (0.17 to 0.65) Requiring ER visit: RR 0.74 (0.59 to 0.93) HR 0.69 (0.54 to 0.88) IRR 0.66 (0.54 to 0.80) Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.74 (0.62 to 0.88) HR 0.70 (0.57 to 0.85) IRR 0.47 (0.40 to 0.55) Requiring hospitalization or ER visit: RR 0.72 (0.58 to 0.90) HR 0.68 (0.53 to 0.86) IRR 0.65 (0.54 to 0.79) Mild exacerbation: RR 0.89 (0.84 to 0.93) HR 0.81 (0.73 to 0.89) Count data Requiring hospitalization: 11 vs. 39 Requiring ER visit: 163 vs. 244 Requiring hospitalization or ER visit: 171 vs. 260 Total number of oral prednisone days: 1215 vs. 1697 | All-cause: Peto’s OR 0.99 (0.06 to 15.89) Asthma-specific: No events occurred | Composite measures: ACQ-5 score: MD −0.124 (−0.179 to −0.069) ACQ-5 responder: RR 1.14 (1.05 to 1.24) Spirometry: FEV1: MD 0.04 (0.015 to 0.064) | NR | Rescue medication use, inhalations/d: MD −0.25 (−0.35 to −0.15)
Papi, 2013^84^ n=1701 RCT, 48w | Age: 12y+ Severity/control: Persistent asthma/not fully controlled ICS daily dose: Low vs. low | Relative Measures Requiring systemic corticosteroid: RR 0.62 (0.49 to 0.79) IRR 0.65 (0.54 to 0.80) Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.65 (0.51 to 0.82) HR 0.64 (0.49 to 0.83) IRR 0.66 (0.55 to 0.80) Requiring hospitalization or ER visit: RR 0.69 (0.49 to 0.96) IRR 0.67 (0.54 to 0.84) Requiring hospitalization: RR 1.18 (0.2 to 2.2) Mild exacerbation: RR 1.00 (0.94 to 1.06) HR 0.97 (0.87 to 1.09) IRR 0.86 (0.76 to 0.98) Count Data Requiring hospitalization or ER visit: 67 vs. 99 Hospitalization: 5 vs. 17 Intubation: No events occurred | NR | Composite measures: ACQ-7 score: MD −0.06 (−0.13 to 0.02) Spirometry: FEV1: MD 0.001 (−0.04 to 0.04) FVC: MD −0.01 (−0.07 to 0.04) | NR | Rescue medication use, inhalations/d: MD −0.02 (−0.13 to 0.09)
Patel, 2013^86^ n=303 RCT, 24w | Age: 12y+ Severity/control: Persistent asthma ICS daily dose: Medium vs. medium | Relative Measures Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.56 (0.38 to 0.84) HR 0.53 (0.33 to 0.85) IRR 0.54 (0.36 to 0.81) Hospital or ER admission for asthma: RR 0.78 (0.30 to 2.05) HR 0.85 (0.37 to 2.00) Hospital admission for asthma: RR 1.01 (0.14 to 7.05) HR 1.54 (0.26 to 9.09) Oral corticosteroid dose (mg prednisone): MD −49.1 (−121.34 to 23.14) Rate of prednisone courses per year: HR 0.58 (0.41 to 0.84) Count data NR | All-cause: No events occurred Asthma-specific: No events occurred | Composite measures: ACQ-7 score: MD −0.23 (−0.47 to 0.01) Spirometry: FEV1: MD 0.15 (−0.06 to 0.36) FEV1 % predicted: MD 1.8 (−2.8 to 6.4) | NR | NR
Hozawa, 2014^78^ n=30 RCT, 8w | Age: 12y+ Severity/control: Persistent asthma/not well controlled and symptomatic ICS daily dose: Medium vs. medium | NR | NR | Composite measures: ACQ-5 score: MD −0.37 (−0.58 to −0.16) Spirometry: FEV1 % predicted: MD 1.9 (−4.27 to 8.07) | NR | Rescue medication use, inhalations/w: MD −0.73 (−1.42 to −0.04)
Takeyama, 2014^101,102^ n=63 RCT, 1y | Age: 12y+ Severity/control: Moderate to severe persistent asthma/not well controlled and symptomatic^g^ ICS daily dose: Low vs. low | Relative Measures Any exacerbation: HR 0.34 (0.11 to 0.92) Count data NR | NR | Composite measures: ACT: MD 6.3 (5.15 to 7.45) Spirometry: FEV1: MD 0.04 (0.02 to 0.06) | NR | Rescue medication use, inhalations/w: MD −2.2 (−3.92 to −0.48)
Stallberg, 2008^100^ n=1343 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma/symptomatic or without symptoms ICS daily dose: Low vs. low to medium | Relative Measures: Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.77 (0.53 to 1.12) IRR 0.81 (0.61 to 1.09) Count Data: Hospitalizations/pt/y: 0.007 vs. 0.000 Unplanned or ER visits/pt/y: 0.448 vs. 0.346 | NR | Composite measures: NR Spirometry:: NR | NR

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; d=day; EPR=Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ER=emergency room; FEV1=forced expiratory volume in one second; FVC=forced vital capacity; HR=hazard ratio; ICS=inhaled corticosteroid; IRR= incident rate ratio; m=month; mg=milligram; MD=mean difference; n=patient sample size; NR=not reported; PEF=peak expiratory flow; pt=patient; RCT=randomized controlled trial; RR=relative risk; w=week; y=year

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations

c Defined as 12+ short-acting β_2_-agonist inhalations during last 10 days of the run-in or 8+ short-acting β_2_-agonist inhalations during last 10 days of the run-in for 4–11y olds

d Defined as rescue medication use 4 or more of the last 7 days in the run-in period

e Defined as rescue medication use 5 or more of the last 7 days in the run-in period

f Defined as Asthma Control Questionnaire >0.75 and short-acting β_2_-agonist use 2–6 times per week

g Defined as Asthma Control Test <20 and reliever use at least 5 times per week

Table C-18 Study level outcomes for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller (higher dose)

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations | Mortality | Asthma control | Quality of life | Healthcare utilization
Bousquet, 2007^76^ n=2309 RCT, 6m | Age: 12y+ Severity/control: Persistent asthma/symptomatic ICS daily dose: Medium vs. high | Relative measures: Requiring systemic corticosteroid: RR 0.82 (0.62 to 1.07) Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.83 (0.65 to 1.06) HR 0.82 (0.63 to 1.05) IRR: 0.79 (0.63 to 0.99) Requiring hospitalization or ER visit: RR 0.66 (0.44 to 0.98) HR 0.64 (0.43 to 0.96) IRR: 0.69 (0.49 to 0.99) Count data: Total number of oral corticosteroid days: 764 vs. 990 | All-cause: OR 7.39 (0.15 to 372.38) Asthma-specific: No events occurred | Composite measures: ACQ-5: MD −0.02 (−0.07 to 0.04) Spirometry:: NR | NR | PRN inhalations/d: MD −0.04 (−0.12 to 0.04)
Kuna, 2007^81^ n=3335 RCT, 6m | Age: 12y+ Severity/control: Persistent asthma/symptomatic during run-in^c^ ICS daily dose: Low vs. medium | Relative Measures vs. budesonide/formoterol: Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.75 (0.58 to 0.96) HR 0.74 (0.56 to 0.96) IRR 0.72 (0.57 to 0.90) Requiring hospitalization or ER visit: RR 0.96 (0.65 to 1.41) HR 0.97 (0.65 to 1.44) IRR 0.88 (0.63 to 1.24) Mild exacerbation: RR 0.97 (0.91 to 1.04) Count data: Total number of oral corticosteroid days: 619d vs. 1044d | All-cause: OR 7.39 (0.15 to 372.38) Asthma-specific: No events occurred | Composite measures: ACQ-5: MD −0.02 (−0.08 to 0.05) Spirometry:: FEV1 MD 0.01 (−0.03 to 0.04) | AQLQ(S): MD 0.01 (−0.07 to 0.08) | PRN inhalations/d: MD −0.03 (−0.12 to 0.06)
| | Relative Measures vs. salmeterol/fluticasone: Composite systemic corticosteroid, hospitalization or ER visit: RR 0.68 (0.53 to 0.87) HR 0.67 (0.52 to 0.87) IRR 0.61 (0.49 to 0.76) Requiring hospitalization or ER visit: RR 0.69 (0.48 to 0.98) HR 0.69 (0.48 to 0.99) IRR 0.61 (0.44 to 0.83) Mild exacerbation: RR 1.04 (0.97 to 1.11) Count data: Total number of oral corticosteroid days: 619d vs. 1132d | All-cause: OR 1.00 (0.06 to 16.00) Asthma-specific: No events occurred | Composite measures: ACQ-5: MD 0.03 (−0.03 to 0.09) Spirometry:: FEV1 MD 0.01 (−0.03 to 0.04) | AQLQ(S): MD −0.02 (−0.09 to 0.06) | PRN inhalations/d: 0.07 (−0.02 to 0.16) Total number of oral corticosteroid days: 619d vs. 1132d
Pavord, 2009^89^ n=127 RCT, 1yr | Age: 12y+ Severity/control: Persistent asthma/symptomatic ICS daily dose: Low vs. medium | Relative Measures Rate of composite systemic steroids, hospitalization, ER visit: IRR 1.02 (0.52 to 2.02) Count data: NR | All-cause: No events occurred Asthma-specific: No events occurred | Composite measures: NR Spirometry:: NR | NR | NR
Lundborg, 2006^115^ n=491 RCT, 26w | Age: Mixed (5–11y and 12+) Severity/control: Persistent asthma/well controlled and not well controlled ICS daily dose: Low vs. medium | Bud/for daily+PRN Relative measures: NR Count data: Number of hospital nights: 0 vs. 0 Number of ER visits: 9 vs. 11 Number of unscheduled MD visits: 11 vs. 17 | NR | Composite measures: ACQ-5: MD −0.07 (−0.24 to 0.10) Spirometry:: NR | NR | NR
| | Bud/for twice daily+PRN Relative measures: NR Count data: Number of hospital nights: 3 vs. 0 Number of ER visits: 17 vs. 11 Number of unscheduled MD visits: 20 vs. 17 | NR | Composite measures: ACQ-5: MD −0.10 (−0.26 to 0.07) Spirometry:: NR | NR | NR
Stallberg, 2008^100^ n=1343 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma/symptomatic or without symptoms ICS daily dose: Low vs. low to medium | Relative Measures: Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.77 (0.53 to 1.12) IRR 0.81 (0.61 to 1.09) Count Data: Hospitalization/pt/y: 0.007 vs. 0.000 Unplanned ER visit/pt/y: 0.448 vs. 0.346 | NR | Composite measures: NR Spirometry:: NR | NR | NR

Abbreviations: ACQ=Asthma Control Questionnaire; Bud/for=budesonide/formoterol; d=day; EPR=Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ER=emergency room; FEV1=forced expiratory volume in one second; HR=hazard ratio; ICS=inhaled corticosteroid; IRR= incident rate ratio; m=months; MD=mean difference; n=patient sample size; NR=not reported; OR=odds ratio; PRN=pro re nata (i.e., as-needed); pt=patient; RCT=randomized controlled trial; RR=relative risk; w=week; y=year

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations

c Defined as symptomatic as short-acting β_2_-agonist use was required at least 5 of 7 days

Table C-19 Study level outcomes for KQ1c, ICS and LABA controller and quick relief vs. ICS and LABA controller and quick relief vs. ICS controller (same dose)

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations | Mortality | Asthma control | Quality of life | Healthcare utilization
Hozawa, 2016^117^ n=30 RCT, 4w | Age: 12y+ Severity/control: Persistent asthma/symptomatic ICS daily dose: Medium vs. low | NR | NR | Composite measures: ACQ-5: MD −0.40 (−0.53 to −0.27) Spirometry:: FEV1 % predicted: MD 3.10 (−1.36 to 7.56) | NR | PRN inhalations/w: MD −0.9 (−1.48 to −0.32)

Abbreviations: ACQ=Asthma Control Questionnaire; d=day; FEV1=forced expiratory volume in one second; ICS=inhaled corticosteroid; MD=mean difference; n=patient sample size; NR=not reported; PRN=pro re nata (i.e., as-needed); pt=patient; RCT=randomized controlled trial; w=week

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

Table C-20 Study level outcomes for KQ1c, ICS and LABA controller and quick relief vs. CBP

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations | Mortality | Asthma control | Quality of life | Healthcare utilization
Sears, 2008^97^ n=1538 RCT, 6m | Age: 12y+ Severity/control: Mild to severe persistent asthma/with or without suboptimal control ICS daily dose: Low vs. mixed | Relative Measures: Systemic corticosteroid: RR 1.03 (0.72 to 1.47) Hospitalization: OR 0.13 (0.00 to 6.77) ER visit: RR 0.69 (0.37 to 1.30) Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.96 (0.69 to 1.35) HR 0.99 (0.85 to 1.15) IRR 0.92 (0.80 to 1.06) Count data: Hospitalization: 0 vs. 1 Hospital day: 0 vs. 5 ER visit: 16 vs. 28 Total number of oral corticosteroid days: 590 vs. 709, p=NR | All-cause: OR 0.51 (0.05 to 4.90) Asthma-specific: No deaths occurred | Composite measures: ACQ-5: MD −0.02 (−0.10 to 0.06) ACQ-5 responder: RR 1.22 (1.03 to 1.44) Spirometry:: NR | NR | PRN inhalations/d: MD −0.16 (−0.26 to −0.05)
Stallberg, 2008^100^ n=1776 RCT, 12m | Age: 12y+ Severity/control: Persistent asthma/symptomatic and without symptoms ICS daily dose: Low vs. mixed | Relative Measures: Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.72 (0.51 to 1.03) IRR 0.89 (0.78 to 1.01) Count Data: Hospitalization/pt/y: 0.007 vs. 0.010 Unplanned ER visit/pt/y: 0.448 vs. 0.295 | NR | Composite measures: NR Spirometry:: NR | NR | NR
Louis, 2009^82^ n=908 RCT, 26w | Age: 12y+ Severity/control: Persistent asthma/symptomatic and without symptoms ICS daily dose: Low vs. mixed | Relative measures: Systemic corticosteroid: RR 0.70 (0.33 to 1.49) Hospitalization: OR 1.99 (0.21 to 19.14) ER visit: RR 0.25 (0.03 to 2.27) Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.64 (0.32 to 1.31) Count data: Hospitalization: 2 vs. 1 Number of hospital days: 10 vs. 15 ER visit: 1 vs. 4 Total number of oral corticosteroid days: 132 vs. 244 | All-cause: OR 7.54 (0.47 to 120.72) Asthma-specific: No deaths occurred | Composite measures: ACQ-5: MD −0.12 (−0.20 to −0.04) Spirometry:: FEV1: MD −0.03 (−0.12 to 0.06) | NR | PRN inhalations/d: MD −0.10 (−0.24 to 0.03) ≥1 day with PRN inhalation: RR 2.96 (2.42 to 3.61)
Quirce, 2011^91^ n=654 RCT, 26w | Age: 12y+ Severity/control: Mild to severe persistent asthma/history of suboptimal control ICS daily dose: Low vs. mixed | Relative measures: Systemic corticosteroid: RR 0.62 (0.33 to 1.16) Hospitalization: OR 7.34 (0.15 to 370.13) ER visit: RR 0.99 (0.47 to 2.11) Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.71 (0.42 to 1.19) HR 0.75 (0.59 to 0.95) IRR 0.75 (0.60 to 0.95) Count data: Hospitalization: 1 vs. 0 ER visit: 14 vs. 15 Total number of oral corticosteroid days: 177 vs. 229, p<0.001 | All-cause: No deaths occurred Asthma-specific: No deaths occurred | Composite measures: ACQ-5: MD −0.12 (−0.23 to −0.01) ACQ-5 responder: RR 1.09 (0.92 to 1.30) Spirometry:: NR | NR | ≥1 day with PRN inhalation: RR 2.96 (2.42 to 3.61) Total number of oral corticosteroid days: 177 vs. 229, p<0.001
Soes-Peterson, 2011^98^ n=1854 RCT, 26w | Age: 12y+ Severity/control: Persistent asthma/with and without history of suboptimal control ICS daily dose: Low vs. mixed | Relative Measures: Systemic corticosteroid: RR 0.79 (0.55 to 1.13) Hospitalization: OR: 0.71 (0.23 to 2.21) ER visit: RR 0.80 (0.43 to 1.51) Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.79 (0.57 to 1.10) HR 0.79 (0.68 to 0.92) IRR 0.74 (0.65 to 0.85) Count data: Hospitalization: 5 vs. 8 Hospital day: 29 vs. 33 ER visit: 18 vs. 22 | All-cause: OR 7.33 (0.15 to 369.58) Asthma-specific: No deaths occurred | Composite measures: ACQ-5: MD −0.09 (−0.15 to −0.03) Spirometry:: NR | NR | NR
Riemersma, 2012^95^ n=102 RCT, 12m | Age: 12y+ Severity/control: Mild to moderate persistent asthma/history of suboptimal control ICS daily dose: Low vs. mixed | Relative Measures: Composite systemic corticosteroid, hospitalization, or ER visit: RR 0.30 (0.06 to 1.40) Requiring ER or hospitalization: No events occurred Count data: Hospitalization: No events occurred ER visit: No events occurred | NR | Composite measures: ACQ-5: MD −0.06 (−0.31 to 0.19) Spirometry:: FEV1 % predicted: MD 0.70 (−1.80 to 3.20) | NR | NR

Abbreviations: ACQ=Asthma Control Questionnaire; d=day; EPR=Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ER=emergency room; FEV1=forced expiratory volume in one second; HR=hazard ratio; ICS=inhaled corticosteroid; IRR= incident rate ratio; m=months; MD=mean difference; n=patient sample size; NR=not reported; OR=odds ratio; PRN=pro re nata (as-needed); pt=patient; RCT=randomized controlled trial; RR=relative risk; w=week; y=year

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was usually not specified and rather details about patients being symptomatic or not at entry were given and reported here. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Relative measures are presented first and include, when reported by the study, RR, HR for time to the event, and IRR for count data allowing multiple events over the period of follow-up. Count data is presented, when reported by the study, for number of hospitalizations, hospital days, and ER visits in association with exacerbations

Table C-21 Study and population characteristics for KQ2a

Study, Year, n, Acronym, Study design, Duration Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Peters, 2010^27^ n=210 TALC RCT- crossover, 14w Low | ≥18 years of age with moderately severe asthma not well controlled on a ICS alone Tiotropium or salmeterol were added on to run-in dose of beclomethasone 80μg BID | Tiotropium 18μg daily (Handihaler) n=210 | 42.2 (12.3) | 32.9 | 26.1 (14.1) | 2.31 (0.77) | 71.5 (14.9) | 1.71 (2.09) | NR
Peters, 2010^27^ n=210 TALC RCT- crossover, 14w Low | ≥18 years of age with moderately severe asthma not well controlled on a ICS alone Tiotropium or salmeterol were added on to run-in dose of beclomethasone 80μg BID | Doubling ICS dose to 160μg BID (MDI) n=210 | 42.2 (12.3) | 32.9 | 26.1 (14.1) | 2.31 (0.77) | 71.5 (14.9) | 1.71 (2.09) | NR
Bateman, 2011^118^ n=254 RCT, 16w Low | 18–65 years of age with moderate persistent asthma (GINA step 3) not controlled on ICS alone (400–1000μg/d budesonide or equivalent) Randomized therapy added on to ICS continued at prestudy dose | Tiotropium 5μg daily (Respimat) n=128 | 43.5 (12.6) | 35.9 | 18.1 (12.1) | 2.3 (0.77) | 74.1 (16.1) | NR | NR
Bateman, 2011^118^ n=254 RCT, 16w Low | 18–65 years of age with moderate persistent asthma (GINA step 3) not controlled on ICS alone (400–1000μg/d budesonide or equivalent) Randomized therapy added on to ICS continued at prestudy dose | Placebo n=126 | 44.0 (11.9) | 40.5 | 17.3 (12.2) | 2.4 (0.8) | 75.3 (19.0) | NR | NR
Kerstjens, 2015^119^ Study 1 MezzoTinA-asthma 1 n=795 RCT, 24w Low | 18–75 year of age with moderate persistent asthma according to GINA guidelines despite treatment with stable medium dose ICS (400–800μg/d budesonide or equivalent) alone or in fixed combination with LABA, symptomatic with ACQ-7 ≥1.5 Randomized therapy was added to prestudy stable maintenance ICS dose^a^ | Tiotropium 5μg daily (Respimat) n=264 | 44.4 (12.6) | 41.7 | 22.9 (14.7) | 2.2 (0.6) | 72.2 (8.2) | NR | 666.4 (216.2)^b^
Kerstjens, 2015^119^ Study 1 MezzoTinA-asthma 1 n=795 RCT, 24w Low | | Tiotropium 2.5μg daily (Respimat) n=262 | 43.7 (13.1) | 40.5 | 22.2 (14.1) | 2.2 (0.7) | 73.1 (8.6) | NR | 649.8 (196.2)^b^
Kerstjens, 2015^119^ Study 1 MezzoTinA-asthma 1 n=795 RCT, 24w Low | | Placebo n=269 | 42.5 (13.1) | 38.3 | 20.2 (13.4) | 2.3 (0.7) | 73.0 (8.2) | NR | 661.5 (209.5)^b^
Kerstjens, 2015^119^ Study 2 MezzoTinA-asthma 2 n=764 RCT, 24w Low | 18–75 year of age with moderate persistent asthma according to GINA guidelines despite treatment with stable medium dose ICS (400–800μg/d budesonide or equivalent) alone or in fixed combination with LABA, symptomatic with ACQ-7 ≥1.5 Randomized therapy was added to prestudy stable maintenance ICS dose^c^ | Tiotropium 5μg daily (Respimat) n=253 | 44.3 (12.7) | 42.3 | 23.1 (15.3) | 2.3 (0.6) | 72.2 (8.3) | NR | 661.3 (216.1)^b^
Kerstjens, 2015^119^ Study 2 MezzoTinA-asthma 2 n=764 RCT, 24w Low | | Tiotropium 2.5μg daily (Respimat) n=257 | 43.0 (12.6) | 37.7 | 21.9 (14.5) | 2.3 (0.7) | 72.5 (8.0) | NR | 662.1 (229.5)^b^
Kerstjens, 2015^119^ Study 2 MezzoTinA-asthma 2 n=764 RCT, 24w Low | | Placebo n=254 | 43.0 (13.0) | 42.9 | 22.0 (13.9) | 2.3 (0.7) | 73.0 (8.4) | NR | 675.6 (225.4)^b^
Lee, 2015^120^ n=362 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 15.6/100μg daily (DPI) n=62 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=362 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 31.25/100μg daily (DPI) n=60 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=362 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 62.5/100μg daily (DPI) n=63 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=362 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 125/100μg daily (DPI) n=58 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=362 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 250/100μg daily (DPI) n=55 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=362 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Fluticasone 100μg daily (DPI) n=64 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Ohta, 2015^121^ n=285 RCT, 52w Low | 18–75 years of age with moderate-severe asthma according to GINA guidelines despite receiving stable medium-dose ICS (400–800μg/d of budesonide or equivalent) alone or fixed combination with LABA, symptomatic with ACQ-7 ≥1.5 Randomized therapy was added to continued background ICS dose with or without LABA^d^ | Tiotropium 2.5μg daily (Respimat) n=114 | 44.7 (12.1) | 36.8 | 21.0 (0.8 to 57.8)^e^ | NR | NR | NR | 673.2 (247.4)^b,f^
Ohta, 2015^121^ n=285 RCT, 52w Low | | Tiotropium 5μg daily (Respimat) n=114 | 42.6 (12.8) | 42.1 | 21.0 (0.3 to 54.0)^e^ | NR | NR | NR | 658.9 (220.5)^b,f^
Ohta, 2015^121^ n=285 RCT, 52w Low | | Placebo N=57 | 47.8 (13.0) | 33.3 | 26.8 (0.8 to 63.0)^e^ | NR | NR | NR | 644.2 (220.9)^b,f^
Hammelmann, 2016^123^ RubaTinA-asthma n=397 RCT, 48w Low | 12–17 years of age with moderate symptomatic asthma with an ACQ ≥1.5 receiving maintenance therapy with ICS with or without LABA or LTRA Randomized therapy was added on to maintenance ICS dose with or without LTRA^g^ | Tiotropium 5μg daily (Respimat) n=134 | 14.5 (1.6) | 66.4 | 8.2 (4.2) | 2.6 (0.6) | 77.3 (8.6) | NR | 536 (256)^b,f^
Hammelmann, 2016^123^ RubaTinA-asthma n=397 RCT, 48w Low | | Tiotropium 2.5μg daily (Respimat) n=125 | 14.2 (1.8) | 64.8 | 7.7 (4.0) | 2.5 (0.6) | 78.1 (7.9) | NR | 557 (346)^b,f^
Hammelmann, 2016^123^ RubaTinA-asthma n=397 RCT, 48w Low | | Placebo n=138 | 14.2 (1.7) | 63.8 | 7.7 (4.2) | 2.6 (0.6) | 77.6 (7.5) | NR | 527 (275)^b,f^
Paggiaro, 2016^122^ GraziaTinA-asthma n=464 RCT, 12w Low | 18–75 years of age with mild symptomatic asthma with an ACQ ≥1.5 despite receiving maintenance therapy with low-moderate ICS (200–400μg/d budesonide or equivalent) that is GINA step 2 Randomized therapy was added on to continued low-medium ICS dose | Tiotropium 5μg daily (Respimat) n=155 | 41.9 (13.0) | 38.1 | 15.2 (10.2) | 2.3 (0.6) | 74.9 (8.1) | NR | 376.9 (59.7)^b,f^
Paggiaro, 2016^122^ GraziaTinA-asthma n=464 RCT, 12w Low | | Tiotropium 2.5μg daily (Respimat) n=154 | 43.8 (14.0) | 46.8 | 17.1 (13.0) | 2.3 (0.7) | 73.2 (8.6) | NR | 384.4 (93.4)^b,f^
Paggiaro, 2016^122^ GraziaTinA-asthma n=464 RCT, 12w Low | | Placebo n=155 | 42.8 (12.1) | 33.5 | 16.2 (12.3) | 2.2 (0.6) | 73.7 (8.5) | NR | 383.0 (77.1)^b,f^

ACQ=Asthma Control Questionnaire; BID=twice daily; d=day(s); DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; GINA=Global Initiative for Asthma; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β-agonist; LTRA=leukotriene receptor antagonist; MDI=metered dose inhaler; n=patient sample size; NR=not reported; RCT=randomized controlled trial; SD=standard deviation; w=weeks; y=years

a Concurrent therapy during the study with leukotriene modifiers was 11.7% in the tiotropium 5μg daily arm, 8.8% in the tiotropium 2.5μg daily arm, 10.9% in the salmeterol 50μg BID arm and 10.8% in the placebo arm

b Data at baseline, randomized treatments were add-on to continued use of ICS

c Concurrent therapy during the study with leukotriene modifiers was 7.1% in the tiotropium 5μg daily arm, 9.7% in the tiotropium 2.5μg daily arm, 8.3% in the salmeterol 50μg BID arm and 7.5% in the placebo arm

d Concurrent therapies during the study in the tiotropium 2.5μg daily arm included LABAs (54.4%), leukotriene modifiers (31.6%) and methylxanthines (22.8%). Concurrent therapies during the study in the tiotropium 5μg daily arm included LABAs (57.0%), leukotriene modifiers (25.4%) and methylxanthines (16.7%). Concurrent therapies during the study in the placebo arm included LABAs (61.4%), leukotriene modifiers (24.6%) and methylxanthines (17.5%).

e Data reported as median (range)

f Budesonide equipotent dose in μg

g Concurrent therapy during the study with leukotriene modifiers was 11.2% in the tiotropium 5μg daily arm, 6.4% in the tiotropium 2.5μg daily arm and 10.1% in the placebo arm

Table C-22 Study level outcomes for KQ2a

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations | Mortality | Asthma control | Quality of life | Healthcare utilization
Peters, 2010^27^ n=210 RCT- crossover, 14w | Age: 12y+ Severity/control: Moderately severe/not well controlled^b^ ICS daily dose: Low vs. medium | Systemic corticosteroids: RR 0.48 (0.12 to 1.84) Oral corticosteroids or increase in ICS or other asthma medications: RR 0.32 (0.09 to 1.13) | NR | Composite measures: ACQ-6: MD −0.15 (−0.45 to 0.15) Spirometry:: FEV1 trough: MD 0.09 (−0.20 to 0.38) | AQLQ: MD 0.04 (−0.32 to 0.40) | NR
Bateman, 2011^118^ n=388 RCT, 16w | Age: 12y+ Severity/control: Moderate persistent/not controlled^c^ ICS daily dose: Low to medium | Systemic corticosteroids: RR 0.93 (0.49 to 1.75) | NR | Composite measures: NR Spirometry:: FEV1 trough: MD 0.15 (0.07 to 0.23) FVC trough: MD 0.14 (0.04 to 0.23) | AQLQ-mini: MD −0.091 (−0.265 to 0.082) | Rescue medication use: MD −0.37 (−0.90 to 0.16)
Kerstjens, 2015^119^ Study 1 n=1071 RCT, 24w | Age: 12y+ Severity/control: Moderate persistent/uncontrolled^d^ ICS daily dose: Low to medium | Systemic corticosteroids: RR 0.62 (0.42 to 0.92)^e^ Asthma worsening: RR 0.79 (0.67 to 0.94)^e^ | All-cause: No deaths occurred | Composite measures: ACQ-7 score: MD −0.21 (−0.30 to −0.12) ACQ-7 responder: RR 1.21 (1.07 to 1.38) Spirometry:: FEV1 peak: MD 0.22 (0.17 to 0.27) FEV1 trough: MD 0.17 (0.11 to 0.22) FEV1 AUC: MD 0.21 (0.16 to 0.26) FVC peak: MD 0.14 (0.09 to 0.19) FVC trough: MD 0.10 (0.04 to 0.16) FVC AUC: MD 0.13 (0.08 to 0.19) | AQLQ: MD 0.07 (−0.06 to 0.2) | Rescue medication use: MD −0.01 (−0.26 to 0.23)
Kerstjens, 2015^119^ Study 2 n=1032 RCT, 24w | Age: 12y+ Severity/control: Moderate persistent/uncontrolled^d^ ICS daily dose: Low to medium | Systemic corticosteroids: RR 0.62 (0.42 to 0.92)^e^ Asthma worsening: RR 0.79 (0.67 to 0.94)^e^ | All-cause: No deaths occurred | Composite measures: ACQ-7 score: MD −0.07 (−0.16 to 0.02) ACQ-7 responder: RR 1.03 (0.92 to 1.15) Spirometry:: FEV1 peak: MD 0.19 (0.15 to 0.24) FEV1 trough: MD 0.16 (0.10 to 0.21) FEV1 AUC: MD 0.18 (0.14 to 0.23) FVC peak: MD 0.10 (0.05 to 0.15) FVC trough: MD 0.08 (0.02 to 0.15) FVC AUC: MD 0.10 (0.04 to 0.16) | AQLQ: MD 0.11 (−0.03 to 0.25) | Rescue medication use: MD −0.03 (−0.25 to 0.19)
Lee, 2015^120^ n=421 RCT- crossover, 15d | Age: 12y+ Severity/control: Not reported/uncontrolled^f^ ICS daily dose: Low | Systemic corticosteroids: RR 0.64 (0.07 to 6.09) | All-cause: No deaths occurred | Composite measures: NR Spirometry:: FEV1 trough: MD 0.11 (0.01 TO 0.21) | NR | Rescue medication use: MD −0.29 (−0.69 to 0.10)
Ohta, 2015^121^ n=285 RCT, 52w | Age: 12y+ Severity/control: Moderate-severe/uncontrolled^d^ ICS daily dose: Low to medium | NR | All-cause: No deaths occurred | Composite measures: ACQ-7 responder: RR 0.98 (0.83 to 1.16) Spirometry:: FEV1 trough: MD 0.06 (−0.02 to 0.15) FVC trough: MD 0.02 (−0.07 to 0.12) | NR | Rescue medication use: MD −0.01 (−0.26 to 0.25)
Hammel-mann, 2016^123^ n=398 RCT, 48w | Age: 12y+ Severity/control: Moderate/uncontrolled^d^ ICS daily dose: Low to medium | Systemic corticosteroids: RR 0.41 (0.16 to 1.09) Asthma worsening: RR 0.92 (0.65 to 1.31) | All-cause: No deaths occurred | Composite measures: ACQ-7: MD −0.17 (−0.30 to −0.04) ACQ-7 responder: RR 1.16 (1.02 to 1.31) Spirometry:: FEV1 peak: MD 0.16 (0.06 to 0.25) FEV1 trough: MD 0.10 (0.00 to 0.20) FEV1 AUC: MD 0.16 (0.07 to 0.24) FVC peak: MD 0.08 (−0.02 to 0.18) FVC trough: MD 0.05 (−0.06 to 0.16) FVC AUC: MD 0.08 (−0.02 to 0.18) | AQLQ(S) 12+ responder: RR 1.12 (0.92 to 1.37) | Rescue medication use: MD −0.29 (−0.53 to −0.05)
Paggiaro, 2016^122^ n=465 RCT, 12w | Age: 12y+ Severity/control: Mild/uncontrolled^d^ ICS daily dose: Low | Systemic corticosteroid: RR 0.88 (0.26 to 2.95) Asthma worsening: RR 0.78 (0.47 to 1.28) | All-cause: No deaths occurred | Composite measures: ACQ-7: MD 0.03 (−0.07 to 0.14) ACQ-7 responder: RR 1.00 (0.86 to 1.18) Spirometry:: FEV1 peak: MD 0.14 (0.08 to 0.21) FEV1 trough: MD 0.12 (0.05 to 0.18) FEV1 AUC: MD 0.14 (0.08 to 0.20) FEV1 % predicted: MD 3.5 (1.58 to 5.42) | NR | Rescue medication use: MD 0.09 (−0.13 to 0.32)

Abbreviations: ACQ=Asthma Control Questionnaire; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; d=days; FEV1=forced expiratory volume in one second; FVC=forced vital capacity; EPR-3=Expert Panel Review-3 (guidelines for the diagnosis and management of asthma); ICS=inhaled corticosteroid; MD=mean difference; n=patient sample size; NR=not reported; RCT=randomized controlled trial; RR=relative risk; w=weeks

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was not always explicitly stated thus study criteria were applied to EPR-3 categories of control to determine asthma control status. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Defined as reported in the study, FEV1% predicted 70% or less or during final 2 week run-in symptoms 6 or more days per week or rescue inhaler used 6 or more days per week or were awakened by symptoms of asthma 2 nights or more per week.

c Defined as reported in the study, symptoms not well controlled on ICS alone

d Required ACQ≥1.5 for enrollment

e Outcome was not reported for study 1 and 2 separately, value reflects data from study 1 and 2 combined

f Patients were required to be symptomatic on ICS with FEV1% predicted 40–80% after run-in

Table C-23 Subgroup analysis by tiotropium dose for KQ2a

| Tiotropium vs. placebo RR or MD (95% CI) (base case analysis) | Tiotropium 2.5μg vs. placebo RR or MD (95% CI) | Tiotropium 5μg vs. placebo RR or MD (95% CI) | Tiotropium 2.5μg vs. 5μg RR or MD (95% CI)
Exacerbation requiring systemic corticosteroid | RR 0.67 (0.48 to 0.92) | RR 0.63 (0.20 to 2.04) | RR 0.69 (0.32 to 1.47) | RR 1.70 (0.11 to 25.55)
Asthma worsening | RR 0.81 (0.68 to 0.97) | RR 0.82 (0.49 to 1.38) | RR 0.85 (0.63 to 1.15) | RR 1.08 (0.45 to 2.57)
ACQ-7 score | MD −0.10 (−0.28 to 0.07) | MD −0.12 (−0.35 to 0.11) | MD −0.09 (−0.23 to 0.06) | MD −0.03 (−0.16 to 0.10)
ACQ-7 responder | RR 1.08 (0.96 to 1.21) | RR 1.08 (0.98 to 1.20) | RR 1.08 (0.95 to 1.24) | RR 0.99 (0.92 to 1.07)
FEV1 peak | MD 0.18 (0.13 to 0.24) | MD 0.20 (0.13 to 0.27) | MD 0.17 (0.13 to 0.21) | MD 0.03 (−0.01 to 0.07)
FEV1 trough | MD 0.13 (0.10 to 0.17) | MD 0.12 (0.03 to 0.21) | MD 0.13 (0.12 to 0.15) | MD −0.01 (−0.08 to 0.06)
FEV1 AUC | MD 0.18 (0.13 to 0.23) | MD 0.19 (0.12 to 0.25) | MD 0.17 (0.12 to 0.21) | MD 0.02 (−0.02 to 0.07)
FVC peak | MD 0.11 (0.05 to 0.18) | MD 0.13 (0.03 to 0.24) | MD 0.09 (0.06 to 0.12) | MD 0.04 (−0.04 to 0.12)
FVC trough | MD 0.08 (0.04 to 0.13) | MD 0.07 (−0.04 to 0.18) | MD 0.08 (0.05 to 0.12) | MD −0.01 (−0.13 to 0.11)
FVC AUC | MD 0.11 (0.05 to 0.17) | MD 0.13 (0.04 to 0.21) | MD 0.09 (0.05 to 0.13) | MD 0.03 (−0.02 to 0.08)
Rescue medication use, puffs/24 hours | MD −0.08 (−0.23 to 0.07) | MD −0.09 (−0.34 to 0.16) | MD −0.03 (−0.22 to 0.16) | MD −0.08 (−0.37 to 0.20)

Abbreviations: ACQ=Asthma Control Questionnaire; AUC=area under curve; CI=confidence interval; FVC=forced vital capacity; FEV1=forced expiratory volume in one second; MD=mean difference; RR=relative risk

Table C-24 Study and population characteristics for KQ2b

Study, Year, n, Acronym, Study design, Duration, Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (yr) [mean (SD)] | FEV_1_ (L) [mean (SD)] | FEV_1_ % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Peters, 2010^27^ TALC n=210 RCT- crossover, 14w Low | ≥18 years of age with moderately severe asthma not well controlled on ICS alone Tiotropium or salmeterol were added on to run-in dose of beclomethasone 80μg BID | Tiotropium 18μg daily (Handihaler) n=210 | 42.2 (12.3) | 32.9 | 26.1 (14.1) | 2.31 (0.77) | 71.5 (14.9) | 1.71 (2.09) | NR
Peters, 2010^27^ TALC n=210 RCT- crossover, 14w Low | ≥18 years of age with moderately severe asthma not well controlled on ICS alone Tiotropium or salmeterol were added on to run-in dose of beclomethasone 80μg BID | Salmeterol 50μg BID (DPI) n=210 | 42.2 (12.3) | 32.9 | 26.1 (14.1) | 2.31 (0.77) | 71.5 (14.9) | 1.71 (2.09) | NR
Bateman, 2011^118^ n=262 RCT, 16w Low | 18–65 years of age with moderate persistent asthma (GINA step 3) not controlled on ICS alone (400–1000μg/d budesonide or equivalent) Randomized therapy added on to ICS continued at prestudy dose | Tiotropium 5μg daily (Respimat) n=128 | 43.5 (12.6) | 35.9 | 18.1 (12.1) | 2.3 (0.77) | 74.1 (16.1) | NR | NR
Bateman, 2011^118^ n=262 RCT, 16w Low | 18–65 years of age with moderate persistent asthma (GINA step 3) not controlled on ICS alone (400–1000μg/d budesonide or equivalent) Randomized therapy added on to ICS continued at prestudy dose | Salmeterol 50μg BID (MDI) n=134 | 42.3 (13.4) | 38.1 | 15.4 (10.7) | 2.4 (0.8) | 75.6 (17.6) | NR | NR
Rajanandh, 2014^146^ n=123 RCT, 90d High | 18–60 years of age with uncontrolled, mild to moderate persistent asthma according to the GINA guidelines^a^ | Tiotropium 18μg daily (HandiHaler) + budesonide 400μg daily n=31 | 40.4 (13.6) | 64.5 | 5.4 (2.7) | NR | 66.9 (1.7) | NR | NR
Rajanandh, 2014^146^ n=123 RCT, 90d High | 18–60 years of age with uncontrolled, mild to moderate persistent asthma according to the GINA guidelines^a^ | Formoterol 6μg BID + budesonide 400μg daily n=32 | 37.2 (14.9) | 56.3 | 5.6 (2.7) | NR | 66.6 (2.0) | NR | NR
Rajanandh, 2014^146^ n=123 RCT, 90d High | 18–60 years of age with uncontrolled, mild to moderate persistent asthma according to the GINA guidelines^a^ | Doxofylline 400mg daily + budesonide 400μg daily n=30 | 37.1 (18.8) | 36.7 | 5.2 (2.7) | NR | 66.8 (1.5) | NR | NR
Rajanandh, 2014^146^ n=123 RCT, 90d High | 18–60 years of age with uncontrolled, mild to moderate persistent asthma according to the GINA guidelines^a^ | Montelukast 10mg daily + budesonide 400μg daily n=30 | 39.3 (17.0) | 40.0 | 5.6 (3.0) | NR | 67.2 (1.4) | NR | NR
Kerstjens, 2015^119^ Study 1 MezzoTinA-asthma 1 n=801 RCT, 24w Low | 18–75 year of age with moderate persistent asthma according to GINA guidelines despite treatment with stable medium dose ICS (400–800μg/d budesonide or equivalent) alone or in fixed combination with LABA, symptomatic with ACQ-7 ≥1.5. Randomized therapy was added to prestudy stable maintenance ICS dose^b^ | Tiotropium 5μg daily (Respimat) n=264 | 44.4 (12.6) | 41.7 | 22.9 (14.7) | 2.2 (0.6) | 72.2 (8.2) | NR | 666.4 (216.2)^c^
Kerstjens, 2015^119^ Study 1 MezzoTinA-asthma 1 n=801 RCT, 24w Low | | Tiotropium 2.5μg daily (Respimat) n=262 | 43.7 (13.1) | 40.5 | 22.2 (14.1) | 2.2 (0.7) | 73.1 (8.6) | NR | 649.8 (196.2)^c^
Kerstjens, 2015^119^ Study 1 MezzoTinA-asthma 1 n=801 RCT, 24w Low | | Salmeterol 50μg BID (MDI) n=275 | 42.6 (12.6) | 42.2 | 21.4 (14.5) | 2.3 (0.6) | 72.8 (8.5) | NR | 656.7 (193.1)^c^
Kerstjens, 2015^119^ Study 2 MezzoTinA-asthma 2 n=776 RCT, 24w Low | 18–75 year of age with moderate persistent asthma according to GINA guidelines despite treatment with stable medium dose ICS (400–800μg/d budesonide or equivalent) alone or in fixed combination with LABA, symptomatic with ACQ-7 ≥1.5 Randomized therapy was added to prestudy stable maintenance ICS dose^d^ | Tiotropium 5μg daily (Respimat) n=253 | 44.3 (12.7) | 42.3 | 23.1 (15.3) | 2.3 (0.6) | 72.2 (8.3) | NR | 661.3 (216.1)^c^
Kerstjens, 2015^119^ Study 2 MezzoTinA-asthma 2 n=776 RCT, 24w Low | | Tiotropium 2.5μg daily (Respimat) n=257 | 43.0 (12.6) | 37.7 | 21.9 (14.5) | 2.3 (0.7) | 72.5 (8.0) | NR | 662.1 (229.5)^c^
Kerstjens, 2015^119^ Study 2 MezzoTinA-asthma 2 n=776 RCT, 24w Low | | Salmeterol 50μg BID (MDI) n=266 | 41.5 (13.1) | 42.5 | 20.4 (14.1) | 2.4 (0.7) | 73.1 (8.1) | NR | 644.7 (217.2)^c^
Lee, 2015^120^ n=357 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 15.6/100μg daily (DPI) n=62 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=357 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 31.25/100μg daily (DPI) n=60 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=357 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 62.5/100μg daily (DPI) n=63 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=357 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 125/100μg daily (DPI) n=58 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=357 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Umeclidinium/fluticasone 250/100μg daily (DPI) n=55 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Lee, 2015^120^ n=357 RCT- crossover, 15d Unclear | 18 years of age and older with symptomatic asthma despite ICS treatment, alone or in combination with LABA or leukotriene modifier | Vilanterol/fluticasone 125/100μg daily (DPI) n=59 | 47.5 (13.8) | 31 | <1y=2% 1–4y=13% 5–9y=17% ≥10=69% | 1.85 (0.53) | 62.3 (10.3) | NR | NR
Rajanandh, 2015^147^ n=297 RCT, 180d Medium | 18–60 years of age with uncontrolled, mild-moderate persistent asthma according to GINA guidelines^a^ | Tiotropium 18μg daily (Handihaler) + budesonide 400μg daily n=72 | 37.4 (13.6) | 52.8 | 5.8 (8.7) | NR | 66.1 (6.4) | 4.4 (1.1) | NR
Rajanandh, 2015^147^ n=297 RCT, 180d Medium | 18–60 years of age with uncontrolled, mild-moderate persistent asthma according to GINA guidelines^a^ | Formoterol 6μg BID + budesonide 400μg daily n=68 | 38.4 (14.9) | 55.4 | 6.6 (6.7) | NR | 66.2 (8.3) | 4.4 (1.1) | NR
Rajanandh, 2015^147^ n=297 RCT, 180d Medium | 18–60 years of age with uncontrolled, mild-moderate persistent asthma according to GINA guidelines^a^ | Montelukast 10mg daily + budesonide 400μg daily n=81 | 36.3 (17.0) | 44.4 | 5.9 (8.0) | NR | 67.2 (6.5) | 4.5 (1.2) | NR
Rajanandh, 2015^147^ n=297 RCT, 180d Medium | 18–60 years of age with uncontrolled, mild-moderate persistent asthma according to GINA guidelines^a^ | Doxofylline 400mg daily + budesonide 400μg daily n=76 | 38.3 (18.8) | 53.9 | 6.2 (9.7) | NR | 66.3 (7.0) | 4.5 (1.1) | NR
Wechsler, 2015^148^ BELT n=1070 RCT, 18m Low | 18–75 years of age with asthma currently on or eligible for step 3 or 4 combination ICS/LABA according to the NHLBI guidelines Randomized therapy was added to continued baseline ICS dose | Tiotropium 18μg daily (HandiHaler) n=532 | 45.2 (12.6) | 23.9 | 23.3 (15.8) | 2.1 (0.7) | 78.6 (17.6) | 3.4 (3.5) | NR^f^
Wechsler, 2015^148^ BELT n=1070 RCT, 18m Low | 18–75 years of age with asthma currently on or eligible for step 3 or 4 combination ICS/LABA according to the NHLBI guidelines Randomized therapy was added to continued baseline ICS dose | LABA BID^e^ n=538 | 45.1 (12.6) | 24.2 | 25.6 (16.0) | 2.1 (0.6) | 78.7 (18.6) | 3.5 (3.7) | NR^f^

Abbreviations: ACQ=Asthma Control Questionnaire; BID=twice daily; d=day; DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; GINA=Global Initiative for Asthma; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; =months; MDI=metered dose inhaler; n=patient sample size; NHLBI=National Heart, Lung, and Blood Institute; NR=not reported; RCT=randomized controlled trial; SD=standard deviation; μg=microgram; w=week; y=year

a Confirmed through author correspondence

b Concurrent therapy during the study with leukotriene modifiers was 11.7% in the tiotropium 5μg daily arm, 8.8% in the tiotropium 2.5μg daily arm, 10.9% in the salmeterol 50μg BID arm and 10.8% in the placebo arm

c Data at baseline, randomized treatments were add-on to continued use of ICS

d Concurrent therapy during the study with leukotriene modifiers was 7.1% in the tiotropium 5μg daily arm, 9.7% in the tiotropium 2.5μg daily arm, 8.3% in the salmeterol 50μg BID arm and 7.5% in the placebo arm

e Either salmeterol 50μg or formoterol 9μg BID, based on baseline usage of LABA. 116/538 (21.6%) for formoterol & 422/538 (78.4%) for salmeterol

f Mean/median ICS dose was not reported, although patients continued baseline ICS dose. Of those taking an ICS without LABA at baseline (28%), 88% were taking low-dose ICS <500μg. Of those taking ICS+LABA, 70% were using a single inhaler to delivery both medications. Approximately half were taking fluticasone/salmeterol 250/50μg

Table C-25 Study level outcomes for KQ2b

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations | Mortality | Asthma control | Quality of life | Healthcare utilization
Peters, 2010^27^ n=210 RCT- crossover, 14w | Age: 12y+ Severity/control: Moderately severe/not well controlled^b^ ICS daily dose: Low vs. medium | Systemic corticosteroid: RR 0.60 (0.15 to 2.42) Oral corticosteroid or increase in ICS or other asthma medication: RR 0.60 (0.15 to 2.42) | NR | Composite measures: ACQ-6: MD 0.30 (0.00 to 0.60) Spirometry:: FEV1 trough: MD 0.12 (−0.15 to 0.39) | AQLQ: MD −0.22 (−0.60 to 0.16) | NR
Bateman, 2011^118^ n=388 RCT, 16w | Age: 12y+ Severity/control: Moderate persistent/not controlled^c^ ICS daily dose: Low to medium | Systemic corticosteroid: RR 0.99 (0.52 to 1.87) | NR | Composite measures: NR Spirometry:: FEV1 trough: MD −0.02 (−0.10 to 0.06) FVC trough: MD 0.01 (−0.08 to 0.11) | AQLQ-mini: MD −0.149 (−0.320 to 0.222) | Rescue medication use: MD 0.20 (−0.32 to 0.72)
Rajanandh, 2014^146^ n=167 RCT, 90d | Age: 12y+ Severity/control: Mild to moderate persistent/uncontrolled^d^ ICS daily dose: Low to medium | NR | NR | Composite measures: NR Spirometry:: FEV1 % predicted: LAMA vs. LABA: MD −7.34 (−8.30 to −6.38) LAMA vs. montelukast: MD −2.14 (−2.93 to −1.35) LAMA vs. doxofylline: MD −3.87 (−4.6 to −3.14) | NR | Rescue medication use: LAMA vs. LABA: MD 1.38 (0.89 to 1.87) LAMA vs. montelukast: MD 0.26 (−0.25 to 0.77) LAMA vs. doxofylline: MD 1.21 (0.89 to 1.53)
Kerstjens, 2015^119^ Study 1 n=1071 RCT, 24w | Age: 12y+ Severity/control: Moderate persistent/uncontrolled^e^ ICS daily dose: Low to medium | Systemic corticosteroid: RR 0.81 (0.54 to 1.24)^f^ Asthma worsening: RR 1 (0.84 to 1.12)^f^ | All-cause: No deaths occurred | Composite measures: ACQ-7 score: MD 0.04 (−0.05 to 0.13) ACQ-7 responder: RR 1.06 (0.96 to 1.18) Spirometry:: FEV1 peak: MD 0.004 (−0.05 to 0.05) FEV1 trough: MD 0.05 (−0.01 to 0.10) FEV1 AUC: MD −0.004 (−0.05 to 0.04) FVC peak: MD 0.016 (−0.04 to 0.07) FVC trough: MD 0.03 (−0.03 to 0.10) FVC AUC: MD 0.005 (−0.05 to 0.06) | AQLQ: MD −0.07 (−0.20 to 0.06) | Rescue medication use: MD 0.44 (0.20 to 0.68)
Kerstjens, 2015^119^ Study 2 n=1032 RCT, 24w | Age: 12y+ Severity/control: Moderate persistent/uncontrolled^e^ ICS daily dose: Low to medium | Systemic corticosteroid: RR 0.81 (0.54 to 1.24)^f^ Asthma worsening: RR 1.00 (0.84 to 1.12)^f^ | All-cause: No deaths occurred | Composite measures: ACQ-7 score: MD 0 (−0.09 to 0.09) ACQ-7 responder: RR 1.00 (0.90 to 1.12) Spirometry:: FEV1 peak: MD 0.014 (−0.03 to 0.06) FEV1 trough: MD 0.05 (0.00 to 0.10) FEV1 AUC: MD 0.004 (−0.04 to 0.05) FVC peak: MD −0.017 (−0.07 to 0.03) FVC trough: MD 0.02 (−0.05 to 0.08) FVC AUC: MD −0.032 (−0.09 to 0.03) | AQLQ: MD −0.05 (0.18 to 0.08) | Rescue medication use: MD 0.09 (−0.13 to 0.31)
Lee, 2015^120^ n=421 RCT- crossover, 15d | Age: 12y+ Severity/control: Not reported/uncontrolled^g^ ICS daily dose: Low | Systemic corticosteroid: RR 6.93 (0.36 to 133.57) | All-cause: No deaths occurred | Composite measures: NR Spirometry: FEV1 trough: MD −0.05 (−0.15 to 0.06) | NR | Rescue medication use: MD 0.14 (−0.25 to 0.53)
Rajanandh, 2015^147^ n=362 RCT, 180d | Age: 12y+ Severity/control: Mild to moderate persistent/uncontrolled^d^ ICS daily dose: Low to medium | Requiring hospitalization: No events occurred | NR | Composite measures: NR Spirometry: FEV1 % predicted: LAMA vs. LABA: MD −4.46 (−6.71 to −2.21) LAMA vs. montelukast: MD −0.87 (−2.77 to −1.03) LAMA vs. doxofylline: MD −2.69 (−4.79 to −0.59) | NR | Rescue medication use: LAMA vs LABA: MD 2.03 (1.72 to 2.34) LAMA vs. monteluklast: 1.19 (0.88 to 1.5) LAMA vs. doxofylline: MD 1.21 (0.89 to 1.53)
Wechsler, 2015^148^ n=1070 RCT, 18m | Age: 12y+ Severity/control: Step 3 or 4 according to NHLBI guidelines/uncontrolled^h^ ICS daily dose: Low to high | Systemic corticosteroid or hospitalization: RR 1.09 (0.87 to 1.36) Requiring hospitalization: RR 0.52 (0.24 to 1.11) | All-cause: 0.6% vs. 0%, p=0.12 Asthma-specific: 0.4% vs. 0%, p=0.25 | Composite measures: ACQ-7: MD 0.04 (−0.18 to 0.27) Spirometry:: FEV1 trough: MD −0.02 (−0.09 to 0.04) FEV1 % predicted: MD −0.63 (−4.41 to 3.15) | AQLQ: MD 0.05 (−0.23, 0.33) | Rescue medication use: MD −0.05 (−0.71 to 0.61)

Abbreviations: ACQ=Asthma Control Questionnaire; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; d=day; FEV1=forced expiratory volume in one second; FVC=forced vital capacity; EPR=Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ICS=inhaled corticosteroid; LABA=long-acting beta-agonist; LAMA=long-acting muscarinic antagonist; m=month; MD=mean difference; n=patient sample size; NHLBI=National Heart, Lung and Blood Institute; NR=not reported; RCT=randomized controlled trial; RR=relative risk; w=week

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was not always explicitly stated thus study criteria were applied to EPR-3 categories of control to determine asthma control status. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b As reported in the study, FEV1 % predicted 70% or less or during final 2 week run-in symptoms 6 or more days per week or rescue inhaler used 6 or more days per week or were awakened by symptoms of asthma 2 nights or more per week.

c As reported in the study, symptoms not well controlled on ICS alone

d Confirmed through email correspondence with author although further details were not provided

e Required ACQ≥1.5 for enrollment

f Outcome was not reported for study 1 and 2 separately, value reflects data from study 1 and 2 combined

g Patients were required to be symptomatic on ICS with FEV1 % predicted 40–80% after run-in

h Not explicitly defined by the study. Expert consensus arrived at “uncontrolled” given baseline ACQ, rescue medication use and FEV1 <80%

Table C-26 Study and population characteristics for KQ2c

Study, Year, n, Acronym, Study design, Duration Risk of bias | Study population | Intervention Comparisons | Age (y) [mean (SD)] | Males (%) | Duration of asthma (y) [mean (SD)] | FEV1 (L) [mean (SD)] | FEV1 % predicted (L) [mean (SD)] | Rescue inhaler use (puffs/d) [mean (SD)] | ICS dose during study (μg/d) [mean (SD)]
Kerstjens, 2012^141^ Study 1 PrimoTinA-asthma 1 n=459 RCT, 48w Low | 18–75 years of age with severe persistent, symptomatic asthma & ACQ-7 ≥1.5 despite daily ICS (≥800μg budesonide or equivalent per day) and LABA therapy Randomized therapy added on to pretrial maintenance high-dose ICS and LABA. Other maintenance medications allowed to continue at stable doses^a^ | Tiotropium 5μg daily (Respimat) n=237 | 52.9 (12.4) | 38.4 | 31 (6 to 70)^b^ | 1.60 (0.55) | 54.6 (12.2) | 2.8 (NR) | 800 (800–1600)^c,d,e^
Kerstjens, 2012^141^ Study 1 PrimoTinA-asthma 1 n=459 RCT, 48w Low | | Placebo n=222 | 53.9 (12.8) | 35.6 | 28 (6 to 68)^b^ | 1.56 (0.54) | 54.6 (12.2) | 3.3 (NR) | 800 (800–1600)^c,d,e^
Kerstjens, 2012^141^ Study 2 PrimoTinA-asthma 2 n=453 RCT, 48w Low | 18–75 years of age with severe persistent, symptomatic asthma & ACQ-7 ≥1.5 despite daily ICS (≥800μg budesonide or equivalent per day) and LABA therapy Randomized therapy added on to pretrial maintenance high-dose ICS and LABA; Other maintenance medications allowed to continue at stable doses.^f^ | Tiotropium 5μg daily (Respimat) n=219 | 51.4 (12.5) | 42.0 | 26 (5 to 72)^b^ | 1.66 (0.57) | 55.1 (12.8) | 3.4 (NR) | 800 (800–1600) ^c,d,e^
Kerstjens, 2012^141^ Study 2 PrimoTinA-asthma 2 n=453 RCT, 48w Low | | Placebo n=234 | 53.6 (11.7) | 42.3 | 28 (5 to 69)^b^ | 1.60 (0.51) | 55.0 (12.6) | 3.3 (NR) | 800 (800–1600) ^c,d,e^
Wang, 2015^151^ n=63 RCT, 12w Unclear | Adults with moderate persistent asthma according to GINA guidelines, uncontrolled on salmeterol/fluticasone 50/250μg BID with daily symptoms and use of SABA Tiotropium was added on to continued salmeterol/fluticasone 50/250μg BID | Tiotropium 18μg daily (HandiHaler) n=33 | 36.7 (5.79)^g^ | 54.5 | NR | NR | NR | NR | 500^h^
Wang, 2015^151^ n=63 RCT, 12w Unclear | | Increase salmeterol /fluticasone to 50/500μg BID (DPI) n=30 | 35.3 (5.89)^g^ | 53.3 | NR | NR | NR | NR | 1000^h^
Hamelmann, 2016^152^ PensieTinA-asthma n=392 RCT, 12w Low | 12–17 years of age with severe persistent asthma according to GINA guidelines despite high-dose ICS (>400μg/d in 12–14y, >800–1600μg/d of budesonide equivalent if >14y) with another controller OR medium dose ICS (200–400μg/d budesonide equivalent in 12–14y, 400–800μg/d in >14y) with two other controllers; Symptomatic with ACQ-7 ≥1.5. Randomized therapies were added on to ICS and other controllers used prior to the study^i^ | Tiotropium 5μg daily (Respimat) n=130 | 14.3 (1.6) | 63.8 | 7.3 (4.0) | 2.6 (0.7) | 79.4 (12.3) | NR | 776.7 (381.2)^d,e^
Hamelmann, 2016^152^ PensieTinA-asthma n=392 RCT, 12w Low | | Tiotropium 2.5μg daily (Respimat) n=127 | 14.4 (1.8) | 63.0 | 8.0 (3.9) | 2.5 (0.6) | 79.8 (9.9) | NR | 727.8 (343.6) ^d,e^
Hamelmann, 2016^152^ PensieTinA-asthma n=392 RCT, 12w Low | | Placebo n=135 | 14.1 (1.7) | 58.5 | 8.0 (3.7) | 2.5 (0.6) | 79.4 (12.2) | NR | 736.6 (347.9) ^d,e^

Abbreviations: ACQ=Asthma Control Questionnaire; BID=twice daily; d=day; DPI=dry powder inhaler; FEV1=forced expiratory volume in one second; GINA=Global Initiative for Asthma; ICS=inhaled corticosteroid; L=liter; LABA=long-acting β_2_-agonist; LAMA=long-acting muscarinic antagonist; n=patient sample size; NR=not reported; RCT=randomized controlled trial; SABA=short-acting β-agonist; SD=standard deviation; μg=microgram; w=week; y=year

a Concurrent therapies during the study in the tiotropium arm included leukotriene modifiers (25.3%), theophylline (18.6%), omalizumab (2.5%), systemic steroids (6.8%) and antihistamines (20.3%). Concurrent therapies during the study in the placebo arm included leukotriene modifiers (27.5%), theophylline (21.2%), omalizumab (4.5%), systemic steroids (5.0%) and antihistamines (16.2%)

b Data reported as median (range)

c Data reported as median (interquartile range)

d Data at baseline, randomized treatments were added on to continued use of ICS

e Budesonide equipotent dose in μg

f Concurrent therapies during the study in the tiotropium arm included leukotriene modifiers (16.4%), theophylline (14.2%), omalizumab (2.7%), systemic steroids (3.7%) and antihistamines (14.2%). Concurrent therapies during the study in the placebo arm included leukotriene modifiers (19.7%), theophylline (12.8%), omalizumab (6.0%), systemic steroids (5.6%) and antihistamines (8.1%)

g Data reported as mean (standard error)

h ICS dose assumed due to fixed dosing with add-on therapy (tiotropium arm) or increased dose (salmeterol/fluticasone arm) used in trial

i Concurrent therapies during the treatment period in the tiotropium 5μg arm were systemic corticosteroids (3%), short acting anticholinergic (0.8%), long-acting β_2_-agonists (82.3%), theophylline (6.2%) and leukotriene modifiers (78.5%). In this arm, 33.1% of patients were on 2 controllers while 66.9% were on three controllers. Concurrent therapies during the treatment period in the tiotropium 2.5μg arm were systemic corticosteroids (0.8%), long-acting β_2_-agonists (79.5%), theophylline (4.7%) and leukotriene modifiers (81.9%). In this arm, 33.9% of patients were on 2 controllers while 66.1% were on three controllers. Concurrent therapies during the treatment period in the placebo arm were systemic corticosteroids (1.5%), long-acting β_2_-agonists (85.9%), theophylline (5.2%) and leukotriene modifiers (80.7%). In this arm, 28.2% of patients were on 2 controllers while 71.9% were on three controllers

Table C-27 Study level outcomes for KQ2c

Study, Year, n, Study design, Duration | Population^a^ | Exacerbations | Mortality | Asthma control | Quality of life | Healthcare utilization
Kerstjens, 2012^150^ Study 1 n=459 RCT, 48w | Age: 12y+ Severity/control: Severe persistent/uncontrolled^b^ ICS daily dose: Medium to high | Systemic corticosteroid: RR 0.73 (0.54 to 0.99) Asthma worsening: RR 0.79 (0.67 to 0.94) Requiring hospitalization: RR 1.33 (0.54 to 3.32) | All-cause: No deaths occurred | Composite measures: ACQ-7 score: MD −0.12 (−0.27 to 0.03) ACQ-7 responder: RR 0.78 (0.68 to 0.88)^c^ ACQ-6 responder: OR 1.49 (1.14 to 1.9)^c^ ACQ-5 responder: OR 1.42 (1.08 to 1.86)^c^ Spirometry:: FEV1 peak: MD 0.07 (0.00 to 0.14) FEV1 trough: MD 0.04 (−0.03 to 0.11) FEV1 AUC: MD 0.07 (0.00 to 0.14) FVC peak: MD 0.12 (0.03 to 0.22) FVC trough: MD 0.11 (0.02 to 0.20) FVC AUC: MD 0.12 (0.04 to 0.21) | AQLQ: MD 0.038 (−0.13 to 0.2) AQLQ responder: RR 1.62 (1.34 to 1.96)^c^ | Rescue medication use: MD −0.09 (−0.47 to 0.29)
Kerstjens, 2012^150^ Study 2 n=453 RCT, 48w | Age: 12y+ Severity/control: Severe persistent/uncontrolled^b^ ICS daily dose: Medium to high | Systemic corticosteroid: RR 0.91 (0.70 to 1.19) Asthma worsening: RR 0.79 (0.67 to 0.93) Requiring hospitalization: RR 1.16 (0.47 to 2.89) | All-cause: No deaths occurred | Composite measures: ACQ-7 score: MD −0.13 (−0.27 to 0.01) ACQ-7 responder: RR 0.78 (0.68 to 0.88)^c^ ACQ-6 responder: OR 1.49 (1.14 to 1.9)^c^ ACQ-5 responder: OR 1.42 (1.08 to 1.86)^c^ Spirometry:: FEV1 peak: MD 0.15 (0.08 to 0.22) FEV1 trough: MD 0.09 (0.03 to 0.16) FEV1 AUC: MD 0.14 (0.07 to 0.20) FVC peak: MD 0.12 (0.02 to 0.21) FVC trough: MD 0.07 (−0.02 to 0.16) FVC AUC: MD 0.11 (0.02 to 0.20) | AQLQ: MD 0.14 (−0.03 to 0.31) AQLQ responder: RR 1.62 (1.34 to 1.96)^c^ | Rescue medication use: MD −0.26 (−0.71 to 0.18)
Wang, 2015^151^ n=63 RCT, 12w | Age: 12y+ Severity/control: Moderate persistent/uncontrolled^d^ ICS daily dose: Medium vs. high | NR | NR | Composite measures: ACT score: MD −0.61 (−4.82 to 3.6) Spirometry:: NR | NR | NR
Hamelmann, 2016^152^ n=392 RCT, 12w | Age: 12y+ Severity/control: Severe persistent/uncontrolled^b^ ICS daily dose: Medium to high | Systemic corticosteroid: RR 1.58 (0.17 to 15.00) Asthma worsening: RR 0.69 (0.43 to 1.12) | All-cause: No deaths occurred | Composite measures: ACQ-7 score: MD 0.05 (−0.11 to 0.20) ACQ-7 responder: RR 0.99 (0.88 to 1.12) ACQ-6 score: MD 0.085 (−0.08 to 0.25) ACQ-6 responder: RR 1.00 (0.88 to 1.12) Spirometry: FEV1 peak: MD 0.10 (−0.01 to 0.21) FEV1 trough: MD 0.08 (−0.03 to 0.20) FEV1 AUC: MD 0.10 (0.00 to 0.20) FVC peak: MD 0.08 (−0.04 to 0.19) FVC trough: MD 0.08 (−0.04 to 0.20) FVC AUC: MD 0.07 (−0.04 to 0.18) | NR | Rescue medication use: MD −0.03 (−0.32 to 0.26)

Abbreviations: ACQ=Asthma Control Questionnaire; ACT=Asthma Control Test; AQLQ=Asthma Quality of Life Questionnaire; AUC=area under the curve; FEV1=forced expiratory volume in one second; FVC=forced vital capacity; EPR=Expert Panel Review (Guidelines for the Diagnosis and Management of Asthma); ICS=inhaled corticosteroid; MD=mean difference; n=patient sample size; NR=not reported; OR=odds ratio; PEF=peak expiratory flow; RCT=randomized controlled trial; RR=relative risk; SABA=short-acting β-agonist; w=weeks

a Age is categorized using study inclusion criteria and the age categories used in EPR-3 of 0–4y, 5–11y and 12y+. Severity is as reported per the study. Control was not always explicitly stated thus study criteria were applied to EPR-3 categories of control to determine asthma control status. ICS daily dose is categorized using the study’s required ICS dose and the EPR-3 categories of low, medium and high

b Required ACQ≥1.5 for enrollment

c Outcome was not reported for study 1 and 2 separately, value reflects data from study 1 and 2 combined

d Daily symptoms, daily SABA use, FEV1 % predicted or PEF 60–80%