# Appendix B List of Excluded Studies

## ICS Search

1 2nd WAO International Scientific Conference, WISC 2012, Abstracts. World Allergy Organ J. 2013;6;Suppl 1:1–67. [Not an intervention of interest]23663402
2 A combination of fluticasone and salmeterol for asthma. Med Lett Drugs Ther. 2001 Apr 16;43(1102):31–3. PMID: 11309534. [Not a human study]11309534
3 Aalbers R, Backer V, Kava TTK, . Adjustable maintenance dosing with budesonide/formoterol compared with fixed-dose salmeterol/fluticasone in moderate to severe asthma. Curr Med Res Opin. 2004;20(2):225–40. PMID: 15006018. [Not an intervention of interest]15006018
4 Aalbers R, Mensing M, Boorsma M, . Protective effect of budesonide/formoterol in a model of repeated exposure to inhaled adenosine 5′-monophosphate (AMP) in patients with asthma. Eur Respir J. 2007;30;Suppl 51:353s. [Not an intervention of interest]
5 Aalbers R. Fixed or adjustable maintenance-dose budesonide/formoterol compared with fixed maintenance-dose salmeterol/fluticasone propionate in asthma patients aged >or=16 years: Post hoc analysis of a randomized, double-blind/open-label extension, parallel-group study. Clin Drug Invest. 2010;30(7):439–51. PMID: 20528000. [Not an intervention of interest]20528000
6 Aalbers R. Single inhaler as maintenance and reliever therapy--is it SMART? Lancet Respir Med. 2013 Mar;1(1):2–3. PMID: 24321788. [Not a human study]24321788
7 Abramson M, Sim MR. Occupational asthma. Thorax. 2006 Sep;61(9):741–2. [Not a human study]16936232
8 Acun C, Tomac N, Sogut A, . A comparison of inhaled budesonide and oral prednisolone for children with acute asthma. 2003 Sep;22;Suppl 45:134. [Not in the target population]
9 Adachi M, Ishihara K, Inoue H, . Safety and efficacy of inhaled ciclesonide in long-term administration to adult patients with bronchial asthma. Ther Res. 2008;29(5):821–32. [Not an intervention of interest]
10 Adelroth E, Thompson S. Advantages of high-dose inhaled budesonide. Lancet. 1988 Feb 27;1(8583):476. PMID: 2893900. [Not an intervention of interest]2893900
11 Adelsberg B. Combined budesonide and formoterol for maintenance and relief provided better asthma control than budesonide for maintenance and terbutaline for relief: commentary. Evid-Based Med. 2006 Oct;11(5):138. [Not a human study]17213140
12 Adler LM, Clarke IC. Efficacy and safety of beclomethasone dipropionate (BDP) delivered via a novel dry powder inhaler (Clickhaler[TM]) in paediatric patients with asthma. Thorax. 1997;52;Suppl 6:A57 P106. [Not an intervention of interest]
13 Adolfsson LE, Lundgren M, Tilling B, . Short-term safety and tolerability of double-dose salmeterol/fluticasone propionate in adult asthmatic patients. Clin Drug Invest. 2005;25(4):231–41. DOI: 10.2165/00044011-200525040-00002. [Not an intervention of interest]
14 Aelony Y. Inhaled fluticasone and zafirlukast in persistent asthma. Am J Med. 2002 Mar;112(4):333. PMID: 11893383. [Not a human study]11893383
15 Affrime MB, Banfield C, Nolop K. Systemic bioavailability of inhaled corticosteriods: appropriate and comparable methodology. Eur Respir J. 2001;18(1):246. [Not a human study]11510799
16 Afilalo M, Guttman A, Colacone A, . Efficacy of inhaled steroids (beclomethasone dipropionate) for treatment of mild to moderately severe asthma in the emergency department: A randomized clinical trial. Ann Emerg Med. 1999 Mar;33(3):304–9. PMID: 10036345. [Not in the target population]10036345
17 Agarwal SK, Arshad N. Utility of high dose inhaled fluticasone therapy for the early management of acute exacerbations of asthma [Abstract]. European Respiratory Society; 2009 Sep 12–16; Vienna, Austra. E4352. [Not in the target population]
18 Agarwal SK, Sharma S. Effect of fluticasone/formoterol pressurized metered-dose inhaler (pMDI) in early management o facute exacerbations of asthma. Am J Respir Crit Care Med. 2010;181:A5659. [Not in the target population]
19 Agarwal SK, Sharma S. Utility of inhaled corticosteroids (fluticasone/formoterol) by pressurized metered-dse inhaler for the early management of acute exacerbations of asthma [Abstarct]. European Respiratory Society; 2010 Sep 18–22; Barcelona, Spain. E5476. [Not in the target population]
20 Agerroft L, Pedersen S. Comparison of lower leg growth rate in prepubertal children with mild asthma treated with inhaled placebo, ciclesonide, or fluticasone propionate. Allergy. 2007;62:131. [Not an intervention of interest]
21 Agerroft L, Pedersen S. Inhaled ciclesonide does not effect lower leg growth rate or HPA-axis function in children with mild asthma. Eur Respir J. 2004;24;Suppl 48:377. [Not an intervention of interest]
22 Agerroft L, Pedersen S. Lower-leg growth rate and APA-axis function in children with asthma during treatment with inhaled ciclesonide. J Allergy Clin Immunol. 2004;113;Suppl 2:S119. [Not an intervention of interest]
23 Agertoft L, Pedersen S. Bone mineral density in children with asthma receiving long-term treatment with inhaled budesonide. Am J Respir Crit Care Med. 1998 Jan;157(1):178–83. PMID: 9445297. [Excluded study design]9445297
24 Agertoft L, Pedersen S. Effects of long-term treatment with an inhaled corticosteroid on growth and pulmonary function in asthmatic children. Respir Med. 1994 May;88(5):373–81. PMID: 8036306. [Not an intervention of interest]8036306
25 Agertoft L, Pedersen S. Influence of inspiratory flow rate on plasma levels and lung deposition of fluticasone propionate inhaled from diskus dry powder inhaler. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 1264p. [Irretrievable]
26 Agertoft L, Pederson S. Long term growth in children with inhaled budesonide or nedocromil. Eur Respir J. 2000;16;Suppl 31:553. [Irretrievable]
27 Akhtaruzzaman M, Ahmed SU, Hoque MA, . Effects of nebulized budesonide as an adjunct to standard treatment of asthma exacerbations: A randomized, double-blind, placebo-controlled trial. Mymensingh Med J. 2014 Jul;23(3):418–25. PMID: 25178590. [Not in the target population]25178590
28 Akkoca O, Mungan D, Karabiyikoglu G, . Inhaled and systemic corticosteroid therapies: Do they contribute to inspiratory muscle weakness in asthma?. Respiration. 1999;66(4):332–7. PMID: 10461081. [Not an intervention of interest]10461081
29 Alangari AA, Malhis N, Mubasher M, . Budesonide nebulization added to systemic prednisolone in the treatment of acute asthma in children: A double-blind, randomized, controlled trial. Chest. 2014 Apr;145(4):772–8. PMID: 24384609. [Not in the target population]24384609
30 Aldridge RE, Hancox RJ, Cowan JO, . Eosinophils and eosinophilic cationic protein in induced sputum and blood: Effects of budesonide and terbutaline treatment. Ann Allergy Asthma Immunol. 2002 Nov;89(5):492–7. [Not an intervention of interest]12452208
31 Allen DB, Bronsky EA, LaForce CF, . Growth in asthmatic children treated with fluticasone propionate. J Pediatr. 1998 Mar;132(3 Pt 1):472–7. PMID: 9544904. [Not an intervention of interest]9544904
32 Allen DB. Effect of inhaled corticosteroids on growth. Pediatrics. 2001 Nov;108(5):1234–5. PMID: 11694712. [Not a human study]11694712
33 Allen DB. Sense and sensitivity: assessing inhaled corticosteroid effects on the hypothalamic-pituitary-adrenal axis. Ann Allergy Asthma Immunol. 2002 Dec;89(6):537–9. [Not a human study]12487216
34 Allen HD, Thong IG, Clifton-Bligh P, . Effects of high-dose inhaled corticosteroids on bone metabolism in prepubertal children with asthma. Pediatr Pulmonol. 2000 Mar;29(3):188–93. PMID: 10686039. [Not an intervention of interest]10686039
35 Al-Samri MT, Benedetti A, Prefontaine D, . Variability of sputum inflammatory cells in asthmatic patients receiving corticosteroid therapy: A prospective study using multiple samples. J Allergy Clin Immunol. 2010 May;125(5):1161,1163.e4. PMID: 20392486. [Not an intervention of interest]20392486
36 Altintas DU, Karakoc GB, Can S, . The effects of long term use of inhaled corticosteroids on linear growth, adrenal function and bone mineral density in children. Allergol Immunopathol (Madr). 2005 Jul–Aug;33(4):204–9. PMID: 16045858. [Not an intervention of interest]16045858
37 Amar NJ, Shekar T, Varnell T, . Mometasone furoate (MF) improves lung function in pediatric asthma: a dose-ranging study of MF metered-dose inhaler (MDI). J Allergy Clin Immunol. 2016;137;2 Suppl 1:AB214. Embase 72197450. [Not an intervention of interest]
38 Amirav I, Newhouse MT. Treatment failures in children with asthma due to inappropriate use of turbuhaler. J Pediatr. 2002;140(4):483. [Excluded study design]12006968
39 Anaev E, Chuchalin A. The efficiency of inhaled budesonide for patients with bronchila asthma. Eur Respir J. 2000;16;Suppl 31:279. [Excluded study design]
40 Anderson W, McFarlane L, Lipworth B. Prospective follow-up of novel bone turnover markers in asthmatics exposed to low or high doses of inhaled ciclesonide over 1 year. Eur Respir J. 2012 Sep 5;40;Suppl 56:P2100. Embase 71926472. [Not an intervention of interest]
41 Anderson WJ, McFarlane LC, Lipworth BJ. Prospective follow-up of novel markers of bone turnover in persistent asthmatics exposed to low and high doses of inhaled ciclesonide over 12 months. J Clin Endocrinol Metab. 2012 Jun;97(6):1929–36. PMID: 22438232. [Not an intervention of interest]22438232
42 Anderson WJ, Short PM, Williamson PA, . The FENOtype trial: inhaled corticosteroid dose-response using domiciliary exhaled nitric oxide in persistent asthma. Thorax. 2012;67;Suppl 2:A5. [Not an intervention of interest]
43 Angus R, Reagon R, Cheesbrough A. Short-acting beta 2-agonist and oral corticosteroid use in asthma patients prescribed either concurrent beclomethasone and long-acting beta 2-agonist or salmeterol/fluticasone propionate combination. Int J Clin Pract. 2005 Feb;59(2):156–62. PMID: 15854190. [Not an intervention of interest]15854190
44 Ankerst J, Malolepszy J, Eliraz A. Budesonide/formoterol in a single inhaler is more effective than a higher dose of inhaled corticosteroids in patients with persistent asthma. Eur Respir J. 2002;20;Suppl 38:387. [Not an intervention of interest]
45 Ankerst J, Persson G, Weibull E. A high dose of budesonide/formoterol in a single inhaler was well tolerated by asthmatic patients. Eur Respir J. 2000;16;Suppl 31:33. [Not an intervention of interest]
46 Ankerst J, Persson G, Weibull E. Cardiovascular effects of a high dose of the budesonide/formoterol single inhaler in asthmatic patients. Eur Respir J. 2001;18;Suppl 33:54. [Not an intervention of interest]
47 Ankerst J, Persson G, Weibull E. Tolerability of a high dose of budesonide/formoterol in a single inhaler in patients with asthma. Pulm Pharmacol Ther. 2003;16(3):147–51. PMID: 12749830. [Not an intervention of interest]12749830
48 Anthonisen NR. Step-down therapy in a asthma. Can Respir J. 2006 Apr;13(3):123–4. [Irretrievable]
49 Anthracopoulos MB, Papadimitriou A, Panagiotakos DB, . Growth deceleration of children on inhaled corticosteroids is compensated for after the first 12 months of treatment. Pediatr Pulmonol. 2007 May;42(5):465–70. PMID: 17394256. [Not an intervention of interest]17394256
50 Antonicelli L, Micucci C, Bonifazi F. Bronchospasm induced by inhalant corticosteroids: The role of ethanol. Allergy. 2006 Jan;61(1):146–7. PMID: 16364174. [Excluded study design]16364174
51 Apold J, Djoseland O. Inhaled beclomethasone dipropionate in the treatment of childhood asthma. Postgrad Med J. 1975;51(Suppl 4):104–5. PMID: 1105511. [Not an intervention of interest]1105511
52 Apold J, Djoseland O. Inhaled beclomethasone dipropionate in the treatment of childhood asthma. Postgrad Med J. 1975;51;Suppl 4:104–5. [Duplicate]1105511
53 Appel DW. Effect of aminophylline when added to metaproterenol sulfate and beclomethasone dipropionate aerosol. J Allergy Clin Immunol. 1984 Feb;73(2):291–7. PMID: 6699312. [Not an intervention of interest]6699312
54 Archer H, Creese K, Doull I, . Higher dose inhaled steroids in childhood asthma. Br Med J. 2001 Jun 06;322(7301):1546. [Not a human study]
55 Arend EE, Fischer GB, Debiasi M, . Inhaled corticosteroid treatment and growth of asthmatic children seen at outpatient clinics. J Pediatr (Rio J). 2006 May–Jun;82(3):197–203. PMID: 16773175. [Not an intervention of interest]16773175
56 Arshad H, Holgate ST. Effect of low doses of mometasone furoate (MF) dry powder inhaler (DPI) on adenosine monophosphate (AMP)-induced bronchoconstriction in asthma. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 2239p. [Irretrievable]
57 Arvidsson P, Larsson S, Lofdahl CG, . Inhaled formoterol during one year in asthma: A comparison with salbutamol. Eur Respir J. 1991 Nov;4(10):1168–73. PMID: 1687129. [Excluded study design]1687129
58 Aubier M, Buhl R, Ekstrom T, . Comparison of two twice-daily doses of budesonide/formoterol maintenance and reliever therapy. Eur Respir J. 2010 Sep;36(3):524–30. PMID: 20595145. [Not an intervention of interest]20595145
59 Aubier M, Buhl R, Haughney J, . Predictive factors for asthma control according to ACQ5 in asthma patients treated with budesonide/formoterol maintenance and reliever therapy. results from the EuroSMART study. Irish J Med Sci. 2010 Nov 6;179;Suppl 12:S474. DOI: 10.1007/s11845-010-0593-0. [Not an intervention of interest]
60 Aubier M, Haughney J, Selroos O, . Is the patient’s baseline inhaled steroid dose a factor for choosing the budesonide/formoterol maintenance and reliever therapy regimen? Therap adv respir dis. 2011 Oct;5(5):289–98. PMID: 21586508. [Not an intervention of interest]21586508
61 Ayres JG, Campbell LM. A controlled assessment of an asthma self-management plan involving a budesonide dose regimen. OPTIONS research group. Eur Respir J. 1996 May;9(5):886–92. PMID: 8793447. [Not an intervention of interest]8793447
62 Baba K, Hattori T, Koishikawa I, . Serum eosinophil cationic protein for predicting the prognosis of a step-down in inhaled corticosteroid therapy in adult chronic asthmatics. J Asthma. 2000 Aug;37(5):399–408. PMID: 10983617. [Excluded study design]10983617
63 Baba K, Sakakibara A, Yagi T, . Long-term observations of the clinical course after step down of corticosteroid inhalation therapy in adult chronic asthmatics: Correlation with serum levels of eosinophil cationic protein. Respirology. 2002 Sep;7(3):255–66. PMID: 12153692. [Not an intervention of interest]12153692
64 Bacci E, Novelli F, Bartoli ML, . Patients with moderate asthma symptoms may benefit from short term inhaled corticosteroid monotherapy. Eur Respir J. 2007;30;Suppl 51:615. [Not an intervention of interest]
65 Bacharier LB. “Step-down” therapy for asthma: why, when, and how? J Allergy Clin Immunol. 2002;109(6):916–9. [Not a human study]12063517
66 Bahçeciler NN, Barlan IB, Nuhoglu Y, . Risk factors for the persistence of respiratory symptoms in childhood asthma. Ann Allergy Asthma Immunol. 2001;86(4):449–55. [Not an intervention of interest]11345291
67 Bahna SL. Is it time to reduce our phobia of inhaled corticosteroids? Pediatrics. 2004 Jun;113(6):1813–4. PMID: 15173513. [Not a human study]15173513
68 Bajraktarevic A, Maglajlija S, Penava S, . Effectiveness of fluticasone propionate and rare adverse effects in preschoolers with asthma. Allergy. 2011;66;S94:584. [Not an intervention of interest]
69 Balanag VM, Yunus F, Yang P, . Budesonide/formoterol in a single inhaler is as effective and well tolerated as salbutamol in relieving aacute asthma in adults and adolescents. Eur Respir J. 2003l22;Suppl 45:Abstract P2836. [Not in the target population]
70 Balanag VM, Yunus F, Yang P, . Efficacy and safety of budesonide/formoterol compared with salbutamol in the treatment of acute asthma. Pulm Pharmacol Ther. 2006;19(2):139–47. PMID: 16009588. [Not in the target population]16009588
71 Balanzat A, Centanni S, Palmqvst M, . Budesonide/formterol single inhaler therapy reduces overreliance on rapid-acting reliever medication. Eur Respir J. 2004;24;Suppl 48:344. [Excluded study design]
72 Balter MS, Bell AD, Kaplan AG, . Management of asthma in adults. CMAJ. 2009 Dec;181(12):915–22. [Not a human study]19786471
73 Baraldi E, Rossi GA, Boner AL. Budesonide in preschool-age children with recurrent wheezing. N Engl J Med. 2012 Feb;366(6):570–1. [Not a human study]
74 Barnes N, Laviolette M, Allen D, . Effects of montelukast compared to double dose budesonide on airway inflammation and asthma control. Respir Med. 2007 Aug;101(8):1652–8. PMID: 17481879. [Not an intervention of interest]17481879
75 Barnes N, Price D, Colice G, . Asthma control with extrafine-particle hydrofluoroalkane-beclometasone vs. large-particle chlorofluorocarbon-beclometasone: A real-world observational study. Clin Exp Allergy. 2011 Nov;41(11):1521–32. PMID: 21752116. [Not an intervention of interest]21752116
76 Barnes PJ, O’Byrne PM, Rodriguez Roisin R, . Treatment of mild persisitent asthma with low doses of inhaled budesonide alone or in combination with formoterol. Thorax. 2000;55;Suppl 3:A4. [Not an intervention of interest]
77 Barnes PJ. A single inhaler for asthma? Am J Respir Crit Care Med. 2005 Jan;171(2):95–6. [Not a human study]15640369
78 Barnes PJ. Using a combination inhaler (budesonide plus formoterol) as rescue therapy improves asthma control. BMJ. 2007 Sep 8;335(7618):513. PMID: 17823193. [Not a human study]17823193
79 Barrueto L, Mallol J, Figueroa L. Beclomethasone dipropionate and salbutamol by metered dose inhaler in infants and small children with recurrent wheezing. Pediatr Pulmonol. 2002 Jul;34(1):52–7. PMID: 12112798. [Not an intervention of interest]12112798
80 Bateman ED, Bantje TA, Joao Gomes M, . Budesonide/formoterol in a single inhaler improves asthma control more effectively than a higher dose of fluticasone. Eur Respir J. 2001;18;Suppl 33:21. [Not an intervention of interest]
81 Bateman ED, Bantje TA, Joao Gomes M, . Early and sustained benefits of budesonide and formoterol in a single inhaler vs fluticasone in moderate asthma. Eur Respir J. 2001;18;Suppl 33:157. [Not an intervention of interest]11510788
82 Bateman ED, Bousquet J, Keech ML, . The correlation between asthma control and health status: The GOAL study. Eur Respir J. 2007 Jan;29(1):56–62. PMID: 17050557. [Not an intervention of interest]17050557
83 Bateman ED, Buhl R, O’Byrne PM, . Development and validation of a novel risk score for asthma exacerbations: the risk score for exacerbations. J Allergy Clin Immunol. 2015 Jun;135(6):1457,64.e4. PMID: 25258144. [Excluded study design]25258144
84 Bateman ED, Palmqvist M, Juniper EF, . Single inhaler therapy with budesonside/formoterol has superior efficacy to fixed-dose budesonide/formoterol or a higher dose of budesonide alone [Abstract]. American Thoracic Society International Conference; 2004 May 21–26; Orlando, FL. J75p. [Irretrievable]
85 Bauer K, Bantje TA, Sips AP, . The effect of inhaled fluticasone propionate FP, a new potent corticosteroid in severe asthma. Eur Respir J. 1988;1;Suppl 2:201. [Not an intervention of interest]
86 Baxter-Jones AD, Helms PJ, Russell G, . Early asthma prophylaxis, natural history, skeletal development and economy (EASE): A pilot randomised controlled trial. Health Technol Assess. 2000;4(28):1–89. PMID: 11074396. [Not an intervention of interest]11074396
87 Baxter-Jones AD, Helms PJ. Early introduction of inhaled steroids in wheezing children presenting in primary care. A pilot study. EASE study group. Clin Exp Allergy. 2000 Nov;30(11):1618–26. PMID: 11069572. [Not an intervention of interest]11069572
88 Bayiz H, Ozkaya S, Dirican A, . The rapid effects of budesonide plus formoterol in patients with obstructive airway diseases. Drug Des Devel Ther. 2015;9:5287–90. PMID: 26451084. [Excluded study design]26451084
89 Beasley R, Cushley M, Holgate ST. A self management plan in the treatment of adult asthma. Thorax. 1989 Mar;44(3):200–4. PMID: 2705150. [Excluded study design]2705150
90 Beasley R, Pavord I, Papi A, . Description of a randomised controlled trial of inhaled corticosteroid/fast-onset LABA reliever therapy in mild asthma. Eur Respir J. 2016 2016 Mar;47(3):981–4. [Not a human study]26846834
91 Beasley R, Sterk PJ, Kerstjens HAM, . Comparative studies of inhaled corticosteroids in asthma. Eur Respir J. 2001;17(4):579–80. [Not a human study]11401048
92 Becker AB, Paré PD. Wheezing in young children: WAITing for pharmacogenomics? Lancet Respir Med. 2014 Oct;2(10):776–7. [Not a human study]25239795
93 Becker AB. Asthma in the preschool child: still a rose by any other name? J Allergy Clin Immunol. 2008 Dec;122(6):1136–7. PMID: 19084109. [Not a human study]19084109
94 Beigelman A, King TS, Mauger D, . Do oral corticosteroids reduce the severity of acute lower respiratory tract illnesses in preschool children with recurrent wheezing?. J Allergy Clin Immunol. 2013;131(6):1518–1525.e14. DOI: 10.1016/j.jaci.2013.01.034. [Not an intervention of interest]23498594
95 Beigelman A, Zeiger RS, Mauger D, . The association between vitamin D status and the rate of exacerbations requiring oral corticosteroids in preschool children with recurrent wheezing. J Allergy Clin Immunol. 2013;133(5):1489–92.e3. [No outcomes of interest]
96 Bell A, McIvor RA. SMART therapy. CMAJ. 2006 Aug 1;175(3):276–7. PMID: 16880449. [Not a human study]16880449
97 Ben-Aryeh H, Berdicevsky I, Zinmann P, . Salivary composition and oral candida in asthmatic children and the effect of inhaled drugs. J Oral Med. 1985 Jul–Sep;40(3):123–6. PMID: 3928845. [Not an intervention of interest]3928845
98 Benbow AG, Naya IP. Patient compliance with inhaled medication: does combining beta-agonists with corticosteroids improve compliance?. Eur Respir J. 1994 Aug;7(8):1554. PMID: 7957846. [Not a human study]7957846
99 Bennati D, Piacentini GL, Peroni DG, . Changes in bronchial reactivity in asthmatic children after treatment with beclomethasone alone or in association with salbutamol. J Asthma. 1989;26(6):359–64. PMID: 2702243. [Not an intervention of interest]2702243
100 Berger WE, Ford LB, Mahr T, . Efficacy and safety of fluticasone propionate 250 microg administered once daily in patients with persistent asthma treated with or without inhaled corticosteroids. Ann Allergy Asthma Immunol. 2002 Oct;89(4):393–9. PMID: 12392384. [Not an intervention of interest]12392384
101 Berger WE, Leflein JG, Uryniak T, . Long term efficacy and resource utilization after treatment with budesonide and formoterol administered via one pressurized metered dose inhaler (pMDI) compared with budesonide dry powder inhaler (DPI) alone in children with asthma. J Allergy Clin Immunol. 2008;21;2 Suppl 1:S8. [Not an intervention of interest]
102 Berger WE, Noonan M, Weinstein SF, . Effect of inhaled mometasone furoate on the use of rescue medication in children aged 4–11 years with mild to moderate persistent asthma. J Allergy Clin Immunol. 2009;123;2 Suppl 1:S7. [Not an intervention of interest]
103 Berger WE, Qaqundah PY, Blake K, . Safety of budesonide inhalation suspension in infants aged six to twelve months with mild to moderate persistent asthma or recurrent wheeze. J Pediatr. 2005 Jan;146(1):91–5. PMID: 15644830. [Not an intervention of interest]15644830
104 Berglund E, Lofdahl CG, Svedmyr N. Dosing of inhaled corticosteroids and therapeutic goals in asthmatic patients. Eur J Respir Dis. 1984 Jul;65(5):319–20. PMID: 6745334. [Not a human study]6745334
105 Bernstein D, Nathan R, Ledford D, . Ciclesonide, a new inhaled corticosteroid, significantly improves asthma-related quality of life in patients with severe, persistent asthma. J Allergy Clin Immunol. 2005;115;2 Suppl:S210. [Not an intervention of interest]
106 Bernstein DI, Hebert J, Cheema A, . Efficacy and onset of action of mometasone furoate/formoterol and fluticasone propionate/salmeterol combination treatment in subjects with persistent asthma. Allergy Asthma Clin Immunol. 2011;7(1):21. [Not an intervention of interest]22152089
107 Bernstein DI, Rachelfsky G, Chrvinsky P, . Mometasone furoate dry powder inhaler improves pulmonary function in patients with persistent asthma previously using inhaled corticosteroids: efficacy analysis based on baseline FEV1 [Abstract]. Chest; 2002; San Diego, CA. P424p. [Not an intervention of interest]
108 Bielory L, Piccone F, Rabinowitz P, . Multicentre, randomised, parallel-group study of the efficacy and tolerability of flunisolide administered once daily via AeroChamber in the treatment of mild to moderate asthma. Clin Drug Investig. 2000;19(2):93–101. Embase 2000093460. [Not an intervention of interest]
109 Bilderback A, Krishnan JA, Riekert KA, . Patterns of use for oral montelukast and inhaled fluticasone in a clinical trial [Abstract]. American Thoracic Society International Conference; 2004 May 21–26; Orlando, Florida. C18p. [Irretrievable]
110 Bisgaard H, Gillies J, Groenewald M, . Efficacy of inhaled fluticasone propionate in the treatment of young children with asthmatic symptoms: a dose comparison study. Am J Respir Crit Care Med. 1998;157;Suppl 3:A711. [Not an intervention of interest]
111 Bisgaard H, Hermansen MN, Loland L, . Intermittent inhaled corticosteroids in infants with episodic wheezing. N Engl J Med. 2006 May 11;354(19):1998–2005. PMID: 16687712. [Not in the target population]16687712
112 Bisgaard H, Munck S, Nielsen JP, . Recurrent wheezing in children below 3 years treated with inhaled budesonide. Eur Respir J. 1990;3;Suppl 10:298. [Not an intervention of interest]
113 Bisgaard H, Munck SL, Nielsen JP, . Inhaled budesonide for treatment of recurrent wheezing in early childhood. Lancet (London, England). 1990 Sep 15;336(8716):649–51. PMID: 1975851. [Not an intervention of interest]1975851
114 Bisgaard H. Systemic activity of inhaled topical steroid in toddlers studied by knemometry. Acta Paediatr. 1993 Dec;82(12):1066–71. PMID: 8155929. [Not an intervention of interest]8155929
115 Black P. Inhaled steroid maintenance treatment of severe asthma. Lancet. 1993 Feb 13;341(8842):445–6. PMID: 8094218. [Not a human study]8094218
116 Bleecker ER, Bateman ED, Busse W, . Fluticasone furoate (FF), an inhaled corticosteroid (ICS), is efficacious in asthma patients symptomatic on low doses of ICS therapy [Abstract]. European Respiratory Society Annual Congress; 2010 Sep 18–22; Barcelona, Spain. P1167. [Not an intervention of interest]
117 Bloom J, Calhoun W, Koenig S, . Fluticasone propionate/salmeterol 100/50mcg is inhaled steroid sparing in patients who require fluticasone propionate 250mcg for asthma stability [Abstract]. American Thoracic Society 99th International conference; 2003; D034 Poster C33p. [Not an intervention of interest]
118 Bodzenta-Lukaszyk A, Buhl R, Balint B, . Fluticasone/formoterol combined in a single aerosol inhaler vs budesonide/formoterol for the treatment of asthma: A non-inferiority trial [Abstract]. European Respiratory Society Annual Congress; 2011 Sep 24–28; Amsterdam, The Netherlands. P894. [Not an intervention of interest]
119 Boskovska MI, Dokic D, Busletic Bozinovska K, . Concomitant use of low-dose inhaled corticosteroids and a long-acting bronchodilatator visavi doubling the dose of inhaled corticosteroid in asthma patients. Eur Respir J. 2001;18;Suppl 33:98. [Not an intervention of interest]
120 Bosman H G, van Uffelen R. Different effects of inhaled beclomethasone dipropionate and oral prednisone on bronchial hyperresponsiveness in asthma. Eur Respir J. 1990;3;Suppl 10:134. [Not an intervention of interest]
121 Boushey HA. Daily inhaled corticosteroid treatment should not be prescribed for mild persistent asthma. Am J Respir Crit Care Med. 2005 discusion 414–5; Aug 15;172(4):412–4. PMID: 16081554. [Not a human study]16081554
122 Bousquet J, Miravitlles M, Wiren A. Budesonide/formoterol provides better efficacy at a lower or similar cost as compared to high-dose salmeterol/fluticasone treatment. Eur Respir J. 2007;30;Suppl 51:193. [Excluded study design]
123 Boyter AC, Ford NH, Zlotos L. Audit of budesonide/formoterol prescribing for asthma in community pharmacy in the U.K Respir Med. 2011 Jun;105(6):864–8. PMID: 21227673. [Not an intervention of interest]21227673
124 Breath-actuated inhaler improves asthma control. Pharm J. 2001 Oct; 267(7169):497. [Not a human study]
125 Brenner BE, Chavda KK, Camargo CAJ. Randomized trial of inhaled flunisolide versus placebo among asthmatic patients discharged from the emergency department. Ann Emerg Med. 2000 Nov;36(5):417–26. PMID: 11054193. [Not in the target population]11054193
126 Bright P. High dose nebulized steroid in the treatment of chronic steroid dependent asthma. Respir Med. 1992 Nov;86(6):528–9. PMID: 1470714. [Not a human study]1470714
127 British Thoracic and Tuberculosis Association (BTTA), British Thoracic and Tuberculosis Association. Inhaled corticosteroids compared with oral prednisone in patients starting long-term corticosteroid therapy for asthma. Lancet. 1975;2(7933):469–73. [Not an intervention of interest]51284
128 Broder I, Tarlo SM, Davies GM, . Safety and efficacy of long-term treatment with inhaled beclomethasone dipropionate in steroid-dependent asthma. CMAJ. 1987 Jan 15;136(2):129–35. PMID: 3098400. [Excluded study design]3098400
129 Brodlie M, Gupta A, Rodriguez-Martinez CE, . Leukotriene receptor antagonists as maintenance or intermittent treatment in pre-school children with episodic viral wheeze. Paediatr Respir Rev. 2016 2016 Jan;17:57–9. [Not a human study]26628194
130 Bruce SA, Scherer YK. Maintenance and symptom relief with budesonide plus formoterol reduced severe asthma exacerbations. Evid Based Nurs. 2005;8:78. DOI: 10.1136/ebn.8.3.78. [Not a human study]16021707
131 Bruggenjurgen B, Selim D, Kardos P, . Economic assessment of adjustable maintenance treatment with budesonide/formoterol in a single inhaler versus fixed treatment in asthma. Pharmacoeconomics. 2005;23(7):723–31. PMID: 15987228. [Excluded study design]15987228
132 Budesonide hydrofluoroalkane inhalation - Chiesi. Drugs R D. 2003;4(1):37–8. [Not a human study]12568634
133 Budesonide turbuhaler for asthma. Med Lett Drugs Ther. 1998 Jan 16;40(1018):15–6. PMID: 9457158. [Not a human study]9457158
134 Budesonide/formoterol (symbicort) for asthma. Med Lett Drugs Ther. 2008 Feb;50(1279):9–11. [Not a human study]
135 Budesonide/formoterol improves asthma control. Can Respir J. 2001. 8:5;357–74. [Irretrievable]
136 Buhl R, Creemers JP, Vondra V, . Once daily symbicort (budesonide/eformoterol in a single inhaler) is effective in moderate-persistent asthma. Thorax. 2011;56;Suppl 3:iii62. [Not an intervention of interest]
137 Buhl R, Creemers JP, Vondra V, . Once-daily budesonide/formoterol via a single inhaler is effective in mild-to-moderate persistent asthma. Eur Respir J. 2001;18;Suppl 33:21. [Not an intervention of interest]
138 Buhl R, Haughney J, van Schayck OCP, . Switching asthma patients using high-dose inhaled steroids to budesonide/formoterol maintenance and reliever therapy [Abstract]. European Respiratory Society Annual Congress; 2010 Sep 18–22; Barcelona, Spain. P4565. [Not an intervention of interest]
139 Buhl R, Kardos P, Richter K, . The effect of adjustable dosing with budesonide/formoterol on health-related quality of life and asthma control compared with fixed dosing. Curr Med Res Opin. 2004 Aug;20(8):1209–20. PMID: 15324523. [Not an intervention of interest]15324523
140 Buhl R, Soler M, Matz J, . Omalizumab provides long-term control in patients with moderate-to-severe allergic asthma. Eur Respir J. 2002 Jul;20(1):73–8. PMID: 12166585. [Not an intervention of interest]12166585
141 Buhl R, Van Schayck O, Aubier M, . Impact of age, age at diagnosis and duration of asthma on the risk of exacerbations in the EuroSMART study. Eur Respir J. 2012 Sep;P2163. Embase 71926516. [Not an intervention of interest]
142 Buhl R, Vinkler I, Magyar P, . Comparable efficacy of ciclesonide once daily versus fluticasone propionate twice daily in asthma. Pulm Pharmacol Ther. 2006;19(6):404–12. PMID: 16310388. [Not an intervention of interest]16310388
143 Buhl R, Zetterstrom O, Mellem H, . Improved asthma control with budesonide/formoterol via a single inhaler compared with budesonide alone, in moderate persistent asthma. Eur Respir J. 2001;18;Suppl 33:48. [Not an intervention of interest]
144 Bukstein DA, Luskin AT, Bernstein A. “Real-world” effectiveness of daily controller medicine in children with mild persistent asthma. Ann Allergy Asthma Immunol. 2003 May;90(5):543–9. PMID: 12775136. [Excluded study design]12775136
145 Bulac S, Cimrin A, Ellidokuz H. The effect of beclometasone dipropionate/formoterol extra-fine fixed combination on the peripheral airway inflammation in controlled asthma. J Aerosol Med Pulm Drug Deliv. 2015 Apr;28(2):82–7. PMID: 25050594. [Not an intervention of interest]25050594
146 Bulow KB, Kalen N. Local and systemic effects of beclomethasone inhalation in steroid-dependent asthmatic patients. Curr Ther Res Clin Exp. 1974 Oct;16(10):1110–8. PMID: 4215621. [Excluded study design]4215621
147 Bulow KB, Kalen N. Local and systemic effects of beclomethasone inhalation in steroid-dependent asthmatic patients. Curr Ther Res Clin Exp. 1974 Oct;16(10):1110–8. PMID: 4215621. [Duplicate]4215621
148 Bush A, Grigg J, Saglani S. Managing wheeze in preschool children. BMJ (Online). 2014 Feb;348:Article Number g15. [Not a human study]
149 Bush A. Inhaled corticosteroid and children’s growth. Arch Dis Child. 2014 Mar;99(3):191–2. PMID: 24162008. [Not a human study]24162008
150 Bush A. Practice imperfect--treatment for wheezing in preschoolers. N Engl J Med. 2009 Jan 22;360(4):409–10. PMID: 19164192. [Not a human study]19164192
151 Busse W, Bleecker ER, Bateman ED, . Fluticasone furoate (FF), an inhaled corticosteroid (ICS), demonstrates efficacy in asthma patients symptomatic on moderate doses of ICS therapy [Abstract]. European Respiratory Society Annual Congress; 2010 Sep 18–22; Barcelona, Spain. P1168. [Not an intervention of interest]
152 Busse W, Kaliner M, Bernstein D, . The novel inhaled corticosteroid ciclesonide is effacious and has a favourable safety profile in adults and adolescents with severe persistent asthma. J Allergy Clin Immunol. 2005;115;Suppl 2:S213. [Not an intervention of interest]
153 Busse WW, Shah SR, Somerville L, . Comparison of adjustable- and fixed-dose budesonide/formoterol pressurized metered-dose inhaler and fixed-dose fluticasone propionate/salmeterol dry powder inhaler in asthma patients. J Allergy Clin Immunol. 2008 Jun;121(6):1407–14. PMID: 18455221. [Not an intervention of interest]18455221
154 Busse WW, Shah SR, Somerville L, . Comparison of asthma exacerbations and lung function with adjustable-dose budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI), fixed dose BUD/FM pMDI and fixed-dose fluticasone/salmeterol dry powder inhaler (FP/SM DPI)[Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. K2p. [Irretrievable]
155 Busse WW, Uryniak T. Efficacy of inhaled budesonide (Pulicort Tubuhaler(R)) in recent-onset moderate to severe persistent asthma. J Allergy Clin Immunol. 2004;113;Suppl 2:S119. [Not an intervention of interest]
156 Caballero-Fonseca F, Sanchez-Borges M. Adrenal suppression related to inhaled corticosteroids revisited. Chest. 2002 Sep;122(3):1103–4. PMID: 12226066. [Not a human study]12226066
157 Calhoun WJ. Physician-, biomarker-, and symptombased djustment of inhaled corticosteroids for asthma had similar effects. Ann Intern Med. 2013;158(2):JC6. [Not a human study]
158 Callén Blecua M, Aizpurua Galdeano P, Ozcoidi Erro I, . Inhaled corticosteroids and wheezing post-bronchiolitis. An Esp Pediatr. 2000;52(4):351–5. [Not an intervention of interest]11203411
159 Campusano L, Pastenes M, Fontecilla C, . Response to budesonide among atopic and non-atopic infants/preschoolers with recurrent wheezing. Allergol Immunopathol (Madr). 2010 Jan–Feb;38(1):31–6. PMID: 19875223. [Not an intervention of interest]19875223
160 Canonica GW, Castellani P, Cazzola M, . Adjustable maintenance dosing with budesonide/formoterol in a single inhaler provides effective asthma symptom control at a lower dose than fixed maintenance dosing. Pulm Pharmacol Ther. 2004;17(4):239–47. PMID: 15219269. [Not an intervention of interest]15219269
161 Cao EH, Tong MR, Tang XM, . Effects of inhaled budesonide on asthmatic patients. Journal Nanjin University. 1998;34(2):223–6. [No English language abstract]
162 Caramez MPR, Grunauer MA, Boueri FMV, . Effect of continuous inhaled beclomethasone for asthmatic pregnant patients on asthma control and perinatal outcome: a randomized controlled study. Am J Respir Crit Care Med. 1998;157;Suppl 3:A621. [Not an intervention of interest]
163 Carlsen K-, Gerritsen J. Inhaled steroids in children: adrenal suppression and growth impairment. Eur Respir J. 2002;19(6):985–8. [Not a human study]12108882
164 Carra S, Gagliardi L, Zanconato S, . Budesonide but not nedocromil sodium reduces exhaled nitric oxide levels in asthmatic children. Respir Med. 2001 Sep;95(9):734–9. PMID: 11575894. [Not an intervention of interest]11575894
165 Casale TB, Nelson HS, Corren J, . Long-term safety of flunisolide hydrofluoroalkane metered-dose inhaler in adults and adolescents with asthma. Clin Drug Invest. 2001;21(11):755–64. [Not an intervention of interest]
166 Castiller F, Trow TK. “Fine tuning” the use of inhaled steroids. Clin Pulm Med. 2005 Sep;12(5):324–6. [Not a human study]
167 Castro HP, Espino SR, Rodríguez Orozco AR. Budesonide (inhaled steroid) to children to control intermittent asthma. Rev Alerg Mex. 2009;56(1):9–12. [Not an intervention of interest]19374158
168 Cates C. Chronic asthma. BMJ. 2001 Oct 27;323(7319):976–9. PMID: 11679388. [Not a human study]11679388
169 Cazzola M, Curradi G. How to prevent relapse after acute exacerbation of asthma? Pol Arch Med Wewn. 2007;117(11–12):487–90. [Not a human study]18363246
170 Cazzola M, Matera MG. Lung blood flow must be considered when prescribing a long-acting beta2-agonist/inhaled corticosteroid combination. Chest. 2012 May;141(5):1134–6. PMID: 22553257. [Not a human study]22553257
171 Chalmers GW, MacLeod KJ, Little SA, . Cigarette smoking impairs the efficacy of inhaled corticosteroid in mild asthma. Annual Thoracic Society 97th International conference; 2001 May 18–23; San Francisco, CA. [Not an intervention of interest]
172 Chandra S. Health outcomes, education, healthcare delivery and quality-3057: randomized, double blind comparative study to assess safety, efficacy with mometasone & formoterol versus fluticasone & formoterol dry powder inhaler (DPI) in the treatment of mild to moderate persistent asthma. World Allergy Organ J. 2013;6;Suppl 2:P255. Embase 71252441. [Not an intervention of interest]
173 Chandra S. Randomized, double blind comparative study to assess safety, efficacy with mometasone & formoterol versus fluticasone & formoterol dry powder inhaler (DPI) in the treatment of mild to moderate persistent asthma. World Allergy Organ J. 2013;6;Suppl 2:P225. [Not an intervention of interest]
174 Chanez P, Karlstrom R, Godard P. High or standard initial dose of budesonide to control mild-to-moderate asthma?. Eur Respir J. 2001 May;17(5):856–62. PMID: 11488316. [Not an intervention of interest]11488316
175 Chao L-, Lin Y-, Wu W-, . Efficacy of nebulized budesonide in hospitalized infants and children younger than 24 months with bronchiolitis. Acta Paediatr Taiwan. 2003;44(6):332–5. [Not in the target population]14983653
176 Chapman KR, McIvor A. Asthma that is unresponsive to usual care. CMAJ. 2010;182(1):45–52. [Not a human study]19825927
177 Chapman KR. SMART isn’t. J Allergy Clin Immunol. 2010 Mar;125(3):609–10. PMID: 20226296. [Not a human study]20226296
178 Chatzimichail A, Pietrobelli A, Boner AL. Growth and adrenal suppression due to moderate- to high-dose inhaled fluticasone. J Paediatr Child Health. 2002 Dec;38(6):623. PMID: 12410884. [Excluded study design]12410884
179 Chavasse R, Bastian Lee Y, . Wheezing in infants with an atopic tendency responds to inhaled fluticasone. Thorax. 1999;54;Suppl 3:A7 S27. [Not an intervention of interest]
180 Chavasse R, Bastian Lee Y, Richter H, . Wheezing in infants responds to inhaled fluticasone. Am J Respir Crit Care Med. 2000;161;Suppl 3:A38. [Irretrievable]
181 Chay OM, Goh A, Lim WH, . Effects of inhaled corticosteroid on bone turnover in children with bronchial asthma. Respirology. 1999 Mar;4(1):63–7. PMID: 10339732. [Not an intervention of interest]10339732
182 Chen XH, Xia Y, Dong CC, . Therapeutic effect of salmeterol xinafoate and fluticasone propionate powder for inhalation in treatment of 50 moderate and severe asthma children. Zhongguo Xinyao yu Linchuang Zazhi. 2004;23(9):575–8. [Not an intervention of interest]
183 Cheng QJ, Huang SG, Chen YZ, . Formoterol as reliever medication in asthma: A post-hoc analysis of the subgroup of the RELIEF study in East Asia. BMC pulmonary medicine. 2016;Jan;16(1).8. PMID: 26758377. [duplicate]26758377
184 Cheng QJ, Huang SG, Chen YZ, . Formoterol as reliever medication in asthma: a post-hoc analysis of the subgroup of the RELIEF study in East Asia. BMC Pulmonary Medicine. 2016;Jan;16:8. PMID: 26758377 [not an intervention of interest]26758377
185 Chervinsky P, Baker J, Bensch G, . Improvement in health-related quality of life (HRQL) after use of budesonide (BUD) and formoterol (FM) in one pressurized metered-dose inhaler (pMDI) in adults with moderate to severe asthma [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. 617p. [Irretrievable]
186 Chetty A, Roy S, Sunderam KR. Beclomethasone dipropionate aerosol therapy in childhood asthma. Indian Pediatr. 1987 Jul;24(7):537–41. PMID: 3692582. [Excluded study design]3692582
187 Chhabra SK. A comparison of inhaled salbutamol with a combination of salbutamol and beclomethasone dipropionate in moderately severe asthma. Indian J Chest Dis Allied Sci. 1994;36(3):119–24. [Not an intervention of interest]7737699
188 Chipps B. Effect of inhaled glucocorticoids in childhood on adult height. Pediatrics. 2013;132;Suppl 1:S45. DOI: 10.1542/peds.2013-2294WWW. [Not a human study]
189 Chipps BE, Bacharier LB, Harder JM. Phenotypic expressions of childhood wheezing and asthma: implications for therapy. J Pediatr. 2011;158(6):878–884.e1. [Not a human study]21429508
190 Chkhaidze I, Kherkheulidze M, Kavlashvili N, . Non-viral wheezing in preschool children: The effect of inhaled fluticasone on symptoms and lung function. Georgian Med News. 2006PMID: 16575135. [Not an intervention of interest]16575135
191 Chlumský J, Striz I, Terl M, . Strategy aimed at reduction of sputum eosinophils decreases exacerbation rate in patients with asthma. J Int Med Res. 2006;34(2):129–39. [Not an intervention of interest]16749408
192 Chong SL, Hsu AA. Not all that wheezes is asthma. Ann Acad Med Singapore. 2014 Oct;43(10):519–20. [Excluded study design]25434625
193 Chowdhury BA. Ciclesonide inhalation aerosol for persistent asthma. J Allergy Clin Immunol. 2006 May;117(5):1194–5. PMID: 16675356. [Not a human study]16675356
194 Chronic asthma. MeReC Brief. 2002;18:1–5. [Irretrievable]
195 Chuchalin AG, Molostova TN. Efficacy of budesonide in bronchial asthma patients assessed by a double-blind crossover placebo-controlled method. Klin Farmakologiia Terapiia. 1999: 23–6p. [Irretrievable]
196 Ciclesonide (alvesco)-a new inhaled corticosteroid for asthma. Med Lett Drugs Ther. 2008 Sep 22;50(1295):75–6. PMID: 18800024. [Not a human study]18800024
197 Ciclesonide. Aust Prescr. 2005 Aug;28(4):106. [Not a human study]
198 Ciclesonide. Drugs R D. 2002;3(6):407–10. [Not a human study]12516947
199 Ciclesonide: Novel asthma treatment. WHO Drug Inf. 2004;18(3):225. [Not a human study]
200 Cimrin AH, Sevinc C, Ellidokuz H, . Is withdrawal of inhaled corticosteroid therapy possible in stable mild-moderate persistent bronchial asthma cases? A randomised controlled study. Eur Respir J. 2000;16;Suppl 31:93. [Irretrievable]
201 Cisneros C, Quiralte J, Capel M, . Cost-effectiveness analysis of budesonide/formoterol in the maintenance treatment and as-needed (Symbicort SMART) versus salmeterol/fluticasone plus terbutaline in the treatment of persistent asthma in Spain. Pharmacoeconomics. 2010;7(4):163–75. [Excluded study design]
202 Clark TJ. Inhaled steroid aerosols and alternate-day prednisone. Lancet. 1979 May 5;1(8123):970–1. PMID: 87630. [Not a human study]87630
203 Clarke GW, Greenaway SD, James WY, . The acute effect of inhaled steroids on airway mucosal flow in asthma [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. B60p. [Irretrievable]
204 Clavenna A, Sequi M, Cartabia M, . Effectiveness of nebulized beclomethasone in preventing viral wheezing: An RCT. Pediatrics. 2014 Mar;133(3):e505–12. PMID: 24534400. [Not in the target population]24534400
205 Cochran D. Diagnosing and treating chesty infants. A short trial of inhaled corticosteroid is probably the best approach. BMJ. 1998 May 23;316(7144):1546–7. PMID: 9596586. [Not a human study]9596586
206 Cockcroft DW, Davis BE, Swystun VA. Salmeterol, inhaled corticosteroids, and tolerance to allergen bronchoprotection. Chest. 1999 Nov;116(5):1497–8. PMID: 10559129. [Not a human study]10559129
207 Combined oral, inhaled steroids prevent relapse in acute asthma. Healthc Demand Dis Manag. 1999 Aug;5(8):123–5. PMID: 10557952. [Not a human study]10557952
208 Connett G, Lenney W. Prevention of viral induced asthma attacks using inhaled budesonide. Arch Dis Child. 1993 Jan;68(1):85–7. PMID: 8435016. [No outcomes of interest]8435016
209 Convery RP, Leitch DN, Bromly C, . Effect of inhaled fluticasone propionate on airway responsiveness in treatment-naive individuals--a lesser benefit in females. Eur Respir J. 2000 Jan;15(1):19–24. PMID: 10678615. [Not in the target population]10678615
210 Corren J, Korenblat PE, Miller CJ, . Comparative assessment of asthma control with budesonide and formoterol in one pressurized metered dose inhaled (pMDI) versus budesonide and formoterol in individual inhalers and placebo. J Allergy Clin Immunol. 2007;119;Suppl 1:S248. [Not an intervention of interest]
211 Cortese S, Gatta A, Della Valle L, . Fluticasone/formoterol association favors long-lasting decrease in bronchial reactivity to methacholine and weekly PEF variability. International Journal of Immunopathology & Pharmacology. 2016;Dec;29(4):769–774. PMID: 27272161 [no outcomes of interest]27272161
212 Corticosteroid therapy for wheezy infants. Indian Pediatr. 2006 Jul;43(7):662. [Not a human study]
213 Cote J, Cartier A, Robichaud P, . Influence on asthma morbidity of asthma education programs based on self-management plans following treatment optimization. Am J Respir Crit Care Med. 1997 May;155(5):1509–14. PMID: 9154850. [Not an intervention of interest]9154850
214 Crim C, Scott CA, Maden CJ, . Fluticasone propionate administered via metered-dose inhaler with valved holding chamber and attached face-mask is effective in improving asthma control by producing at least a 2-step improvement in asthma staging in preschool age children with asthma. J Allergy Clin Immunol. 2004;113;Suppl 2:S118. [Not an intervention of interest]
215 Crimi N, Polosa R, Prosperini G, . Inhaled beclomethasone attenuates bronchial reactivity to neurokinin a (NKA) and histamine in asthma. Eur Respir J. 1996;9;Suppl 23:33. [Not an intervention of interest]8834330
216 Csonka P, Mertsola J, Klaukka T, . Corticosteroid therapy and need for hospital care in wheezing preschool children. Eur J Clin Pharmacol. 2000 Nov;56(8):591–6. PMID: 11151750. [Not in the target population]11151750
217 Currie GP, Douglas JG, Heaney LG. Difficult to treat asthma in adults. BMJ (Online). 2009 Mar;338(7694):593–7. [Not a human study]
218 Currie GP, Small I, Douglas G. Long acting β2 agonists in adult asthma. BMJ (Online). 2013 Oct;347(7927):Article Number f4662. [Not a human study]
219 Currie GP. Why SMART about second-line treatment when first-line treatment is being ignored?. Chest. 2006 Sep;130(3):929. PMID: 16963701. [Not a human study]16963701
220 Curtiss FR. Asthma disease management - evidence-based medicine must be dynamic. J Managed Care Pharm. 2006;12(1):80–2. [Not a human study]
221 Curtiss FR. More evolution of the evidence in asthma disease management--SMART versus GOAL clinical trials debate the cost-benefit of LABA while the value of leukotriene modifiers, particularly montelukast, is uncertain. J Manage Care Pharm. 2006 May;12(4):343–6. PMID: 16792441. [Not a human study]16792441
222 Dahl R, Johansson SA. Effect on lung function of budesonide by inhalation, terbutaline s.c. and placebo given simultaneously or as single treatments. Eur J Respir Dis Suppl. 1982;122:132–7. PMID: 6958477. [Not an intervention of interest]6958477
223 Dahl R, Pedersen B, Hagglof B. Nocturnal asthma: effect of treatment with oral sustained-release terbutaline, inhaled budesonide and the two in combination. Eur Respir J. 1988;1;Suppl 2:339. [Not an intervention of interest]
224 Dal Negro R, Micheletto C, Ciani F, . Efficacy and safety of inhaled beclomethasone dipropionate dry powder in the treatment of chronic asthma: a controlled study vs. budesonide. Eur Respir J. 1998;12;Suppl 28:351. [Not an intervention of interest]9727784
225 Danov Z, Guilbert T. Regular use of inhaled corticosteroids controls symptoms of mild persistent asthma, but with growth effect. J Pediatr. 2009 Jan;154(1):150. [Not a human study]
226 Daugbjerg P, Brenoe E, Forchhammer H, . A comparison between nebulized terbutaline, nebulized corticosteroid and systemic corticosteroid for acute wheezing in children up to 18 months of age. Acta Paediatr. 1993 Jun–Jul;82(6–7):547–51. PMID: 8338988. [Not in the target population]8338988
227 Davies G, Thomas P, Broder I, . Steroid-dependent asthma treated with inhaled beclomethasone dipropionate. A long-term study. Ann Intern Med. 1977 May;86(5):549–53. PMID: 322562. [Not an intervention of interest]322562
228 De Benedictis FM, Boner A, Cavagni G, . Treating asthma in children with beclomethasone dipropionate: Pulvinal versus diskhaler. J Aerosol Med. 2000;13(1):35–41. PMID: 10947322. [Not an intervention of interest]10947322
229 De Benedictis FM, Del Giudice MM, Vetrella M, . Nebulized fluticasone propionate vs. budesonide as adjunctive treatment in children with asthma exacerbation. J Asthma. 2005 Jun;42(5):331–6. PMID: 16116682. [Not an intervention of interest]16116682
230 de Blic J, Delacourt C, Le Bourgeois M, . Efficacy of nebulized budesonide in treatment of severe infantile asthma: A double-blind study. J Allergy Clin Immunol. 1996 Jul;98(1):14–20. PMID: 8765813. [Not an intervention of interest]8765813
231 de Jongste JC, Carraro S, Hop WC, . Daily telemonitoring of exhaled nitric oxide and symptoms in the treatment of childhood asthma. Am J Respir Crit Care Med. 2009 Jan 15;179(2):93–7. PMID: 18931330. [Not an intervention of interest]18931330
232 De Marzo N, Maestrelli P, Saetta M, . Management of occupational asthma induced by toluene diisocyanate (TDI) effect of removal from exposure and long term treatment with inhaled beclomethasone dipropionate (BPD). Eur Respir J. 1992;5;Suppl 15:111. [Not an intervention of interest]
233 De Vries MP, Van den Bemt L, Aretz K, . House dust mite allergen avoidance and self-management in allergic patients with asthma: randomised controlled trial. Br J Gen Pract. 2007;57(536):184–90. [Not an intervention of interest]17359604
234 de Vries MP, van den Bemt L, Thoonen BPA, . Relationship between house dust mite (HDM) allergen exposure level and inhaled corticosteroid dosage in HDM-sensitive asthma patients on a self management program. Prim Care Respir J. 2006 Apr;15(2):110–5. PMID: 16701770. [Not an intervention of interest]16701770
235 Decimo F, Maiello N, Miraglia Del Giudice M, . High-dose inhaled flunisolide versus budesonide in the treatment of acute asthma exacerbations in preschool-age children. Int J Immunopathol Pharmacol. 2009 Apr–Jun;22(2):363–70. PMID: 19505390. [Not in the target population]19505390
236 Del Donno M, Foresi A, Chetta A, . Effect of six week treatment with low dose of inhaled fluticasone propionate on airway inflammation in mild asthma. Eur Respir J. 1995;8;Suppl 19:302. [Not an intervention of interest]
237 del-Rio-Navarro BE, Corona-Hernandez L, Fragoso-Rios R, . Effect of salmeterol and salmeterol plus beclomethasone on saliva flow and IgA in patients with moderate-persistent chronic asthma. Ann Allergy Asthma Immunol. 2001 Nov;87(5):420–3. PMID: 11730186. [Not an intervention of interest]11730186
238 Demay MCR, Magny JP, Idrès N, . Use of the low-dose corticotropin stimulation test for the monitoring of children with asthma treated with inhaled corticosteroids. Horm Res. 2006;66(2):51–60. [Not an intervention of interest]16714852
239 Derom E, Louis R, Tiesler C, . Comparison of systemic and clinical effects of inhaled ciclesonide and fluticasone propionate in moderate to severe asthma [Abstract]. Americna Thoracic Society International Conference; 2008 May 16–21; Toronto, Canada. A50p. [Not an intervention of interest]
240 Deslandes B, Lim J, Staudinger H. Efficacy and safety of azmacort MDI and flovent diskhaler. J Allergy Clin Immunol. 1998 Jul;102(1):154–5. PMID: 9679864. [Not a human study]9679864
241 Devoy M. Use of inhaled corticosteroids in children. Arch Dis Child. 2003 May;88(5):461. PMID: 12716732. [Not a human study]12716732
242 Di Franco A, Bacci E, Bartoli ML, . Inhaled fluticasone propionate is effective as well as oral prednisone in reducing sputum eosinophilia during exacerbations of asthma which do not require hospitalization. Pulm Pharmacol Ther. 2006;19(5):353–60. PMID: 16289980. [Not an intervention of interest]16289980
243 DiSantostefano RL, Boudiaf N, Stempel DA, Barnes NC, Greening AP. The frequency of, and adherence to, single maintenance and reliever therapy instructions in asthma: a descriptive analysis. NPJ Primary Care Respiratory Medicine. 2016;July;26:16038. PMID: 27442488 [no outcomes of interest]27442488
244 Dixit R, Dixit K, Sharma S, . Adrenal suppression and its pattern with high dose inhaled budesonide and fluticasone propionate in adult asthmatic patients. Chest. 2007;132(4):505a. [Not an intervention of interest]
245 Djordjevic DD, Stankovic IJ, Rancic MH, . Inhaled corticosteroids in treatment of patients with intermittent bronchial asthmla, yes or no? Eur Respir J. 2005;26;Suppl 49: Abstract No 3288. [Not in the target population]
246 Dogra P, Kajal NC, Bhushan B, . To study the effect of inhaled fluticasone verses montelukast as treatment of persistent asthma. Chest. 2006;130(4):109s. [Not an intervention of interest]
247 Dombrowski MP, Schatz M, Wise R, . Inhaled beclomethasone and oral theophylline were similarly effective in pregnant women with moderate asthma. Evid -based Obstet Gynecol. 2005 Mar;7(1):11–2. [Not a human study]
248 Domingo C. Ultra-LAMA, ultra-LABA, ultra-inhaled steroids? the future has landed. Arch Bronconeumol. 2013 Apr;49(4):131–4. PMID: 23415574. [Not a human study]23415574
249 Dorinsky P, Yancey S, Reilly D, . Long-term effectiveness of the fluticasone propionate/salmeterol (FSC) 100/50mcg combination product as an inhaled corticosteroid sparing. J Allergy Clin Immunol. 2003;11(2):S125. [Not an intervention of interest]
250 Dorow P, Thalhofer S. Inhaled beclomethasone (BDP) versus oral theophylline: a 12 month study in patients with bronchial asthma. Eur Respir J. 1990;3;Suppl 10:91. [Not an intervention of interest]2311736
251 Dos Santos LZM, Soares CG, Filho WR. Oral montelukast versus inhaled beclomethasone in the prophylactic treatment of post acute viral bronchiolitis wheezing. World Allergy Organ J. 2014;8;Suppl 1:A128. DOI: 10.1186/1939-4551-8-S1-A128. [Not an intervention of interest]
252 Dose-effect of inhaled corticosteroid on growth rates of children. Drug Ther Bull. 2014;52(10):111. [Not a human study]
253 Doubling the dose of inhaeled corticosteroid ineffective when asthma control is detiorating. AJP. 2004;85(1011):457. [Not a human study]
254 Drake AJ, Howells RJ, Shield JPH, . Symptomatic adrenal insufficiency presenting with hypoglycaemia in children with asthma receiving high dose inhaled fluticasone propionate. BMJ. 2002 May 4;324(7345):1081–2. PMID: 11991916. [Excluded study design]11991916
255 Dreyer EB. Inhaled steroid use and glaucoma. N Engl J Med. 1993 Dec 9;329(24):1822. PMID: 8232507. [Excluded study design].8232507
256 Drollman A, Langdon C, Engelst A, . Ciclesonide is effective in the treatment of bronchial asthma. Eur Respir J. 2001;18;Suppl 33:95. [Not an intervention of interest]
257 du Toit JI, Salome CM, Woolcock AJ. Short term effects of inhaled corticosteroids on bronchial hyperresponsiveness. Aust NZ J Med Suppl. 1986;16(4):627. [Not an intervention of interest]
258 Dubus J, Mely L, Huiart L, . Cough after inhalation of corticosteroids delivered from spacer devices in children with asthma. Fundam Clin Pharmacol. 2003 Oct;17(5):627–31. PMID: 14703724. [Excluded study design]14703724
259 Ducharme FM. Continuous versus intermittent inhaled corticosteroids for mild persistent asthma in children: Not too much, not too little. Thorax. 2012 Feb;67(2):102–5. [Not a human study]21998124
260 Dukes EM, Kemp J, Tinkelman D, . The impact of budesonide inhalation suspension BIS on the health status of young children with asthma. Ann Allergy Asthma Immunol. 1999:82;124. [Irretrievable]
261 Duong-Quy S, Hua-Huy T, Doan-Quynh N, . A study of exhaled NO (FENO) measurement used to determine asthma control, dose of inhaled corticosteroid and cost in a developing country. Eur Respir J. 2015;46:PA5013. DOI: 10.1183/13993003.congress2015.PA5013. [Not an intervention of interest]
262 Durmaz C, Asilsoy S, Usta Guc B. Efficacy of nebulised budesonide in infants with viral wheezing. Allergy. 2011;6;Suppl 94:563–4. DOI: 10.1111/j.1398-9995.2011.02608.x. [Abstract without full-text]
263 Durzo A, Hebrt JR, Kunkel G, . Mometasone furoate (MF) therapy improves plmonary function in patients previously maintained on high doses of inhaled corticosteroids (ICS). Eur Respir J. 2000;16;Suppl 31:338. [Irretrievable]
264 Dutu S, Stoicescu P, Bistriceanu G, . Clinical management of bronchial asthma with inhaled high-dose beclomethasone dipropionate (beclomet 250--orion). Pneumoftiziologia. 1991 Jul–Sep;40(3):46–7. PMID: 1841740. [Excluded study design]1841740
265 Dykewicz MS. Asthma treatment with inhaled corticosteroids versus antileukotrienes: What exhaled nitric oxide studies do and do not tell us. Ann Allergy Asthma Immunol. 2001 Oct;87(4):257–60. PMID: 11686416. [Not a human study]11686416
266 Edelman JM, Ghannam A, Bird S, . Onset of action of montelukast and inhaled beclomethasone in achieving asthma control. Am J Respir Crit Care Med. 2000;161;Suppl 3:A202. [Irretrievable]
267 Edelman JM. Rescue-free days in patients with mild persistent asthma receiving montelukast sodium or an inhaled corticosteroid [abstract]. European Respiratory Society Annual Congress; 2002; Stockholm, Sweden. 771. [Irretrievable]
268 Edin HM, Payne E, Herrle MR, . Salmeterol/Fluticasone Propionate combination via HFA MDI improves quality of life in asthma patients. J Allergy Clin Immunol. 2001;107(2):S246. [Not an intervention of interest]
269 Edmonds ML, Rowe BH. Treatment with inhaled flunisolide. Chest. 2004 May;125(5):1961–2. PMID: 15136418. [Not a human study]15136418
270 Edsbacker S, Thorsson L. Fluticasone and asthma. Lancet. 2001 Mar 10;357(9258):804. PMID: 11253999. [Not a human study]11253999
271 Eigen H. Differential diagnosis and treatment of wheezing and asthma in young children. Clin Pediatr. 2008 Oct;47(8):735–43. [Not a human study]
272 Ekroos H, Lindqvist A, Saarinen A, . Significant association with the decrease of bronchial hyperresponsiveness and the decrease of exhaled nitric oxide after starting inhaled fluticasone in mild asthma. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 1213p. [Irretrievable]
273 Eliraz A, Fritscher CC, Perez CMR, . Budesonide and formoterol in a single inhaler quickly gains asthma control compared with fluticasone propionate in mild asthma. Eur Respir J. 2001;18;Suppl 33:48. [Not an intervention of interest]
274 Emin O, Fatih M, Mustafa O, . Evaluation impact of long-term usage of inhaled fluticasone propionate on ocular functions in children with asthma. Steroids. 2011 May;76(6):548–52. PMID: 21335020. [Excluded study design]21335020
275 Ermers MJJ, Rovers MM, van Woensel JB, . The effect of high dose inhaled corticosteroids on wheeze in infants after respiratory syncytial virus infection: Randomised double blind placebo controlled trial. BMJ. 2009;338:b897. PMID: 19336497. [Not in the target population]19336497
276 Estelle F, Simons R. The benefits of long-term inhaled glucocorticosteroid treatment in children with asthma outweigh the risks. Pediatr Res. 2001;49(3):315–6. [Not a human study]11228253
277 Fabbri LM. Does mild persistent asthma require regular treatment?. N Engl J Med. 2005 Apr 14;352(15):1589–91. PMID: 15829540. [Not a human study]15829540
278 Farah CS, King GG, Brown NJ, . Ventilation heterogeneity predicts asthma control in adults following inhaled corticosteroid dose titration. J Allergy Clin Immunol. 2012 Jul;130(1):61–8. PMID: 22460065. [Excluded study design]22460065
279 FitzGerald JM, Boulet L, Follows RMA. The CONCEPT trial: A 1-year, multicenter, randomized, double-blind, double-dummy comparison of a stable dosing regimen of salmeterol/fluticasone propionate with an adjustable maintenance dosing regimen of formoterol/budesonide in adults with persistent asthma. Clin Ther. 2005 Apr;27(4):393–406. PMID: 15922813. [Not an intervention of interest]15922813
280 FitzGerald JM, Sears MR, Boulet L, . Adjustable maintenance dosing with budesonide/formoterol reduces asthma exacerbations compared with traditional fixed dosing: A five-month multicentre canadian study. Can Respir J. 2003 Nov–Dec;10(8):427–34. PMID: 14679407. [Not an intervention of interest]14679407
281 FitzGerald JM, Shragge D, Haddon J, . A randomized, controlled trial of high dose, inhaled budesonide versus oral prednisone in patients discharged from the emergency department following an acute asthma exacerbation. Can Respir J. 2000 Jan–Feb;7(1):61–7. PMID: 10700672. [Not in the target population]10700672
282 FitzGerald JM. Effect of inhaled formoterol and budesonide on exacerbations of asthma. N Engl J Med. 1998 Apr 9;338(15):1071–2. PMID: 9537879. [Not a human study]9537879
283 Fitzpatrick AM, Jackson DJ, Mauger DT, Boehmer SJ. Individualized therapy for persistent asthma in young children. Journal of Allergy & Clinical Immunology. 2016;Dec 138(6):1608–1618.e12. PMID: 27777180 [no outcomes of interest]27777180
284 Fleming L, Wilson N, Regamey N, . Use of sputum eosinophil counts to guide management in children with severe asthma. Thorax. 2012 Mar;67(3):193–8. PMID: 21825081. [Not an intervention of interest]21825081
285 Fluticason furoate (arnuity ellipta) for asthma. Med Lett Drugs Ther. 2015 May 25;57(1469):76–9. PMID: 25989197. [Not a human study]25989197
286 Fluticasone linked to adrenal crisis. Pharm J. 2002 2002/11;269(7226):770. [Not a human study]
287 Fluticasone/salmeterol: New indications not justified. Prescrire Int. 2008;17(98):229. [Not a human study]19418648
288 Foresi A, Pelucchi A, Dorini S, . Effect of low and high dose inhaled fluticasone propionate fp in symptomatic asthma. Annual Thoracic Society 97th International Conference; 2001 May 18–23; San Francisco, CA. A519. [Not an intervention of interest]
289 Fox GF, Everard ML, Marsh MJ, . Randomised controlled trial of budesonide for the prevention of post-bronchiolitis wheezing. Arch Dis Child. 1999 Apr;80(4):343–7. PMID: 10086941. [Not in the target population]10086941
290 Francis RS, McEnery G. Disodium cromoglycate compared with beclomethasone dipropionate in juvenile asthma. Clin Allergy. 1984 Nov;14(6):537–40. PMID: 6439430. [Not an intervention of interest]6439430
291 Francis RS, McEnery G. Disodium cromoglycate compared with beclomethasone dipropionate in juvenile asthma. Clin Allergy. 1984;14(6):537–40. [Not an intervention of interest]6439430
292 Freed-Martens R, Anderson SD, Brannan JD. Effect of treatment on recovery of FEV1 to baseline after a mannitol challenge: a phase 3 study. Respirology. 2005;10;Suppl;A1. [Not an intervention of interest]15725117
293 Fritsch M, Uxa S, Horak F, . Exhaled nitric oxide in the management of childhood asthma: a prospective 6-months study. Pediatr Pulmonol. 2006 Sep;41(9):855–62. PMID: 16850457. [Not an intervention of interest]16850457
294 Fukuoka J. Different responses of morning dipping and nocturnal dipping to inhaled and/or oral steroids in chronic asthmatics. Nihon Kyobu Shikkan Gakkai Zasshi. 1994 Aug;32(8):731–8. [Not an intervention of interest]7807751
295 Gajanan SG. Inhaled corticosteroids in childhood bronchial asthma. Natl Med J India. 1993 Mar–Apr;6(2):76–7. PMID: 8477214. [Not a human study]8477214
296 Galant S, Gode Sellers S, Kalberg C, . Low dose inhaled fluticasone propionate provides greater improvement in pulmonary function as compared to montelukast in patients with persistent asthma. J Allergy Clin Immunol. 2001;107(2):S106. [Not an intervention of interest]
297 Galant S, Miller CJ, Mezzanotte WS, . Efficacy of budesonide inhalation suspension (pulmicort respules) in children with asthma previously treated with inhaled corticosteroids or other daily medications. J Allergy Clin Immunol. 2002;109;Suppl 1:S241. [Not an intervention of interest]
298 Garay SM, Bensch GW, Lockey RF. Rapid reduction of nocturnal awakenings with inhaled mometasone furoate in adults with mild to moderate persistent asthma [Abstract]. American Thoracic Society International Conference; 2008 May 16–21; Toronto, Canada. A52p. [Not an intervention of interest]
299 Garrett J, Williams S, Wong C, . Treatment of acute asthmatic exacerbations with an increased dose of inhaled steroid. Arch Dis Child. 1998 Jul;79(1):12–7. PMID: 9771245. [No outcomes of interest]9771245
300 Geddes DM. Inhaled budesonide for mild asthma. N Engl J Med. 1995 Mar 9;332(10):683–4. PMID: 7845439. [Not a human study]7845439
301 Gelfand EW, Gallegos CM, Silveira LJ, . Effect of the Inhaled Corticosteroid Mometasone Furoate on Small Airway Patency in Patients with Asthma. J Allergy Clin Immunol. 2009;123;2 Suppl 1:S77. [Not an intervention of interest]
302 Gerald JK, Gerald LB, Chinchilli VM, . Adherence to rescue inhaled corticosteroid use during the TREXA trial. Am J Respir Crit Care Med. 2012;185;Meeting Abstracts:A2200. Embase 71986726. [Duplicate]
303 Ghosh CS, Joseraj R, Kumari A, . A randomized controlled clinical trial comparing the effects of inhaled budesonide vs. inhaled ipratropium bromide in patients with bronchiectasis. Indian J Allergy Asthma Immunol. 2002;16(1):67. [Not in the target population]
304 Giannini D, Di Franco A, Bacci E, . Different doses of inhaled fluticasone propionate fp in the management of moderate asthmatic subjects. Annual Thoracic Society 97th International Conference; 2001 May 13–23; San Francisco CA. A517. [Not an intervention of interest]
305 Glassroth J. Use of long-acting β-agonists and inhaled corticosteroids [7]. Ann Intern Med. 2006 Nov;145(9):710. [Not a human study]
306 Gleeson JG, Price JF. Controlled trial of budesonide given by the nebuhaler in preschool children with asthma. BMJ. 1988 Jul 16;297(6642):163–6. PMID: 3044506. [Not an intervention of interest]3044506
307 Godfrey S, Avital A, Rosler A, . Nebulised budesonide in severe infantile asthma. Lancet. 1987 Oct 10;2(8563):851–2. PMID: 2889046. [Excluded study design]2889046
308 Gogtay JA, Balki A, Dalal S, . Efficacy and tolerability of a new HFA-propelled fluticasone/formoterol combination inhaler compared to budesonide/formoterol combination in subjects with moderate to persistent asthma. Chest. 2010;138(4):161A. [Not an intervention of interest]
309 Gold DR, Fuhlbrigge AL. Inhaled corticosteroids for young children with wheezing. N Engl J Med. 2006 May 11;354(19):2058–60. PMID: 16687719. [Not a human study]16687719
310 Gomez Tejada RA, Finkelstein CN, Gene RJ. Inhaled corticosteroids and asthma education. Medicina. 1998;58(6):692–8. [Not an intervention of interest]10347961
311 Gonzalez PYE, Ruiz BA, Garate AJ, . A multicenter randomized, open, parallel group study comparing different treatments for hospitalized infants with acute wheezy bronchitis. An Esp Pediatr. 1994;41(5):315–9. [Not an intervention of interest]
312 Goodman DC. When an asthma drug has an inferiority complex: a noninferiority trial. Pediatrics. 2005 Aug;116(2):493–5. PMID: 16061609. [Not a human study]16061609
313 Goossens LMA, Riemersma RA, Postma DS, . An economic evaluation of budesonide/formoterol for maintenance and reliever treatment in asthma in general practice. Adv Ther. 2009 Sep;26(9):872–85. PMID: 19768640. [Excluded study design]19768640
314 Gotz M. The safety and efficacy of inhaled fluticasone propionate (FP) in childhood asthma. Eur Respir J. 1994;4;Suppl 14:S804. [Not an intervention of interest]
315 Gould W, Peterson EL, Karungi G, . Factors predicting inhaled corticosteroid responsiveness in african american patients with asthma. J Allergy Clin Immunol. 2010 Dec;126(6):1131–8. PMID: 20864153. [Excluded study design]20864153
316 Gradman J, Wolthers OD. One year height growth in children with asthma treated with inhaled budesonide delivered from a new dry powder inhaler [Abstract]. European Respiratory Society Annual Congress; 2008 Oct 4–8; Berlin, Germany. P3942. [Not an intervention of interest]
317 Green RH, Brightling CE, McKenna S, . Asthma exacerbations and sputum eosinophil counts: A randomised controlled trial. Lancet. 2002 Nov 30;360(9347):1715–21. PMID: 12480423. [Not an intervention of interest]12480423
318 Green RH, Pavord ID. Use of long-acting beta2 agonists in arginine-16 homozygous patients with asthma. Thorax. 2008 Jun;63(6):568–9. PMID: 18511645. [Not a human study]18511645
319 Greenough A, Pool J, Gleeson JG, . Effect of budesonide on pulmonary hyperinflation in young asthmatic children. Thorax. 1988 Nov;43(11):937–8. PMID: 3065976. [Not an intervention of interest]3065976
320 Greos L, Corren J, Ruiz N, . Efficacy of flunisolide HFA (aerospan) in adult and adolescent patients 12 years and older with asthma by baseline inhaled steroid. Ann Allergy Asthma Immunol. 2014;113;5 Suppl 1:A42. Embase 71679240. [Not an intervention of interest]
321 Gross G, Woodring A, Prillaman B, . Efficacy and safety of the salmeterol/fluticasone propionate (50/100 μg) dry powder combination inhaler in patients with asthma. Eur Respir J. 1998;12;Suppl:156. [Not an intervention of interest]
322 Growth retardation in asthmatic children treated with inhaled beclomethasone dipropionate. Lancet. 1988 Feb 27;1(8583):475–6. PMID: 2893899. [Not a human study]2893899
323 Grunberg K, Sharon RF, Sont JK, . Rhinovirus-induced airway inflammation in asthma: Effect of treatment with inhaled corticosteroids before and during experimental infection. Am J Respir Crit Care Med. 2001 Nov 15;164(10 Pt 1):1816–22. PMID: 11734429. [Not an intervention of interest]11734429
324 Guleria R, Singh TR, Sinha S, . Effect of inhalation of Salbutamol, Beclomethasone dipropionate and Ipratropium bromide on mucociliary clearance in chronic stable bronchial asthma. Indian J Tuberc. 2004;51:54–7. [Not an intervention of interest]
325 Guo XD, Xu SL, Zhao P, . Efficiency of inhalation of budesonide aerosol in the treatment of asthma in infants and young children. Guangxi Medical Journal. 2002;24(1):14–6. [No English language abstract]
326 Haahtela T. Lung function decline in asthma and early intervention with inhaled corticosteroids. Chest. 2006 Jun;129(6):1405–6. PMID: 16778255. [Not a human study]16778255
327 Hacena M, Ingard A, Guenot A, . A prospective outcome study in patients with asthma on inhaled corticosteroid treatment. Ann Allergy Asthma Immunol. 2001;86:103. [Not an intervention of interest]
328 Hahn DL. Bronchodilator therapy with or without inhaled corticosteroid therapy for obstructive airway disease. N Engl J Med. 1993 Apr 8;328(14):1044–5. PMID: 8450868. [Not a human study]8450868
329 Hamada K, Yasuba H, Tanimura K, . How can we stop ICS? –Risk control therapy by as-needed inhaled fluticasone after stepping down. J Allergy Clin Immunol. 2008;121(2):S219. [Excluded study design]
330 Hamalainen KM, Laurikainen K, Leionen M, . Comparison of two multidose powder inhalers (MDP) in the treatment of asthma with inhaled corticosteroids. Eur Respir J. 1998;12;Suppl 28:61. [Not an intervention of interest]
331 Hampel Jr FC, Martin P, Mazzanotte WS. Early bronchodilatory effects of budesonide formoterol pressurized metered dose inhaler (pMDI) compared with fluticasone propionate salmeterol dry powder inhaler (DPI) and albuterol pMDI in adults with asthma. J Allergy Clin Immunol. 2008;21;2 Suppl 1:S220. [Not an intervention of interest]
332 Hancox RJ, Cowan JO, Flannery EM, . Randomised trial of an inhaled beta2 agonist, inhaled corticosteroid and their combination in the treatment of asthma. Thorax. 1999 Jun;54:482–7. PMID: 10335000. [Not an intervention of interest]10335000
333 Handforth J, Friedland JS, Sharland M. Inhaled corticosteroids after respiratory syncytial virus infection. BMJ (Online). 2009 Apr;338(7701):963. [Not a human study]
334 Harding S, Herje N, Hamedani A, . Long term effects of inhaled fluticasone propionate in subjects with asthma. Eur Respir J. 1997;10;Suppl 25:173. [Not an intervention of interest]
335 Harding SM, Herje NE, Hamedani AG. Comparison of the long-term effects of inhaled fluticasone propionate FP on the HPA axis in patients with asthma. Ann Allergy Asthma Immunol. 1997;78:156. [Not an intervention of interest]
336 Hart L, Sim S, Adcock I, . Effects of inhaled corticosteroid on expression and activation of nuclear factor -kB (NFkB) in asthma. Eur Respir J. 1998;12;Suppl 28:115. [Not an intervention of interest]
337 Haughney J, Aubier M, Jorgensen L, . Comparing asthma treatment in elderly versus younger patients. Respir Med. 2011 Jun;105(6):838–45. PMID: 21435854. [Not an intervention of interest]21435854
338 Hebert JR, Kunkel G, Neffen H, . Mometasone furoate (MF) therapy improves asthma symptoms in addition to pulmonary function in patients previously maintained on high doses of inhaled corticosteroids (ICS). Am J Respir Crit Care Med. 2000;161;Suppl 3:A187. [Irretrievable]
339 Hedlin G, Svedmyr J, Ryden AC. Systemic effects of a short course of betamethasone compared with high-dose inhaled budesonide in early childhood asthma. Acta Paediatr. 1999 Jan;88(1):48–51. PMID: 10090547. [No outcomes of interest]10090547
340 Henriksen JM. Effect of inhalation of corticosteroids on exercise induced asthma: Randomised double blind crossover study of budesonide in asthmatic children. Br Med J (Clin Res Ed). 1985 Jul 27;291(6490):248–9. PMID: 3926141. [Not an intervention of interest]3926141
341 Hesselmar B, Adolfsson S. Inhalation of corticosteroids after hospital care for respiratory syncytial virus infection diminishes development of asthma in infants. Acta Paediatr. 2001 Mar;90(3):260–3. PMID: 11332164. [Not in the target population]11332164
342 Hofhuis W, van der Wiel EC, Nieuwhof EM, . Efficacy of fluticasone propionate on lung function and symptoms in wheezy infants. Am J Respir Crit Care Med. 2005 Feb 15;171(4):328–33. PMID: 15531753. [Not an intervention of interest]15531753
343 Holt S, Patel M, Montgomery B, . Cohort study of a simple ‘step-up’ regimen with the asthma control test. Respirology. 2015 Apr;20(3):504–6. PMID: 25572675. [Excluded study design]25572675
344 Hozawa S, Terada M, Haruta Y, . Comparison of early effects of budesonide/formoterol maintenance and reliever therapy with fluticasone furoate/vilanterol for asthma patients requiring step-up from inhaled corticosteroid monotherapy. Pulm Pharmacol Ther. 2016;37:15–23. DOI: 10.1016/j.pupt.2016.01.005. [Duplicate]26850307
345 Huang J-L, Hung I-J, Hsieh K-H. Effect of inhaled beclomethasone dipropionate in the treatment of recurrent wheezing in infancy and early childhood. J Formos Med Assoc. 1993;92(12):1066–9. [Not an intervention of interest]7911355
346 Huang JL, Hung IJ, Hsieh KH. Effect of inhaled beclomethasone dipropionate in the treatment of recurrent wheezing in infancy and early childhood. J Formos Med Assoc. 1993 Dec;92(12):1066–9. PMID: 7911355. [Not an intervention of interest]7911355
347 Huang SG, Cheng QJ, Sears MR. As-needed formoterol (F) in asthma: an analysis of the East-Asian subgroup of the RELIEF study. Eur Respir J. 2014;44:P2425. Embase 71850114. [Not an intervention of interest]
348 Hughes GL, Edelman JM, Turpin JA. Randomized, open-label pilot study comparing the effects of montelukast sodium tablets, fluticasone aerosol inhaler and budesonide dry powder inhaler on asthma control in mild asthmatics. Am J Respir Crit Care Med. 1999;159(3 (Pt 2)):A641. [Not an intervention of interest]
349 Hypertrichosis in children treated with steroids. Prescrire Int. 2008;17(97):204. [Excluded study design]
350 Ige OM, Ohaju-Obodo JO, Chukwu C, . Effectiveness and safety of adjustable maintenance dosing with budesonide/formoterol turbuhaler compared with traditional fixed doses in bronchial asthma: A multi-centre nigerian study. Afr J Med Med Sci. 2010 Sep;39(3):165–72. PMID: 21416785. [Irretrievable]21416785
351 Implementing key therapeutic topics: 1 NSAIDs; antibiotics; and inhaled corticosteroids in asthma. MeReC Bull. 2012;22(3):1–8. [Irretrievable]
352 Ind P, Haughney J, Price D, . 4-month adjustable or fixed maintenance treatment with budesonide/formoterol in a single inhaler reduces symptoms severity. Eur Respir J. 2002;20;Suppl 38:41. [Not an intervention of interest]11852893
353 Ind P, Haughney J, Price D, . Four months adjustable or fixed BD dosing with budesonide/formoterol in a single inhaler reduces symptom severity. Thorax. 2002;57;Suppl III:iii88. [Not an intervention of interest]
354 Ind PW, Dal Negro R, Colman N, . Inhaled fluticasone propionate and salmeterol in moderate adult asthma II: exacerbations. Am J Respir Crit Care Med. 1998;157;Suppl 3:A415. [Not an intervention of interest]
355 Ind PW, Dal Negro R, Colman N, . Inhaled fluticasone propionate and salmeterol in moderate adult asthma I: lung function and symptoms. Am J Respir Crit Care Med. 1998;157;Suppl 3:A416. [Not an intervention of interest]
356 Ind PW, dal Negro R, Fletcher CP, . Inhaled salmeterol and fluticasone propionate therapy in moderate adult asthma. Eur Respir J. 1997;10;Suppl 25:1. [Not an intervention of interest]
357 Ind PW, Haughney J, Price D, . Adjustable and fixed dosing with budesonide/formoterol via a single inhaler in asthma patients: The ASSURE study. Respir Med. 2004 May;98(5):464–75. PMID: 15139576. [Not an intervention of interest]15139576
358 Ind PW, Price D, Haughney J, . Adjustable dosing with budesonide/formoterol in a single inhaler (symbicortA(R)) provides similarly effective treatment of asthma compared with fixed dosing but at a lower overall dose [abstract]. American Thoracic Society International Conference; 2003. 38p. [Irretrievable]
359 Inhaled corticosteroids for mild asthma. Med Today. 2002;3(1):9. [Not a human study]
360 Inhaled corticosteroids may cause only temporary slowing of growth in children, studies suggest. Am J Health-Syst Pharm. 2000 Dec 2;57(23):2142–9. [Not a human study]11127692
361 Inhaled corticosteroids: Are higher doses better? Drug Ther Bull. 1986 Jan 13;24(1):1–2. PMID: 3516617. [Not a human study]3516617
362 Inhaled corticosteroids: Children are at risk from high doses. MeReC Extra. 2007:27. [Irretrievable]
363 Inhaled corticosteroids: Do they inhibit growth? Med Today. 2002;3(5):10. [Not a human study]
364 Inhaled glucocorticoids found to cause dose-related bone density loss. Pharm J. 2001 Oct;267(7168):454. [Not a human study]
365 Inhaled glucocorticoids more effective than leukotriene receptor antagonists for treating asthma. Formulary. 2003 May;38(5):271. [Not a human study]
366 Inhaled steroids switch can destabilise asthma. Pharm J. 2002 May;268(7199):710. [Not a human study]
367 Inman MD, Watson RM, Rerecich T, . Dose-dependent protection against allergen-induced asthmatic responses by inhaled mometasone furoate. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 1989p. [Irretrievable]
368 Inman MD, Watson RM, Rerecich T, . Effect of low doses of mometasone furoate (MF) dry powder inhaler (DPI) on allergen induced asthmatic responses. Am J Respir Crit Care Med. 2000;161;Suppl 3:A187. [Irretrievable]
369 Intelligent inhalers for pulmonary delivery. Manuf Chem. 2001;72(4):23–5. [Irretrievable]
370 Intermittent therapy effective for mild persistent asthma. J Fam Pract. 2005;54(7):578. Embase 2005312735. [Not a human study]
371 Irani AM, Berger W, Qaquandah P, . Effect of budesonide inhalation suspension (BIS) on HPA axis function in infants stratified by age [Abstract]. American Thoracic Society 100th International Conference; 2004 May 21–26; Orlando, FL. A37 Poster J106p. [Not an intervention of interest]
372 Irani AM, Fitzpatrick S, Smith J, . Budesonide inhalation suspension compared with cromolyn sodium: effects on asthma outcomes in young children. Pediatr Res. 2001;49(4):130A. [Not an intervention of interest]11134503
373 Jackson C, Lipworth B. Benefits of combination therapy on exacerbations in nonsmoking patients with asthma. J Allergy Clin Immunol. 2008;121(3):780. [Not a human study]18243291
374 Jarjour NN, Kelly EAB, Rodriguez RR, . Inhaled budesonide (BUD) via turbohaler decreases late asthmatic reaction (LAR) to antigen and down regulates airway lymphocyte function in atopic asthma. Am J Respir Crit Care Med. 1998;157;Suppl 3:A873. [Not an intervention of interest]
375 Jayaram L, Pizzichini MM, Cook RJ, . Determining asthma treatment by monitoring sputum cell counts: effect on exacerbations. Eur Respir J. 2006 Mar;27(3):483–94. PMID: 16507847. [Not an intervention of interest]16507847
376 Jenkins C, Belousova E, Marks G, . Intermittent or continuous inhaled corticosteroids for mild asthma? Respirology. 2006;11;Suppl 2:A70. [Abstract without full-text]
377 Jenkins C, Eriksson G, Bateman ED, . Efficacy of budesonide/formoterol maintenance and reliever therapy in mild asthma. Eur Respir J. 2013 Sep 11;42:P4125. Embase 71842582. [Abstract without full-text]
378 Jenkins C, Goldberg H, Ryder E, . The effect of inhaled budesonide on bronchial responsiveness to histamine in patients with asthma. Aust Nz J Med. 1991;21:662. [Not an intervention of interest]
379 Jonasson G, Edvardsen E, Carlsen KH. Clinical efficacy of a low dose inhaled budesonide in children with mild asthma previously not treated with steroids. Eur Respir J. 1997;10;Suppl 25:221. [Not an intervention of interest]
380 Jung J, Lee J, Kim J. Treatment of inhaled corticosteroid and leukotriene receptor antagonist in Korean young cough variant asthma children. J Allergy Clin Immunol. 2006;117;2 Suppl 1:S93. [Not an intervention of interest]
381 Kaiser HB, Miller CJ, O’Dowd L. Measured onset of bronchodilation with budesonide and formoterol administered via one pressurized metered dose inhaler (pMDI) in patients with asthma previously receiving inhaled corticosteroids. J Allergy Clin Immunol. 2007;119;Suppl 1:S249. [Not an intervention of interest]
382 Kajosaari M, Syvanen P, Forars M, . Inhaled corticosteroids during and after respiratory syncytial virus-bronchiolitis may decrease subsequent asthma. Pediatr Allergy Immunol. 2000 Aug;11(3):198–202. PMID: 10981531. [Not in the target population]10981531
383 Kalister H. Treating children with asthma. West J Med. 2001;174(6):415–20. [Not a human study]11381011
384 Kaplan A. Inadequately controlled asthma. patients do not understand their treatment plans. Can Fam Phys. 2002 Aug;48:1280–2. [Not a human study]
385 Kardos P, Brueggenjuergen B, Baare A, . The ATACO study: adjustable maintenance therapy with budesonide and formoterol in a single inhaler. Eur Respir J. 2002;20;Suppl 38:41. [Not an intervention of interest]
386 Kardos P, Bruggenjurgen B, Martin A, . The treatment of asthma: A study (TACO asthma control lan) introducing a new adjustable combination-treatment plan. Pneumologie. 2001;55(5):253–7. [Duplicate]11449612
387 Kardos P, Brüggenjürgen B, Martin A, . The treatment of asthma: a study (TACO asthma control plan) introducing a new adjustable combination-treatment plan. Pneumologie. 2001;55(5):253–7. [Not an intervention of interest]11449612
388 Kardos P, Bruggenjurgen B, Martin A, . Treatment of bronchial asthma using a new adjustable combination treatment plan: Asthma Control Plan (ATACO). Pneumologie. 2001 May;55(5):253–7. [Duplicate]11449612
389 Kardos P, Richter K, Vogelmeier C, . Adjustable dosing with budesonide/formoterol in a single inhaler maintains improvement in health-related quality of life at a lower drug load than fixed dosing - the ATACO study. Eur Respir J. 2003;22;Suppl 45:Abstract P1696. [Not an intervention of interest]
390 Kari O. Helsinki early intervention childhood asthma (HEICA) study: inhaled budesonide halved the number of asthma exacerbations compared with inhaled disodium cromogylcate during 18 months of treatment. Eur Respir J. 2000;16;Suppl 31:311. [Irretrievable]
391 Karkinski D, Arsovski Z, Nikolau M, . Inhalation of fluticasone propionate spray compared with theophilline as primary treatment for chronic mild to moderate asthma. Eur Respir J. 2006;28;Suppl 50:500. [Not an intervention of interest]
392 Karpel JP, Fish JE, Craig TJ, . Mometasone furoate (MF) administered by metered dose inhaler (MDI) reduces oral prednisone requirements and improves pulmonary function of patients with severe persistent asthma. Eur Respir J. 2000l16;Suppl 31:93. [Not an intervention of interest]
393 Karpel JP, Nayak A, Lumry W, . Mometasone furoate reduces oral corticosteroid requirements in patients with severe persisitent asthma previously using other inhaled corticosteroids. Chest. 2002;122(4):65S. [Not an intervention of interest]
394 Kasayama S, Otsuki M, Tanemura M, . Association of subclinical hypothalamic-pituitary-adrenal axis suppression with bone loss in patients with asthma taking inhaled corticosteroids. Ann Allergy Asthma Immunol. 2013;111(3):229–31. [Not an intervention of interest]23987207
395 Kassutto S, Daily JP. Footprints. N Engl J Med. 2004 Sep;351(14):1438–43 and 1475. [Excluded study design]
396 Kawayama T, Gauveau GM, Watson RM, . Effects of inhaled ciclesonide on circulating Th1/Th2 cells in atopic asthmatics after allergen challenge. American Thoracic Society International Conference; 2005 May 20–25; San Diego, CA. A351. [Not an intervention of interest]
397 Keeley D. Higher dose inhaled corticosteroids in childhood asthma. Br Med J. 2001 Mar;322(7285):504–5. [Not a human study]11230052
398 Kellerman D, Stricker W, Howland W, . Effects of inhaled fluticasone propionate (FP) on the HPA axis of patients with asthma. Eur Respir J. 1996;9;Suppl 23:162. [Not an intervention of interest]
399 Kelly M, O’ Connor T, Leigh R, . Inhaled budesonide/formoterol combination therapy significantly attenuates allergen induced increases in airway myfibroblasts. Eur Respir J. 2007;30;Suppl 51:137. [Not an intervention of interest]
400 Kelso JM. Daily versus as-needed inhaled corticosteroid for mild persistent asthma (the helsinki early intervention childhood asthma study). Pediatrics. 2009;124;suppl 2:S148–9. [Not a human study]
401 Kerigan AT, Pugsley SO, Cockcroft DW, . Subsittution of inhaled beclomethasone dipropionate for ingested prednisone in steroid-dependent asthmatics. Can Med Assoc J. 1977 Apr 23;116(8):867–71. PMID: 851928. [Not an intervention of interest]851928
402 Kerwin EM, Gillespie M, Song S, . Dose-ranging study of a fluticasone propionate multidose dry powder inhaler in adolescents and adults with asthma uncontrolled by noncorticosteroid asthma medications. Am J Respir Crit Care Med. 2015;191:A4232. Embase 72052107. [Not an intervention of interest]
403 Kerwin EM, Gillespie M, Song S, . Randomized, dose-ranging study of a fluticasone propionate multidose dry powder inhaler in adolescents and adults with uncontrolled asthma not previously treated with inhaled corticosteroids. J Asthma. 2016 Jun. Epub 2016 Jun 10. PMID: 27285965. [Not an intervention of interest]27285965
404 Ketchell RI, Jensen MW, Montgomery AA, . Inhaled fluticasone propionate rapidly attentuates airway responsiveness to adenosine 5′-monophosophate and decreases exhaled nitric oxide in mild asthma. Eur Respir J. 2000;16;Suppl 31:340. [Irretrievable]
405 Kim KT, Lanier BQ, Goldman M, . Effect of adjustable-dose (AD) budesonide/formoterol pressurized metered-dose inhaler (pMDI), fixed-dose (FD) budesonide/formoterol pMDI, and FD fluticasone/salmeterol dry powder inhaler (DPI) on predose FEF25–75% [Abstract]. American Thoracic Society International Conference; 2009 May 15–20; San Diego, CA. A2788 Poster #J57. [Not an intervention of interest]
406 Kim S, Ye Y, Hur G, . Effect of beta2-adrenergic receptor polymorphism in asthma control of patients receiving combination treatment. Yonsei Med J. 2009 Apr 30;50(2):182–8. PMID: 19430548. [Not an intervention of interest]19430548
407 Kim SR, Lim KH, Kim MJ, . The efficacy and safey of inhaled steroid therapy for prevention of recurrent wheezing after bronchiolitis. Pediatr Allergy Respir Dis. 2004;14(4):392–401. [Not in the target population]
408 King V, Nettleton W. Intermittent Inhaled Corticosteroid Therapy for Mild Persistent Asthma in Children and Adults. American Family Physician. 2016; July;94(1):21–2. PMID: 27386720 [not a human study]27386720
409 Kini SH, Jain K, Nabar ST, . Three modes of delivery of steroids in asthma: a comparison. Eur Respir J. 2001;18;Suppl 33:99. [Not an intervention of interest]
410 Klaassen EMM, van de Kant, K D G., Jobsis Q, . Symptoms, but not a biomarker response to inhaled corticosteroids, predict asthma in preschool children with recurrent wheeze. Mediators Inflamm. 2012;2012:162571. PMID: 23304059. [Not an intervention of interest]23304059
411 Knox AJ, Deacon K, Clifford R. Blanching the airways: Steroid effects in asthma. Thorax. 2007;62(4):283–5. [Not a human study]17387210
412 Ko FWS, Wang HY, Wong GWK, . Wheezing in chinese schoolchildren: Disease severity distribution and management practices, a community-based study in hong kong and guangzhou. Clin Exp Allergy. 2005 Nov;35(11):1449–56. PMID: 16297141. [Excluded study design]16297141
413 Koenig SM, Murray JJ, Wolfe J, . Does measuring BHR add to guideline derived clinical measures in determining treatment for patients with persistent asthma?. Respir Med. 2008 May;102(5):665–73. PMID: 18328683. [Not an intervention of interest]18328683
414 Konig P, Ford L, Galant S, . A 1-year comparison of the effects of inhaled fluticasone propionate (FP) and placebo on growth in pre-pubescent children with asthma. Eur Respir J. 1996;9;Suppll S294. [Not an intervention of interest]
415 Kotaniemi-Syrjanen A, Reijonen TM, Korhonen K, . Sodium cromoglycate therapy in wheezing infants: Preliminary evidence of beneficial outcome at early school age. Pediatr Int. 2005 Dec;47(6):627–34. PMID: 16354214. [Not an intervention of interest]16354214
416 Kovesi T, Schuh S, Spier S, . Achieving control of asthma in preschoolers. CMAJ. 2010 Mar;182(4):E172–183. [Not a human study]19933790
417 Kovesi T. In children and adolescents with mild persistent asthma, daily beclomethasone reduces treatment failure compared with rescue beclomethasone plus albuterol. Evidence-based medicine. 2011;16(6):183–4. DOI: 10.1136/ebm1411. [Not a human study]21561924
418 Kraemer R, Graf Bigler U, Casaulta Aebischer C, . Clinical and physiological improvement after inhalation of low-dose beclomethasone dipropionate and salbutamol in wheezy infants. Respiration. 1997;64(5):342–9. PMID: 9311050. [Not an intervention of interest]9311050
419 Kraemer R, Graf Bigler U, Casaulta Aebischer C. Clinical and functional improvement after inhalations of low-dose beclomethasone dipropionate (BDP) and salbutamol in wheezy infants. Eur Respir J. 1995;8;Suppl 19:468. [Not an intervention of interest]
420 Kraemer R, Sennhauser F. Inhaled beclometasone and cromoglycate on bronchial hyperreactivity in asthmatic children. Atemwegs-Lungenkrankh. 1986;12(3):110–3. [Not an intervention of interest]
421 Kraft M, Israel E, O’Connor GT. Treatment of mild persistent asthma. N Engl J Med. 2007 May;356(20):2096–100. [Not a human study]17507711
422 Krishnan JA, Nowak R, Davis SQ, . Anti-inflammatory treatment after discharge home from the emergency department in adults with acute asthma. J Emerg Med. 2009 Aug;37;2 Suppl:S35–41. [Not a human study]19683663
423 Krishnan JA, Nowak R, Davis SQ, . Anti-inflammatory treatment after discharge home from the emergency department in adults with acute asthma. J Allergy Clin Immunol. 2009 Aug;124;Suppl 2:S29–34. [Not a human study]19647133
424 Krishnan JA, Nowak R, Davis SQ, . Anti-inflammatory treatment after discharge home from the emergency department in adults with acute asthma. Proc Am Thorac Soc. 2009 Aug;6(4):380–5. [Not a human study]19675348
425 Kuna P, Chuchalin A, Ringdal N, . Low-dose single-inhaler budesonide/formoterol administered once daily is effective in mild-persistent asthma. Eur Respir J. 2001;18;Suppl 33:158. [Not an intervention of interest]
426 Kuna P, Gath I, ThyroffFriesinger U, . Equivalence of an innovative multidose salmeterol/fluticasone dry powder inhaler vs comparator in paediatric asthma. Eur Respir J. 2013;42;Suppl 57:918s. Embase 71843005. [Not an intervention of interest]
427 Kuna P, Gath I, ThyroffFriesinger U, . Equivalence of fluticasone propionate/salmeterol delivered via new multi-dose dry powder inhaler and accuhalerTM in adolescent and adult asthma. Am J Respir Crit Care Med. 2013;187:A2611. [Not an intervention of interest]
428 Kuna P, Lalloo U, Bateman ED, . Budesonide/formoterol in a single inhaler rapidly improves lung function in adult patients with mild or moderate asthma. European Respiratory Society Annual Congress; 2002. Abstract P2400. [Not an intervention of interest]
429 Kuo HP, Uy TR. The relationship of hypodense eosinophil with clinical severity and its response to inhaled corticosteroid in patients with bronchial asthma. Eur Respir J. 1993;6;Suppl 17:584. [Not an intervention of interest]
430 Kuzik BA. Inhaled corticosteroids in children with persistent asthma: Effects on growth. Paediatr Child Health. 2015 Jun;20(5):248–50. [Not a human study]26175562
431 La Rosa M, Francesco G, Musarra I, . Double-blind comparative study of inhaled flunisolide and flunisolide plus salbutamol in bronchial asthma in children. Curr Ther Res Clin Exp. 1991;50(1):56–61. [Not an intervention of interest]
432 LaForce CF, Baker JW, Amin D, . Ciclesonide a novel inhaled steroid has no effect on hypothalamic pituitary adrenal (HPA) - axis function in mild to moderate asthmatics. J Allergy Clin Immunol. 2003;111;Suppl 2:S218. [Not an intervention of interest]
433 Lahzami S, King GG. Targeting small airways in asthma: The new challenge of inhaled corticosteroid treatment. Eur Respir J. 2008 Jun;31(6):1145–7. PMID: 18515551. [Not a human study]18515551
434 Lai S-T, Hua Y-M, Lai Y-S, . Comparison of nebulized budesonide with intravenous dexamethasone in the treatment of young children hospitalized with acute asthma. J Med Sci. 2005 Oct;25(5):223–8. [Not in the target population]
435 Lalloo UG, Malolepsky J, Kozma D, . Budesonide and formoterol in a single inhaler controls exacerbations more effectively than a higher dose of inhaled corticosteroids alone, in mild-moderate persistent asthma. Eur Resp J. 2001;18;Suppl 33:43. [Not an intervention of interest]
436 Lalloo UG, Malolepsky J, Kozma D, . Budesonide and formoterol in a single inhaler is more effective than a higher dose of inhaled corticosteroid in mild-moderate persistent asthma. Eur Resp J. 2001;18;Suppl 33:159. [Not an intervention of interest]
437 Lalloo UG, Malolepszy J, Kozma D, . Symbicort(R) (budesonide and formoterol in a single inhaler) is more effective than increasing the dose of inhaled corticosteroids in mild asthma. Annual Thoracic Society 97th International Conference; 2001; San Francisco, CA. D31p. [Not an intervention of interest]
438 Lalloo UG, Malolepszy J, Kozma D, . Symbicort(R) (budesonide and formoterol in a single inhaler) is more effective than increasing the dose of inhaled corticosteroids in mild asthma. Am J Respir Crit Care Med. 2001;163;Suppl 5:A863. [Irretrievable]
439 Lan WP, Wang J, Dai C, . Efficacy of fluticasone proprioante aerosol versus budesonide suspention in treatment of recurrent wheezing caused by bronchiolitis. Chin J Contemp Pediatr. 2016 Apr; 18(4):316–9. [Excluded study design]
440 Langdon CG, Thompson J. A multicentre study to compare the efficacy and safety of inhaled fluticasone propionate and budesonide via metered-dose inhalers in adults with mild-to-moderate asthma. British Journal of Clinical Research. 1994;5:73–84. [Not an intervention of interest]
441 Lara-Perez EA. Improvement of the asthma in children using salmeterol and fluticasone (Seretide) in inhaled combination [abstract]. XIX World Allergy Organization Congress; 2005. 816p. [Irretrievable]
442 Laurikainen K, Toivanen P, Silvasti M, . Comparison of two beclomethasone dipropionate (BDO) powder inhalers in the treatment of asthma. Eur Resp J. 1997;10;Suppl 25:235. [Not an intervention of interest]
443 Laursen LC, Taudorf E, Weeke B, . High-dose inhaled budesonide in treatment of severe steroid-dependent asthmatics. Lancet. 1983 Dec 3;2(8362):1305. PMID: 6139644. [Excluded study design]6139644
444 Laviolette M, Barnes N, Lindsay C, . Absence of sputum eosinophils in subjects with symptomatic asthma on inhaled budesonide [Abstract]. European Respiratory Society Annual Congress; 2002. P1753. [Not an intervention of interest]
445 Laviolette M, Ferland C, Trepanier L, . Effects of inhaled steroids on blood eosinophils in moderate asthma. Ann N Y Acad Sci. 1994 May 28;725:288–97. PMID: 8031001. [Not an intervention of interest]8031001
446 Lawrance R, Ambrose H, Goldman M. Effect of gly16arg beta2-adrenergic receptor variation on the long-term safety of formoterol (FM) in combination with budesonide (BUD) and of BUD alone, delivered via one pressurized metered-dose inhaler (pMDI) in patients with moderate to severe asthma [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. 420p. [Irretrievable]
447 Le Bourgeois M, Cormier C, Kindermans C, . Inhaled beclomethasone and bone metabolism in young asthmatic children: A six month study. J Allergy Clin Immunol. 1995 Oct;96(4):565–7. PMID: 7560673. [Excluded study design]7560673
448 Lee DKC, Currie GP, Cockburn WJ, . Budesonide/formoterol and fluticasone/salmeterol combination inhalers delay immediate albuterol recovery following acute bronchoconstriction. J Allergy Clin Immunol. 2003;111;Suppl 2:S202. [Not an intervention of interest]
449 Lee DKC, Currie GP, Cockburtn WJ, . Comparison of budesonide/formoterol versus fluticasone/salmeterol combination inhalers in moderate persistent asthma [abstract]. American Thoracic Society International Conference; 2003. 613p. [Irretrievable]
450 Lee-Wong M, Dayrit FM, Kohli AR, . Comparison of high-dose inhaled flunisolide to systemic corticosteroids in severe adult asthma. Chest. 2002 Oct;122(4):1208–13. PMID: 12377843. [Not in the target population]12377843
451 Leflein JG, Berger WE, Uryniak T, . Long term safety and systemic effects of budesonide and formoterol administered via one pressurized metered dose inhaler (pMDI) in children with asthma. J Allergy Clin Immunol. 2008;21;2 Suppl 1:S155. [Not an intervention of interest]
452 Leflein JG, Gawchick SM, Galant SP, . Safety of budesonide inhalation suspension (Pulmicort Respules) after up to 52 weeks of treatment in infants and young children with persistent asthma. Allergy Asthma Proc. 2001;22(6):359–66. [Not an intervention of interest]11775393
453 Leidy NK, Gutierrez B, Lampl K, . Can patients with asthma feel inhaler therapy working right away? two clinical trials testing the effect of timing of assessment on patient perception. J Asthma. 2009 Dec;46(10):1006–12. PMID: 19995138. [Not an intervention of interest]19995138
454 Leidy NK, Patrick DL, Boggs R, . Perceived onset of effect of budesonide and formoterol administered via one pressurized metered dose inhaler in patients with asthma previously receiving inhaled corticosteroids. J Allergy Clin Immunol. 2007;119;Suppl 1:S246. [Not an intervention of interest]
455 Lemanske RF, Lockey RF, Murphy KR. Effects of one year of treatment with mometasone furoate metered dose inhaler (MF-MDI) on growth in children with asthma. Eur Respir J. 2004;24;Suppl 48:379. [Not an intervention of interest]
456 Leuppi JD, Salzberg M, Meyer L, . An individualized, adjustable maintenance regimen of budesonide/formoterol provides effective asthma symptom control at a lower overall dose than fixed dosing. Swiss Med Wkly. 2003 May 31;133(21–22):302–9. PMID: 12861468. [Not an intervention of interest]12861468
457 Levy ML, Stevenson C, Maslen T. Comparison of short courses of oral prednisolone and fluticasone propionate in the treatment of adults with acute exacerbations of asthma in primary care. Thorax. 1996 Nov;51(11):1087–92. PMID: 8958890. [Not in the target population]8958890
458 Li LW, Huang Y, Luo R, . Efficacy of regular or intermittent inhalation of corticosteroids in treatment of asthma and its effects on growth and development in children. Zhongguo Dangdai Erke Zazhi. 2015 Mar;17(3):237–40. [Not an intervention of interest]25815491
459 Li Y, Liu D, Yi H-L. Clinical significance of bronchial reversibility test in the treatment of childhood asthma. Chin J Contemp Pediatr. 2013;15(2):105–8. [Not an intervention of interest]
460 Li YQ, Xue HY, Chen W, . Application of asthma predictive index-based group therapy in wheezing children under 5 years of age. Zhongguo Dangdai Erke Zazhi. 2014 Aug;16(8):795–9. [Not an intervention of interest]25140770
461 Liam C, Pang Y, Chua K. Satisfaction level and asthma control among malaysian asthma patients on symbicort maintenance and reliever therapy (SMART) in the primary care setting (SMARTEST study). Asian Pac J Allergy Immunol. 2014 Jun;32(2):145–52. PMID: 25003728. [Excluded study design]25003728
462 Lim DH, Kim JH, Son BK. New regimen of inhaled corticosteroid in preschool children with asthma. J Korean Med Assoc. 2012 Dec;55(12):1201–6. DOI: http://dx.doi.org/10.5124/jkma.2012.55.12.1201. [Not a human study]
463 Lin C, Hsu J, Hsiao Y, . Budesonide/formoterol maintenance and reliever therapy in asthma control: Acute, dose-related effects and real-life effectiveness. Respirology. 2015 Feb;20(2):264–72. PMID: 25366969. [Not an intervention of interest]25366969
464 Lin J, Tang Y, Xiu Q. Real-life effectiveness of budesonide/formoterol therapy in asthma: A subanalysis of the SMARTASIA study. Allergy & Asthma Proceedings. 2016;Feb;37(1):27–34. PMID: 26831844 [not an intervention of interest]26831844
465 Lindgren S, Eriksson NE, Lindholm N. Experience of local inhalation of beclomethasone dipropionate (becotide) in the treatment of adult steroid-dependent asthmatic patients. Scand J Respir Dis Suppl. 1977;101:163–72. PMID: 343237. [Not an intervention of interest]343237
466 Lindgren S, Eriksson NE, Lindholm N. Experience of local inhalation of beclomethasone dipropionate becotide in the treatment of adult steroid-dependent asthmatic patients. Scand J Respir Dis Suppl. 1977;101:163–72. [Not an intervention of interest]343237
467 Lipworth BJ, Short PM, Williamson PA, . A randomized primary care trial of steroid titration against mannitol in persistent asthma: STAMINA trial. Chest. 2012 Mar;141(3):607–15. PMID: 21998259. [Not an intervention of interest]21998259
468 Liu CT, Wang YM, Wang G, . A clinical study on the significance of airway hyperresponsiveness monitoring in the adjustment of combined therapy for asthmatic patients. Chin J Tuberc Respir Dis. 2007 Jul;30(7):498–503. [Not an intervention of interest]
469 Lockey RF, Abreu P, Kimel M, . Health related quality of life effects of mometasone furoate dry-powder inhaler corticosteroids. Eur Respir J. 2003;22;Suppl 45:P1834. [Not an intervention of interest]
470 Lodrup Carlsen KC, Carlsen KH, Nikander K, . Nebulized budesonide after hospitalization for recurrent bronchial obstruction in children younger than 18 months. Pediatr Allergy Immunol. 2001 Jun;12(3):159–65. PMID: 11473681. [Not an intervention of interest]11473681
471 Look for adrenal insufficiency caused by inhaled corticosteroids. Pharm J. 2001 Oct;267(7168):454. [Not a human study]
472 Loukides S, Papageorgiou M, Karokis A, . Single inhaler therapy (SiT) with budesonide/formoterol (BUD/FUM) is effective in asthma control. Eur Respir J. 2005;26;Suppl 49:A848. [Abstract without full-text]
473 Low-dose steroids and asthma mortality. Hosp Pract. 2000;35(10):25. [Not a human study]
474 Lowhagen O, Wever AM, Lusuardi M, . The inflammatory marker serum eosinophil cationic protein (ECP) compared with PEF as a tool to decide inhaled corticosteroid dose in asthmatic patients. Respir Med. 2002 Feb;96(2):95–101. PMID: 11862965. [Not an intervention of interest]11862965
475 Lyutzkanova T, Klinkanova M. The effect of drugs on inhalatory provocation tests in children with bronchial asthma. Folia Med (Plovdiv). 1980;22(4):33–5. PMID: 6790377. [Not an intervention of interest]6790377
476 Maayan C, Itzhaki T, Bar-Yishay E, . The functional response of infants with persistent wheezing to nebulized beclomethasone dipropionate. Pediatr Pulmonol. 1986 Jan–Feb;2(1):9–14. PMID: 3513105. [Not an intervention of interest]3513105
477 Macias CG, Felner EI, Gan V. Inhaled corticosteroids may be superior to systemic corticosteroids in children with moderate-to-severe acute asthma. Pediatr Asthma Alelrgy Immunol. 2003;16(3):121–8. Embase 2003322769. [Not in the target population]
478 Maintenance treatment. J Invest Allergol Clin Immunol. 2010;20;Suppl 1:19–26. [Not a human study]
479 Mallol J, Aguirre V, Barrueto L, . Effect of inhaled fluticasone on lung function in infants with recurrent wheezing: A randomised controlled trial. Allergol Immunopathol (Madr). 2009 Mar–Apr;37(2):57–62. PMID: 19445860. [Not an intervention of interest]19445860
480 Malo JL, Cartier A, Laviolette M, . Skin bruising adrenal function and bone metabolism in asthmatic subjects on inhaled beclomethasone and fluticasone. Am J Resp Crit Care Med. 1998;157;Suppl 3:A406. [Not an intervention of interest]
481 Malur A, Rambasek T, Isabella T, . Therapy for asthma with long acting beta-agonist and a lower dose of an inhaled corticosteroid (ICS) does not activate proinflammatory genes when compared with higher dose ICS alone [Abstract]. American Thoracic Society 100th International Conference; 2004 May 21–26; Orlando, FL. C8p. [Not an intervention of interest]
482 Managing asthma and allergy medications during pregnancy. J Respir Dis. 2000;21(12):744–6. [Not a human study]
483 Manolitsas N, Wang J, Trigg C, . Long-term inhaled beclomethasone dipropionate BDP and bronchial inflammation in mild asthma. Aust NZ J Med. 1994;24:460. [Not an intervention of interest]
484 Marcus P. Dosing inhaled steroids in asthma: is once-a-day administration effective?. Chest. 2003 Oct;124(4):1196–8. PMID: 14555546. [Not a human study]14555546
485 Maritotti F, Poli G, Acerbi D, . Pharmacokinetics and pharmacodynamics of beclomethasone dipropionate and formoterol combination after inhalation using dry powder inhaler. Eur Respir J. 2007;20;Suppl 51:350. [Not an intervention of interest]
486 Mark Fitzgerald J. A randomized, controlled trial of high dose, inhaled budesonide versus oral prednisone in patients discharged from the emergency department following an acute asthma exacerbation. Can Respir J. 2000;7(1):61–7. [Not in the target population]10700672
487 Maspero J, Cherrez I, Nolte H. Long-term safety and tolerability of two doses of mometasone furoate/formoterol (MF/F) combination, administered via a metered-dose inhaler, for the treatment of moderate-to-severe persistent asthma. J Allergy Clin Immunol. 2009;123;2S Suppl 1:S159. [Not an intervention of interest]
488 Maspero JF, Cherrez I, Nolte H. Mometasone furoate and formoterol (MF/F) combination administered via a metered-dose inhaler (MDI) for the treatment of asthma: results from a 1-yr safety study. American Thoracic Society International Conference; 2009 May 15–20; San Diego, CA. A2768 Poster #J37. [Not an intervention of interest]
489 McCarthy T P, Edin H M, House K, . Low dose salmeterol/fluticasone propionate combination (SFC) via metered dose inhaler (MDI) improves asthma control and quality of life in patients not well controlled on inhaled steroids (ICS). Eur Respir J. 2002. 20;Suppl 38:47. [Irretrievable]
490 McCarthy T P, Edin H M, House K, . Salmeterol/fluticasone 50/100 (SFC) dry powder (DPI) provides improved control and quality of life in patients symptomatic on inhaled corticosteroids (ICS). Eur Respir J. 2002;20;Suppl 38:47. [Not an intervention of interest]11852894
491 McCarthy TP, Edin HM, House K, . Quality of life and asthma control assessment in patients previously on inhaled corticosteroids (ICS) treated with salmeterol/fluticasone combination (SFC) metered dose inhaler (MDI). Thorax. 2001;56;Suppl 3:iii64. [Not an intervention of interest]
492 McCarthy TP, Edin HM, House K, . The effects of salmeterol/fluticasone combination (SFC) dry powder inhaler (DPI) on asthma control and quality of life in patients previously treated with inhaled corticosteroids (ICS). Thorax. 2001;56;Suppl 3:iii63. [Not an intervention of interest]
493 McCarthy TP, Greening AP, Holgate SK, . The efficacy of salmeterol/fluticasone propionate combination (SFC) metered dose inhaler compared with beclomethasone dipropionate (BDP) in patients not well controlled at step 1 of the British guidelines on asthma management (BGAM). Thorax. 2001;56;Suppl 3:iii62. [Not an intervention of interest]
494 McCarthy TP, Russell D, Baxter LE, . A comparison of the efficacy of salmeterol/fluticasone propionate combination (SF) with beclometasone dipropionate (BDP) delivered via metered dose inhaler (MDI) in patients mot well controlled on bronchodilators alone. Eur Respir J. 2001;18;Suppl 33:53. [Not an intervention of interest]11510806
495 McKinlay L, Williamson PA, Short PM, . Proof of concept study to evaluate step-down therapy with inhaled corticosteroid alone or additive therapy on surrogate inflammatory markers in asthma. Br J Clin Pharmacol. 2011 Jan;71(1):128–31. PMID: 21143509. [Not an intervention of interest]21143509
496 Mehta PN. Asthma and the school going child. Indian Pediatr. 2002 Aug;39(8):731–8. [Not a human study]12196684
497 Melamed J, Beaucher W. A prospective evaluation of the adequacy of peak inspiratory flow rates and validation of the turbutester score in asthmatic individuals with “low” peak expiratory flow rates: Implications for dry powder inhalers. J Allergy Clin Immunol. 2003 Mar;111(3):648–50. [Not an intervention of interest]12642853
498 Mellon M, Dukes E, Ollendorf D, . Budesonide inhalation suspension improves symptom-free days and use of asthma-related services in infants and young children. Ann Allergy Asthma Immunol. 2000;84:161. [Not an intervention of interest]
499 Meltzer EO, Uryniak T, Trudo F, . Efficacy and safety of budesonide (BUD) administered by pressurized metered-dose inhaler (pMDI) in children aged 6 to <12 years with asthma: a phase II study. Am J Resp Crit Care Med. 2014;189:A1811. [Not an intervention of interest]
500 Mendelson L, Welch M, Murphy K, . Greater efficacy of budesonide inhalation suspension compared to cromolyn sodium over 52 weeks in young children with persistent asthma. Am J Respir Crit Care Med. 2000;161;Suppl 3:A36. [Irretrievable]
501 Merkus PJFM, De Jongste JC. Inhaled corticosteroids and long term outcome in adults with asthma. Thorax. 2006 Nov;61(11):1011. [Not a human study]
502 Mezzanotte WS, Miller CJ, Senn S. Comparative bronchodilatory effects of formoterol dry powder inhaler (DPI) versus the combination of formoterol and budesonide pressurized metered dose inhaler (pMDI). J Allergy Clin Immunol. 2007;119;Suppl 1:S248. [Not an intervention of interest]
503 Micheletto C, Mauroner L, Burti E, . Inhaled beclomethasone dipropionate and budesonide dry powder in chronic asthma: lung function-serum ECP relationship. Eur Respir J. 1998;12;Suppl 28:351. [Not an intervention of interest]9727784
504 Mild asthma may not require daily corticosteroid use. Pharm J. 2005 Apr;274(7345):442. [Not a human study]
505 Milenkovic B, Bosnjak-Petroic V. Self-management program in treatment of asthma. Srpski Arhiv Za Celokupno Lekarstvo. 2007 Mar–Apr;135:147–52. [Not an intervention of interest]17642451
506 Mileva S, Galeva I, Kufardzhieva A, . Inhaled corticosteroids in wheezing infants with clinical diagnosis asthma [Abstract]. XIX World Allergy Organization Congress; 2005:853p. [Excluded study design]
507 Milgrom H, Berger W, Noonan M, . Rapid onset of significant improvements in peak expiratory flow among children with asthma treated with mometasone furoate administered via a dry powder inhaler. Chest. 2008;134(4):51003s. [Not an intervention of interest]
508 Miller DS, Yiu G, Hellriegel ET, . Dose-ranging study of salmeterol using a novel fluticasone propionate/salmeterol multidose dry powder inhaler in patients with persistent asthma. Allergy Asthma Proc. 2016;37:291–301. PMID: 27216137. [Not an intervention of interest]27216137
509 Mitra A, Sims EJ, Mukhopadhyay S, . Low-dose inhaled corticosteroid (ICS) confers optimal anti-inflammatory effects while additional bronchodilator activity is afforded by salmeterol in mild persistent asthmatic children. J Allergy Clin Immunol. 2003;111;Suppl 2:S145. [Not an intervention of interest]
510 Mitsui S, Yoshida T, Kobayashi S, . Double-blind study on the clinical effect of beclomethasone dipropionate inhaler and its placebo in the treatment of steroid-independent bronchial asthma. Rinsho Hyoka. 1977;5(2):213–30. [Not an intervention of interest]
511 Miyamoto T, Takishima T, Makino S, . Clinical Examination of Fluticasone Propionate Dry Powder: Comparison between Beclomethasone Dipropionate Inhaler in Bronchial Asthma. Rinsho Iyaku. 1994;10(2):321–45. [Not an intervention of interest]
512 Moeller A, Franklin P, Hall GL, . Inhaled fluticasone dipropionate decreases levels of nitric oxide in recurrenty wheezy infants. Pediatr Pulmonol. 2004 Sep;38(3):250–5. PMID: 15274106. [Not an intervention of interest]15274106
513 Moeller A, Franklin PJ, Straub D, . Inhaled fluticasone diproprionate decreases levels of nitric oxide in recurrently wheezy infants. Eur Respir J. 2003;22;Suppl 45:388. [Not an intervention of interest]
514 Mohan G, MacLusky KA, Godley CC, . A comparison of a budesonide-based and a beclomethasone/prednisolone-based management strategy for the treatment of severe asthma in general practice. Dis Manage Health Out. 1999;5(2):83–91. DOI: 10.2165/00115677-199905020-00003. [Not an intervention of interest]
515 Mometasone (asmanex twisthaler) for asthma. Med Lett Drugs Ther. 2005 Dec 5–19;47(1223–1224):98–9. PMID: 16331243. [Not a human study]16331243
516 Mometasone/Formoterol (dulera) for asthma. Med Lett Drugs Ther. 2010 Oct 18;52(1349):83–4. PMID: 21045758. [Not a human study]21045758
517 Montelukast for persistent asthma. Med Lett Drugs Ther. 1998 Jul 17;40(1031):71–3. PMID: 9698701. [Not a human study]9698701
518 More support for single maintenance and reliever therapy regimens for asthma. Drug Ther Bull. 2013;51(5):51–2. [Not a human study]
519 Morgul M, Cerrahoglu K, Ilvan A, . The effect of inhaled budesonide on pulmonary function (FEV1) of asthmatic patients. Eur Respir J. 1998;12;Suppl 29:73. [Not an intervention of interest]
520 Morimoto Y, Yagura T, Yamamura Y. The effect of prolonged administration of beclomethasone dipropionate inhaler on adrenocortical functions in bronchial asthma. J Med. 1977;8(1):1–26. PMID: 194990. [Not an intervention of interest]194990
521 Moss MH. Long-term effect of budesonide on hypothalamic-pituitary-adrenal axis function in children with mild to moderate asthma. Pediatrics. 2005;116(2):567. [Not a human study]
522 Murphy K, Fitzpatrick S, Cruz Rivera M, . Greater caregiver satisfaction and compliance with budesonide inhalation suspension vs cromolyn sodium. Am J Respir Crit Care Med. 2002;165;Suppl 8:A742. [Not an intervention of interest]
523 Murphy K, Nelson H, Parasuraman B, . Patient satisfaction with budesonide and formoterol in one pressurized metered-dose inhaler in adults with mild to moderate persistent asthma [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. 928p. [Irretrievable]
524 Murphy KR, Meltzer EO, Nolte H, . Quality of life is improved in persistent asthma subjects treated with mometasone furoate/formoterol: a new inhaled corticosteroid/long-acting beta2-agonist combination. Chest. 2010;138(4):159A. [Not an intervention of interest]
525 Murphy KR, Parasuraman B, Pethick N, . Greater improvement in functional health status with budesonide inhalation suspension (pulmicort respules) versus conventional therapy in children with persistent asthma. Pediatr Res. 2002;51(4):177A. [Not an intervention of interest]11809911
526 Murphy KR, Pearlman DS, Uryniak T, . Efficacy of budesonide/formoterol pressurized metered dose inhaler (BUD/FM pMDI) in children with asthma previously treated with inhaled corticosteroids (ICSs) [Abstract]. American Thoracic Society International Conference; 2008 May 16–21; Toronto, Canada. A710. [Not an intervention of interest]
527 Murphy VE, Jensen ME, Mattes J, . The breathing for life trial: a randomised controlled trial of fractional exhaled nitric oxide (FENO)-based management of asthma during pregnancy and its impact on perinatal outcomes and infant and childhood respiratory health. BMC Pregnancy and Childbirth. 2016;16:111. DOI: 10.1186/s12884-016-0890-3. [Not a human study]27189595
528 Murphy VE, Powell H, Gibson P. Exacerbations following step down and step up inhaled corticosteroid therapy in the managing asthma in pregnancy (MAP) study. Am J Respir Crit Care Med. 2015;191:A4275. [Not an intervention of interest]
529 Murphy VE, Powell H, Gibson PG. Exacerbations of asthma following changes in inhaled corticosteroid (ICS) and long acting beta agonist (LABA) therapy in the managing asthma in pregnancy (MAP) study. J Paediatr Child Health. 2015;62:64. [Not an intervention of interest]
530 Murphy VK, Ververeli K. Antibody response after varicella vaccination similar in children treated with budesonide inhalation suspension (BIS) or nonsteroidal conventional asthma therapy (NSCAT). Eur Respir J. 2006;28;Suppl 50;711. [Excluded study design]
531 Murray C, Martin L, Deas J, . Early intervention with inhaled fluticasone propionate (FP) in wheezy children under 2 years of age [abstract]. American Thoracic Society International Conference; 2003. 617p. [Irretrievable]
532 Murray CS, Gore C, Kerry G, Custovic A, . Inhaled fluticasone propionate in young wheezy children- does early use alter the course of disease? [Abstract]. American Thoracic Society International Conference; 2006 May 19–24; San Diego, California: Proceedings of the American Thoracic Society; 2006:A54p. [Irretrievable]
533 Murray CS, Woodcock A, Langley SJ, . Secondary prevention of asthma by the use of inhaled fluticasone propionate in wheezy INfants (IFWIN): Double-blind, randomised, controlled study. Lancet. 2006 Aug 26;368(9537):754–62. PMID: 16935686. [Not an intervention of interest]16935686
534 Murray JJ, Busse W, Dockhorn R, . Long-term safety of mometasone furoate (MF) administered by dry powder inhaler (DPI) in patients with moderate persistent asthma. Eur Respir J. 2000;16;Suppl 31:280. [Irretrievable]
535 Naji N, O’Byrne PM. Asthma maintenance and reliever therapy. Ann Allergy Asthma Immunol. 2012 Dec;109(6):388–91. [Not a human study]23176874
536 Nakanishi AK, Klasner AK, Rubin BK. A randomized controlled trial of inhaled flunisolide in the management of acute asthma in children. Chest. 2003 Sep;124(3):790–4. PMID: 12969999. [Not in the target population]12969999
537 Nana A, Youngchaiyud P, Charoenratanakul S, . High-dose inhaled budesonide may substitute for oral therapy after an acute asthma attack. J Asthma. 1998;35(8):647–55. PMID: 9860085. [Not in the target population]9860085
538 Nathan R, Pearlman D, Nayak A, . Safety and tolerability of medium-dose mometasone furoate/formoterol treatment versus mometasone furoate or formoterol monotherapies in persistent asthmatics who previously used medium-dose inhaled corticosteroids (alone or with long-acting beta2-agonist). Chest. 2009;136(4):8S. [Not an intervention of interest]
539 Nayak A, Charous BL, Finn A, . A novel inhaled corticosteroid ciclesonide significantly improves quality of life in patients with mild-to-moderate asthma. J Allergy Clin Immunol. 2005;115;Suppl 2:S210. [Not an intervention of interest]
540 Nebulized budesonide for asthma in children. Med Lett Drugs Ther. 2001 Jan;43(1096):6–7. [Not a human study]11177221
541 Nebulized budesonide for asthma in children. Med Lett Drugs Ther. 2001 Jan 22;43(1096):6–7. PMID: 11177221. [Not a human study]11177221
542 Nelson H, Murphy K, Parasuraman B, . Budesonide and formoterol in one metered dose inhaled improves health related quality of life in adults with mild to moderate persistent asthma previously treated with inhaled corticosteroids. J Allergy Clin Immunol. 2007;119;Suppl 1:S246. [Not an intervention of interest]
543 Nelson HS, Baitinger L, Scott C, . Salmeterol/fluticasone propionate (50/100μg dose) non-CFC metered dose inhaler is safe and effective in patients with asthma using short-acting β2-agonists alone. Eur Respir J. 2000;16;Suppl 31:53. [Not an intervention of interest]
544 New data from asthma and COPD inhaler studies. Pharm J. 2000 Sep;265(7113):355. [Not a human study]
545 Newman K, Corren J, Nelson H. Improves pulmonary function in patients with mild-to-moderate asthma treated with inhaled HFA Flunisolide for 12 weeks. J Allergy Clin Immunol. 2001;107(2):S104. [Not an intervention of interest]
546 NICE endorses costly inhaler devices for children if asthma better controlled. Pharm J. 2002 Apr;268(7194):524. [Not a human study]
547 Nielson K, Mather DC, Clements D, . Inhaled fluticasone propionate inproves asthma-related quality of life in oral steroid-dependent asthmatic subjects undergoing reduction or elimination of oral steroid use. J Allergy Clin Immunol. 2001;107(2):S100. [Not an intervention of interest]
548 Nielson KG, Bisgard H. Effect of inhaled budesonide on symptoms, lung functions and bronchial hyperresponsiveness to cold, dry air challenge in preschool children. Eur Respir J. 2000;16;Suppl 31:306. [Not an intervention of interest]
549 Niphadkar P, Joshi J, Mahesh PA, . Randomized double blind comparison of ciclesonide formoterol combination inhale rand ciclesonide alone in persistent asthma [Abstract]. European Respiratory Society Annual Congress; 2008 Oct 4–8; Berlin, Germany. E4278. [Not an intervention of interest]
550 Niu CK, Huang SC, Huang CB. Effect of short-course budesonide on the bone turnover of asthmatic children. Pediatr Pulmonol. 1998 Oct;26(4):290–2. PMID: 9811081. [Not an intervention of interest]9811081
551 Noble V, Ruggins NR, Everard ML, . Inhaled budesonide for chronic wheezing under 18 months of age. Arch Dis Child. 1992 Mar;67(3):285–8. PMID: 1575550. [Not an intervention of interest]1575550
552 Noonan M, Berger W, Thomas R, . Inhaled fluticasone propionate dry powder administered via the diskus or diskhaler is safe and effective in pediatric patients with chronic asthma. Eur Respir J. 1997;10;Suppl 25:221. [Not an intervention of interest]
553 Noonan M, Corren J, Leflein J. Safety of mometasone furoate dry powder inhaler and comparison with beclomethasone dipropionate in children with asthma previously maintained on inhaled corticosteroids (ICS). Chest. 2004;126;Suppl 4:912. [Not an intervention of interest]
554 Noonan MJ, Rosenwasser LJ, Martin P, . Effect of budesonide and formoterol administered via one pressurized metered dose inhaler on lung function in adults and adolescents with moderate to severe persistent asthma. J Allergy Clin Immunol. 2007;119;Suppl 1:S2. [Not an intervention of interest]
555 Novotna B, Teturova J, Kolman P, . A multi-centre, double-blind, double-dummy, randomised, parallel group study to assess efficacy and safety of beclometasone dipropionate and ease of handling of a breath operated aerosol inhaler in adults with reversible airways obstruction. Eur Respir J. 2001;18;Suppl 33:101. [Not an intervention of interest]
556 Nuhoglu Y, Bahceciler NN, Barlan IB, . The effectiveness of high-dose inhaled budesonide therapy in the treatment of acute asthma exacerbations in children. Ann Allergy Asthma Immunol. 2001 Mar;86(3):318–22. PMID: 11289332. [Not an intervention of interest]11289332
557 O’ Byrne P, Pedersen S, Lamm C-J, . Severe exacerbations, decline in lung function and inhaled budesonide in asthma. Eur Respir J. 2007;30;Suppl 51:619. [Not an intervention of interest]
558 O’ Connor RD, Patrick DL, Parasuraman MB, . Patient satisfaction during treatment with adjustable dose budesonide/formoterol pressurized metered dose inhaler (BUD/FM pMDI) fixed dose BUD/FM pMDI and fixed dose fluticasone/salmeterol dry powder inhaler (FP/SM DPI) [Abstract]. American Thoracic Society International Conference; 2008 May 16–21; Toronto, Canada. A609. [Not an intervention of interest]
559 O’ Connor TM, Kelley MM, Leigh R, . Additional anti-inflammatory effects of inhaled budesonide in subjects with atopic asthma. Eur Respir J. 2006;28;Suppl 20:441. [Not an intervention of interest]
560 O’ Dowd L, Berger WE, Leflein JG, . Health related quality of life (HRQL) and asthma control after long term treatment with budesonide and formoterol administered via one pressurized meter dose inhaler (pMDI) compared with budesonide dry powder inhaler (DPI) alone in children with asthma. J Allergy Clin Immunol. 2008;21;2 Suppl 1:S152. [Not an intervention of interest]
561 Obodo O, Ige O, Chukwu C. Scientific rationale for using a single inhaler for asthma control by comparison of the effectiveness and safety of formoterol/budesonide turbuhaler as physician-guided adjustable maintenance dosing regimen versus formoterol/budesonide given as fixed dose of twice daily therapy in the management of bronchial asthma [Abstract]. European Respiratory Society Annual congress; 2009 Sep 12–16; Vienna, Austria. 1968. [Not an intervention of interest]
562 O’Brien CD, Peters SP, Prenner BM, . Long-term safety of budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) in asthma patients: adverse events and asthma exacerbations [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. L57p. [Irretrievable]
563 O’Brien CD, Peters SP, Prenner BM, . Resource use with budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) versus BUD pMDI in asthma patients [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. L58p. [Irretrievable]
564 O’Byrne P, Barnes P, Rodriguez-Roisin R, . Low dose inhaled budesonide with and without formoterol in steroid free patients with mild persistent asthma [abstract]. Am J Respir Crit Care Med. 2001;163;Suppl 5:A862. [Irretrievable]
565 O’Byrne PM, Godard P, Pistolesi M, . Single inhaler therapy with budesonide/formoterol improves asthma control compared with fixed dosing with budesonide/formoterol or a higher dose of budesonide alone [Abstract]. American Thoracic Society International Conference; 2004 May 21–26; Orlando, FL. J93p. [Irretrievable]
566 O’Callaghan C, Milner AD. Inhaled steroids and recurrent wheeze after bronchiolitis. Lancet. 1989 Jun 24;1(8652):1458. PMID: 2567473. [Not a human study]2567473
567 O’Connor TM, Kelly MM, Leigh R, . Anti-inflammatory effects of inhaled budesonide combined with formoterol after allergen challenge in subjects with atopic asthma [Abstract]. American Thoracic Society International Conference; 2006 May 19–24; San Diego, California. A75. [Not an intervention of interest]
568 Oliver AJ, Covar RA, Goldfrad CH, . Randomised trial of once-daily vilanterol in children with asthma on inhaled corticosteroid therapy. Respir Res. 2016;17(1):37. PMID: 27044326. [Not an intervention of interest]27044326
569 Oliver AJ, Covar RA, Goldfrad CH, . Randomised trial of once-daily vilanterol in children with asthma on inhaled corticosteroid therapy. Respir Res. 2016;17(1):37. DOI: 10.1186/s12931-016-0353-4. [Not an intervention of interest]27044326
570 Olsson P, Stallberg B, Ekstrom T, . Adjustable maintenance treatment of asthma with budesonide and formoterol in a single inhaler [abstract]. European Respiratory Society Annual Congress; 2002. P2451. [Not an intervention of interest]
571 Olsson, Karlsson G, Ekstrom T, . Adjustable dosing with budesonide/formeterol in a single inhaler reduces costs compared with a conventional fixed dosing regimen. Eur Respir J. 2003;22;Suppl 45:P2643. [Not an intervention of interest]
572 Orr LC, Fowler SJ, Lipworth BJ. Relationship between changes in quality of life and measures of lung function and bronchial hyper-responsiveness during high-dose inhaled corticosteroid treatment in uncontrolled asthma. Am J Respir Med. 2003;2(5):433–8. PMID: 14719994. [Excluded study design]14719994
573 Ortega-Cisneros M, Maldonado-Alaniz ML, RosasVargas MA, . Salmeterol and inhaled beclomethasone versus high dose inhaled beclomethasone in the control of pediatric patients with moderate asthma. Ann Allergy Asthma Immunol. 1998;80:131. [Not an intervention of interest]
574 Osur S, Chervinsky P, Herie N, . Long term effects of fluticasone propionate (FP) inhalation aerosol in subjects with asthma. Am J Respir Crit Care Med. 1998;157;Suppl 3:A405. [Not an intervention of interest]
575 Paggiaro P, Nicolini G, Papi A. Extrafine beclomethasone dipropionate/formoterol hydrofluoroalkane-propelled inhaler in asthma. Expert Rev Resp Med. 2008;2(2):161–6. DOI: 10.1586/17476348.2.2.161. [Not a human study]
576 Palmer KP, Green TD, Williams LW. Effects of inhaled fluticasone propionate in children less than 2 years old with recurrent wheezing. Pediatrics. 2005;116(2):565–6. [Not a human study]
577 Palumbo R, Groth ML. The CAMP asthma study. Clin Pulm Med. 2001;8(3):192–3. [Not a human study]
578 Pao CS, McKenzie SA. Randomized controlled trial of fluticasone in preschool children with intermittent wheeze. Am J Respir Crit Care Med. 2002 Oct 1;166(7):945–9. PMID: 12359651. [Not an intervention of interest]12359651
579 Papi A, Marku B, Scichilone N, . Regular versus as-needed budesonide and formoterol combination treatment for moderate asthma: A non-inferiority, randomised, double-blind clinical trial. Lancet Respir Med. 2015 Feb;3(2):109–19. PMID: 25481378. [Not an intervention of interest]25481378
580 Papi A, Nicolini G, Boner AL, . Short term efficacy of nebulized beclomethasone in mild-to-moderate wheezing episodes in pre-school children. Ital J Pediatr. 2011;37:39. PMID: 21859484. [Not an intervention of interest]21859484
581 Parakh U, Gupta K, Sharma S, . A comparative evaluation of the efficacy of inhaled beclomethasone dipropionate, budesonide and fluticasone propionate in the management of bronchial asthma. Indian J Allergy Asthma Immunol. 2004;18(1):33–8. [Not an intervention of interest]
582 Parasuraman B, Murphy KR, Pethick N, . Budesonide inhalation suspension improves the functional health status of pediatric asthmatic patients. Eur Respir J. 2001;18;Suppl 33:121. [Not an intervention of interest]
583 Parasuraman B, Pethick N, Juniper E, . Budesonide inhalation suspension improves quality of life in families of childrem with asthma. J Allergy Clin Immunol. 2001;107(2):S102. [Not an intervention of interest]
584 Park J, Lee J, Whang K, . The effect of salbutamol and budesonide inhalation therapy in infants with bronchiolitis. J Korean Pediatr Soc. 1997l40(1):45–54. [Not in the target population]
585 Patel M, Pilcher J, Beasley R. Combination ICS/fast-onset LABA inhaler as maintenance and reliever therapy: The future for uncontrolled adult asthma?. Expert Rev Respir Med. 2013 Oct;7(5):451–4. PMID: 24138688. [Not a human study]24138688
586 Patel M, Pilcher J, Reddel HK, . Metrics of salbutamol use as predictors of future adverse outcomes in asthma. Clin Exp Allergy. 2013 Oct;43(10):1144–51. PMID: 24074332. [Not an intervention of interest]24074332
587 Patel YA, Patel P, Bavadia H, . A randomized, open labeled, comparative study to assess the efficacy and safety of controller medications as add on to inhaled corticosteroid and long-acting beta2 agonist in the treatment of moderate-to-severe persistent asthma. J Postgrad Med. 2010 Oct–Dec;56(4):270–4. PMID: 20935397. [Not an intervention of interest]20935397
588 Pauli G, Aubert B. A comparison of inhaled fluticasone propionate with nedocromil in the treatment of moderate adult asthma. A French Study Group. European Journal of Clinical Researach. 1995;7:45–56. [No English language abstract]
589 Pearlman D, Kerwin E, Kim K, . Fluticasone prorionate HFA-134 A significantly improves asthma control in inhaled corticosteroid dependent asthmatics. Am J Respir Crit Care Med. 2002;165;Suppl 8:A770. [Not an intervention of interest]
590 Pearlman DS, Murphy KR, Uryniak T, . Safety of budesonide/formoterol pressurized metered dose inhaler (BUD/FM pMDI) in children with asthma previously treated with inhaled corticosteroids (ICSs) [Abstract]. American Thoracic Society International Conference; 2008 May 16–21; Toronto, Canada. A710. [Not an intervention of interest]
591 Pearlman DS, Uryniak T, O’Brien CD, . Predose forced expiratory flow between 25% and 75% (FEF25–75%) in inhaled corticosteroid (ICS)-dependent patients with mild to moderate or moderate to severe persistent asthma receiving budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI). J Allergy Clin Immunol. 2009;123;2 Suppl 1:S158. [Not an intervention of interest]
592 Pedersen S. Budesonide plus formoterol for reliever therapy in asthma. Lancet. 2006 Aug;368(9537):707–8. [Not a human study]16935666
593 Pelkonen AS, Hakulinen AL, Hallman M, . Effect of inhaled budesonide therapy on lung function in schoolchildren born preterm. Respir Med. 2001 Jul;95(7):565–70. PMID: 11453312. [Not in the target population]11453312
594 Pelkonen AS, Malmstrom K, Malmberg LP, . Budesonide improves decreased airway conductance in infants with respiratory symptoms. Arch Dis Child. 2009 Jul;94(7):536–41. PMID: 19254906. [Not an intervention of interest]19254906
595 Pepys J. Effects of inhaled beclomethasone dipropionate on bronchial provocation test reactions. Postgrad Med J. 1975;51;Suppl 4:42–8. PMID: 812074. [Not a human study]812074
596 Perera BJ. Efficacy and cost effectiveness of inhaled steroids in asthma in a developing country. Arch Dis Child. 1995 discussion 315–6; Apr;72(4):312–5. PMID: 7763062. [Not an intervention of interest]7763062
597 Perlman DS, Kent E, Lanz MJ, . Fluticasone propionate/salmeterol HFA MDI has a rapid onset of effect in asthmatics treated with short or long-acting beta2-agonists (BA) or inhaled corticosteroids (ICS). Annual Thoracic Society 97th International Conference; 2001 May 18–23; San Francisco CA. A865. [Not an intervention of interest]
598 Pescollderungg L, Radetti G, Gottardi E, . Inhaled fluticasone in asthmatic children. Ann Allergy Asthma Immunol. 2002 author reply 329; Sep;89(3):328–9. PMID: 12269658. [Not an intervention of interest]12269658
599 Peters SP, Prenner BM, Martin P, . Bronchodilation with budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) vs BUD pMDI in asthma patients [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. K6p. [Irretrievable]
600 Peters SP, Prenner BM, Martin P, . Long-term effects on lung function of budesonide (BUD) and formoterol (FM) in one pressurized metered-dose inhaler (BUD/FM pMDI) and BUD pMDI in patients with asthma [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. K5p. [Irretrievable]
601 Peters SP, Bleecker ER, Canonica GW, . Serious Asthma Events with Budesonide plus Formoterol vs. Budesonide Alone New England Journal of Medicine. 2016;Sept;375(9):850–60. PMID: 27579635 [not an intervention of interest]27579635
602 Petitto J, Jones SM. Adherence to inhaled corticosteroids: An ancillary study of the childhood asthma management program clinical trial. Pediatrics. 2012;130;Suppl 1:S37–8. DOI: 10.1542/peds.2012-2183JJJ. [Not a human study]
603 Pharmacotherapy - treatment of intermittent asthma with ICSs. Can Med Assoc J. 2005;173;Suppl 6:S33–6. [Not a human study]16157734
604 Pieters W, Ringdal N, Aubier M, . A new inhaler combination containing salmeterol and fluticasone propionate is well-tolerated in longterm use. Eur Respir J. 1998;12;Suppl 29:20. [Not an intervention of interest]
605 Pizzichini MM, Stirbulov R, Fristcher CC, . Efficacy and safety of a combination of budesonide/formoterol in a single capsule in uncontrolled asthma. Am J Respir Crit Care Med. 185:A3970. [Not an intervention of interest]
606 Pohl WR, Vetter N, Zwick H, . Adjustable maintenance dosing with budesonide/formoterol or budesonide: Double-blind study. Respir Med. 2006 Mar;100(3):551–60. PMID: 16005623. [Not an intervention of interest]16005623
607 Ponce CH, Rodrigquez ES, Rodriguez OAR. Administration of budesonide (inhaled steroid) to children to control intermittent asthma. Rev Alerg Mex. 2009;56(1):9–12. [Not in the target population]19374158
608 Poulton A, Liu A, Nanan R. Budesonide in preschool-age children with recurrent wheezing. N Engl J Med. 2012 Feb;366(6):570. [Not a human study]
609 Prasad R, Bandhu M, Kant S, . A comparative study on efficacy of inhaled fluticasone propionate and beclomethasone dipropionate in patients of bronchial asthma. Indian J Allergy Asthma Immunol. 2004;18(2):73–7. [Not an intervention of interest]
610 Prenner B, Berkowitz R, Bensch GW, . Onset of improvements of lung function with mometasone furoate dry powder inhaler (MF-DPI) in ICS-naive patients with asthma. J Allergy Clin Immunol. 2005;115;Suppl 2:S5. [Not an intervention of interest]
611 Prenner BM, Peters SP, Martin P, . Long-term control of asthma symptoms with budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) versus BUD pMDI [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. L67p. [Irretrievable]
612 Price D, Haughney J, Duerden M. The effect of switching to beclomethasone extrafine aerosol on symptom-free days. Eur Respir J. 2001;18;Suppl 33:69. [Not an intervention of interest]11510808
613 Price MJ, Mahajan P, Maden C, . Impact of inhaled fluticasone propionate on parental sleep disturbance and perception of asthma symptoms in pre-school children. J Allergy Clin Immunol. 1998;101(1(Pt 2)):S151. [Not an intervention of interest]
614 Priftis KN, Papadimitriou A, Nicolaidou P, . Testing for hypothalamic-pituitary-adrenal axis suppression in asthmatic children. Pediatr Allergy Immunol. 2008;19(5):466–7. [Not a human study]18713340
615 Pro-drug improves lung function. Pharm J. 2003 Oct;271(7270):487. [Not a human study]
616 Prosperini G, Spicuzza L, Piccillo G, . Rapid protective of effect of inhaled fluticasone on airway hyperresponsiveness to AMP in patients with fixed airway obstruction due to asthma but not COPD. Eur Respir J. 2006;28;Suppl 50:670. [Not an intervention of interest]16946099
617 Purello-D’Ambrosio F, Gangemi S, Merendino RA, . Fluticasone propionate reduces serum interleukin-8 levels in asthmatic patients. Respiration. 2000;67(3):348. PMID: 10867611. [Not an intervention of interest]10867611
618 Pyke SD, Frith L, Pritchard J, . Synergy with salmeterol and fluticasone proprionate after administration from a single inhaler (Seretide). Eur Respir J. 2001;18;Suppl 33:176. [Not a human study]11510791
619 Raissy HH, Blake K. As needed use of inhaled corticosteroids for management of mild persistent asthma in children. Pediatr Allergy Immunol Pulmonol. 2011 Dec;24(4):231–3. [Not a human study]22375279
620 Rakes G, Gaston B. Inhaled budesonide in acute asthma? J Pediatr. 2001 Sep;139(3):346–8. PMID: 11562611. [Not a human study]11562611
621 Ramirez I, Lumeng CN. Daily and intermittent corticosteroids have similar impact on recurrent wheezing in young children. J Pediatr. 2012;160(5):881. [Not a human study]
622 Randolph C. Poor adherence with inhaled corticosteroids for asthma: Can using a single inhaler containing budesonide and formoterol help? J Asthma. 2008;45(4):349. [Not a human study]
623 Reddel HK, Jenkins C, Quirce S, . Effect of different asthma treatments on risk of cold-related exacerbations. Eur Respir J. 2011 Sep;38(3):584–93. PMID: 21406510. [No outcomes of interest]21406510
624 Reddel HK, Peyters MJ, Wark PA, . Comparison of the efficacy of Seretide and Flixotide when down-titrating the inhaled corticosteroid dose. Respirology. 2007;12;Suppl 1:A40. [Not an intervention of interest]
625 Reddel HK, Ware SI, Marks GB, . Effect of starting dose of inhaled budesonide on airway hyperresponsiveness in poorly controlled asthma. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 105p. [Irretrievable]
626 Reddel HK, Ware SI, Marks GB, . Long-term back-titration of inhaled corticosteroids - the effect of starting dose. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 106p. [Irretrievable]
627 Reddel HK, Yan KY. Single maintenance and reliever therapy (SMART) of asthma. Thorax. 2011 Jan;66(1):86–7. PMID: 21097538. [Not a human study]21097538
628 Reddel HK. Increasing the dose of inhaled corticosteroid when asthma deteriorates--does it prevent severe exacerbations?. Pol Arch Med Wewn. 2010 Mar;120(3):64–7. PMID: 20332710. [Not a human study]20332710
629 Reijonen T, Korppi M, Kuikka L, . Anti-inflammatory therapy reduces wheezing after bronchiolitis. Arch Pediatr Adolesc Med. 1996 May;150(5):512–7. PMID: 8620234. [Not an intervention of interest]8620234
630 Reijonen TM, Korppi M. One-year follow-up of young children hospitalized for wheezing: The influence of early anti-inflammatory therapy and risk factors for subsequent wheezing and asthma. Pediatr Pulmonol. 1998 Aug;26(2):113–9. PMID: 9727762. [Not an intervention of interest]9727762
631 Reijonen TM, Kotaniemi-Syrjanen A, Korhonen K, . Predictors of asthma three years after hospital admission for wheezing in infancy. Pediatrics. 2000 Dec;106(6):1406–12. PMID: 11099596. [Not an intervention of interest]11099596
632 Riccioni G, D’Orazio N, Castronuovo M, . Dosage tapering of inhalatory budesonide in subjects with mild to moderate persistent asthma treated with montelukast. Eur Respir J. 2003;22;Suppl 45:P713. [Not an intervention of interest]
633 Rice-McDonald G, Bowler S, Staines G, . Doubling daily inhaled corticosteroid dose is ineffective in mild to moderately severe attacks of asthma in adults. Intern Med J. 2005 Dec;35(12):693–8. PMID: 16313543. [No outcomes of interest]16313543
634 Riedler J, Huttegger I. Long-term effect of inhaled corticosteroid and cromoglycate on the bronchial responsiveness in children with asthma. Eur Respir J. 1992;5;Suppl 15:309. [Not an intervention of interest]
635 Robinson WS, Blaiss MS. Randomized trial to evaluate efficacy and safety of combination budesonide and formoterol and new FDA mandate regarding LABAs. Hosp Pract (Minneap). 2010 Jun;38(3):79–81. PMID: 20499777. [Not a human study]20499777
636 Robinson WS, Blaiss MS. Randomized trial to evaluate efficacy and safety of combination budesonide and formoterol and new FDA mandate regarding LABAs. Hosp Pract (Minneap). 2010;38(3):79–81. [Not a human study]
637 Roche N, Postma DS, Colice G, . Differential effects of inhaled corticosteroids in smokers/ex-smokers and nonsmokers with asthma. Am J Respir Crit Care Med. 2015 Apr 15;191(8):960–4. PMID: 25876207. [Not an intervention of interest]25876207
638 Rodriguez Santos O, Celio Murillo R. Quality of life in asthmatic children in Cuba and Mexico that use inhaled steroids. Acta Pediatr Esp. 2010;68(3):124–7. [Not an intervention of interest]
639 Rogala B, Majak P, Gluck J, . Asthma control in adult patients treated with a combination of inhaled corticosteroids and long-acting beta2-agonists: a prospective observational study. Polish Archives Of Internal Medicine. 2017;127(2):100–106. PMID: 28220767 [not an intervention of interest]28220767
640 Rogers AJ, Tantisira KG, Fuhlbrigge AL, . Phenotypic predictors of poor response to inhaled corticosteroids in asthmatic children over four years [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. 617p. [Irretrievable]
641 Roorda RJ, Mezei G, Bisgaard H, . Response of preschool children with asthma symptoms to fluticasone propionate. J Allergy Clin Immunol. 2001 Oct;108(4):540–6. PMID: 11590379. [Not an intervention of interest]11590379
642 Rosenhall L, Heinig JH, Lindqvist A, . Budesonide and formoterol in a single inhaler is safe and effective in the treatment of asthma. Eur Respir J. 2001;18;Suppl 33:159. [Not an intervention of interest]
643 Rosenhall L, Heinig JH, Lindqvist A, . Symbicort (budesonide/formoterol in a single inhaler) is safe and effective in the treatment of asthma. Thorax. 2011;56;Suppl 3:iii63. [Not an intervention of interest]
644 Rosenhall L, Lundqvist G, Adelroth E, . Comparison between inhaled and oral corticosteroids in patients with chronic asthma. Eur J Respir Dis Suppl. 1982;122;Suppl 122:154–62. PMID: 6958480. [Not an intervention of interest]6958480
645 Rosenhall L, Stahl E, Heinig JH, . Health-related quality of life and asthma control in patients using symbicort(R) (budesonide and formoterol in a single inhaler). Annual Thoracic Society 97th International Conference; 2001; San Francisco CA. D31p. [Not an intervention of interest]
646 Rosenhall L, Stahl E, Heinig JH, . Health-related quality of life and asthma control in patients treated with budesonide and formoterol in a single inhaler. Eur Respir J. 2001;18;Suppl 33:46. [Not an intervention of interest]
647 Rosenwasser LJ, Noonan MJ, Martin P, . Safety of budesonide and formoterol administered via one pressurized metered dose inhaler (budesonide/formoterol pMDI) in patients (>12 years) with moderate to severe persistent asthma. J Allergy Clin Immunol. 2007;119;Suppl 1:S5. [Not an intervention of interest]
648 Rowe BH, Bota GW, Fabris L, . Inhaled budesonide in addition to oral corticosteroids to prevent asthma relapse following discharge from the emergency department: A randomized controlled trial. JAMA. 1999 Jun 9;281(22):2119–26. PMID: 10367823. [Not in the target population]10367823
649 Rowe BH, Wong E, Blitz S, . Adding long-acting beta-agonists to inhaled corticosteroids after discharge from the emergency department for acute asthma: A randomized controlled trial. Acad Emerg Med. 2007 Oct;14(10):833–40. PMID: 17898245. [Not in the target population]17898245
650 Rutkowski R, Rutkowski K, Bilbin M, . Childhood asthma - effect of regular and on demand formoterol with budesonide treatment twice a day. Int Rev Allergol Clin Immunol. 2009;15(3–4):52–8. [Not an intervention of interest]
651 Rytila P, Lisa G, Varghese S, . Inhaled mometasone benefits adult patients with asthma like symptoms but not fulfilling functional asthma criteria. Eur Respir J. 2007;30;Suppl 51:351. [Not in the target population]
652 Sacks H, Gates D, Kuo WL, . Assessment of the defined daily dose for mometasone furoate dry powder inhaler in persistent asthma. Eur Respir J. 2003;22;Suppl 45:P335. [Not an intervention of interest]
653 Sahu GN, Mania RN, Panigrahi MK, . Comparison of inhaled salmeterol and budesonide with salmeterol and fluticasone propionate in patients with moderate to severe asthma. Indian J Allergy Asthma Immunol. 2004;18(2):100–1. [Not an intervention of interest]
654 Saito M, Kikuchi Y, Hoshina M. Inhaled high dose budesonide is as effective as systemic corticosteroids for children under three with mild asthma exacerbations. J Allergy Clin Immunol. 2016;137;2 Suppl 1:AB212. Embase 72197446. [Not in the target population]
655 Saito T, Hasunuma T. Safety and tolerability of high-dose budesonide/formoterol via turbuhaler in japanese patients with asthma: A randomized, double-blind, crossover, active comparator-controlled, phase III study. Clin Drug Invest. 2012 Jan 1;32(1):51–61. PMID: 22024920. [Not an intervention of interest]22024920
656 Saito T, Hasunuma T. Safety and tolerability of high-dose budesonide/formoterol via turbuhaler in Japanese patients with asthma: phase III study results. Am J Respir Crit Care Med. 2011;183;1MeetingAbstracts. [Not an intervention of interest]
657 Salvi S. Effect of inhaled formoterol and budesonide on exacerbations of asthma. N Engl J Med. 1998 Apr 9;338(15):1072. PMID: 9537880. [Not a human study]9537880
658 Sawicki GS, Strunk RC, Schuemann B, . Patterns of inhaled corticosteroid use and asthma control in the childhood asthma management program continuation study. Ann Allergy Asthma Immunol. 2010 Jan;104(1):30–5. PMID: 20143642. [Not an intervention of interest]20143642
659 Schokker S, Kooi EMW, de Vries TW, . Inhaled corticosteroids for recurrent respiratory symptoms in preschool children in general practice: Randomized controlled trial. Pulm Pharmacol Ther. 2008;21(1):88–97. PMID: 17350868. [Not an intervention of interest]17350868
660 Sears MR, Taylor DR, Print CG, . Increased inhaled bronchodilator vs increased inhaled corticosteroid in the control of moderate asthma. Chest. 1992 Dec;102(6):1709–15. PMID: 1446477. [Not an intervention of interest]1446477
661 See S, Rubin S. Tapering inhaled steroids effective for chronic asthma. J Fam Pract. 2003 Oct;52(10):748–51. PMID: 14529591. [Not a human study]14529591
662 Sehmi R, Wood LJ, Gauvreau GM, . Allergen-induced phenotypic changes in bone marrow progenitors from asthmatic subjects: effect of inhaled budesonide. Am J Respir Crit Care Med. 1998;157;Suppl 3:A871. [Not an intervention of interest]
663 Sekerel BE, Sackesen C, Tuncer A, . The effect of nebulized budesonide treatment in children with mild to moderate exacerbations of asthma. Acta Paediatr. 2005 Oct;94(10):1372–7. PMID: 16299866. [Not in the target population]16299866
664 Selroos O, Löfroos A-, Pietinalho A, . Asthma control and steroid doses 5 years after early or delayed introduction of inhaled corticosteroids in asthma: a real-life study. Respir Med. 2004;98(3):254–62. [Not an intervention of interest]15002762
665 Shah A, Solanki R, Shah K. Effect of add on therapy compared with doubling steroid inhalation in bronchial asthma. Thorax;59;Suppl II:ii70. [Not an intervention of interest]
666 Shah S. Asthma & COPD - SMi’s sixth annual conference. IDrugs. 2010;13(6):376–78. [Irretrievable]20506058
667 Shah SR, Busse WW, McElhattan J, . Efficacy and tolerability of fixed-dose (FD) and adjustable-dose (AD) budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) and FD fluticasone propionate/salmeterol dry powder inhaler (FP/SAL DPI) within racial groups. J Allergy Clin Immunol. 2009;123;2 Suppl 1:S80. [Not an intervention of interest]
668 Shah SR, Busse WW, Somerville L, . Asthma control with adjustable-and fixed-dose budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) and fixed-dose fluticasone/salmeterol dry powder inhaler (FP/SM DPI) [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. K4p. [Irretrievable]
669 Shamsul AI, Hadzri HM, Noradina AT, . Step-down approach in chronic stable asthma; a comparison of reducing dose inhaled formoterol/budesonide with maintaining inhaled budesonide. Respirology. 2007;12;Suppl 4:A141. [Not an intervention of interest]
670 Shimoda T, Obase Y, Kishikawa R, . Impact of inhaled corticosteroid treatment on 15-year longitudinal respiratory function changes in adult patients with bronchial asthma. Int Arch Allergy Immunol. 2013;162(4):323–9. PMID: 24193229. [Not an intervention of interest]24193229
671 Shiraishi S, Hirata K, Ohtani K, . Inhaled corticosteroid improved the perception of dyspnea during methacholine induced bronchoconstriction and changed the hypoxic ventilatory response in patients with asthma. Eur Respir J. 2002;20;Suppl 38:49. [Not an intervention of interest]
672 Shokker S, Kooi EM, Duiverman EJ, . Effectiveness of inhaled corticosteroids in preschool children with recurrent respiratory symptoms in general practice: Asterisk study. Prim Care Respir J. 2006;15(3):186. [Not an intervention of interest]
673 Simon RA. Clinical implications of combination therapy on the future of asthma management. Allergy Asthma Proc. 2003;24(2):91–3. [Irretrievable]12776441
674 Skoner D, Dunn M, Lee T. Effects of mometasone furoate dry powder inhaler on growth velocity and HPA axis function in children with asthma [abstract]. American Thoracic Society International Conference; 2003. A117p. [Irretrievable]
675 Smart BA. Daily or intermittent budesonide in preschool children with recurrent wheezing. Pediatrics. 2012;130;Suppl 1:S39–40. [Not a human study]
676 Smith AD, Cowan J, Taylor R. Optimising inhaled corticosteroid (ICS) dose using exhaled nitric oxide (eNO) measurements. Eur Respir J. 2003;22;Suppl 45:P342. [Not an intervention of interest]
677 Smith AD, Cowan JO, Brassett KP, . Use of exhaled nitric oxide measurements to guide treatment in chronic asthma. N Engl J Med. 2005 May 26;352(21):2163–73. PMID: 15914548. [Not an intervention of interest]15914548
678 Sole D. Inhaled steroids for young children with recurrent wheezing: Friend or foe? Allergol Immunopathol (Madr). 2009 Mar–Apr;37(2):55–6. PMID: 19445859. [Not a human study]19445859
679 Somerville L, Busse WW, Shah SR, . Safety of adjustable-dose budesonide (BUD)/formoterol (FM) pressurized metered-dose inhaler (pMDI), fixed-dose (BUD/FM pMDI and fixed-dose fluticasone (FP)/salmeterol (SM) dry powder inhaler (DPI) in asthma patients [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. K3p. [Irretrievable]
680 Sovijarvi ARA, Haahtela T, Ekroos HJ, . Sustained reduction of bronchial hyperresponsiveness with inhaled fluticasone propionate in mild asthma within three days [Abstract]. European Respiratory Soociety Annual Congress; 2002. P1244. [Not an intervention of interest]
681 Special circumstances. J Invest Allergol Clin Immunol. 2010;20;Suppl 1:43–9. [Not a human study]
682 Spector S, Backer V, Pavord I, . Dose-dependent anti-inflammatory effect of inhaled mometasone furoate/formoterol in subjects with asthma and high baseline exhaled nitric oxide and sputum eosinophils. J Allergy Clin Immunol. 2011;127;2 Suppl 1:AB161. [Not an intervention of interest]
683 Spector SL, O’ Brien CD, Uryniak T, . Safety and tolerability of a budesonide/formoterol (BUD/FM) pressurized metered-dose inhaler (pMDI) in black adolescents and adults with moderate to severe persistent asthma. Chest. 2010;138(4):705A. [Not an intervention of interest]
684 Spencer DA, Gleeson JG, Price JF. Inhaled budesonide for acute wheeze in infants. Lancet. 1989 Mar 25;1(8639):665. PMID: 2564474. [Not a human study]2564474
685 Spicuzza L, Scuderi V, Prosperini G, . Acute effect of inhaled fluticasone on airway hyperresponsiveness to adenosine 5′-monophosphate in asthma and in COPD [Abstract]. American Thoracic Society International Conference; 2004 May 21–26; Orlando, FL. K33p. [Irretrievable]
686 Spicuzza L, Scuderi V, Prosperini G, . Rapid protective effect of inhaled fluticasone on airway hyperresponsiveness to AMP in asthma but not in COPD. J Allergy Clin Immunol. 2004l113;Suppl 2:S266. [Not an intervention of interest]
687 Stahl E, Baker J, Pearlman D, . QVARA(R)-BAI (HFA-propelled beclomethasone dipropionate in a breath actuated inhaler) reduced the number of asthma exacerbations in moderate asthmatic adolescents and adults [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. F78p. [Irretrievable]
688 Stallberg B, Naya I, Ekelund J, . Real-life use of budesonide/formoterol in clinical practice: a 12-month follow-up assessment in a multi-national study of asthma patients established on single-inhaler maintenance and reliever therapy. Int J Clin Pharmacol Ther. 2015 Jun;53(6):447–55. PMID: 25907171. [Not an intervention of interest]25907171
689 Stallberg B, Olsson P, Ekstrom T, . Fewer asthma patients experience exacerbations with budesonide/formoterol in a single inhaler using adjustable versus fixed dosing. Eur Respir J. 2003;22;Suppl 45:P2798. [Not an intervention of interest]
690 Stallberg B, Olsson P, Jorgensen LA, . Budesonide/formoterol adjustable maintenance dosing reduces asthma exacerbations versus fixed dosing. Int J Clin Pract. 2003 Oct;57(8):656–61. PMID: 14627173. [Not an intervention of interest]14627173
691 Stanbrook MB. Is daily inhaled steroid use necessary in the treatment of mild persistent asthma? Can Med Assoc J. 2005 May;172(11):1439. [Not a human study]15911856
692 Stempel DA. Montelukast added to inhaled beclomethasone in treatment of asthma. Am J Respir Crit Care Med. 2000 Jul;162(1):331–2. PMID: 10903264. [Not a human study]10903264
693 Sterk PJ. Is there a need for higher doses of steroids in moderate asthma? Clin Exp Allergy Suppl Rev. 2001;1(1):39–44. [Not a human study]
694 Steroids show benifits in mild asthma. Pharm J. 2003 Mar;270(7242):429. [Not a human study]
695 Stockmann C, Reilly CA, Fassl B, . Effect of CYP3A5*3 on asthma control among children treated with inhaled beclomethasone. J Allergy Clin Immunol. 2015 Aug;136(2):505–7. PMID: 25825214. [Not an intervention of interest]25825214
696 Storms W, Glaet V, Banerji D, . RPR 106541 - an effective inhaled corticosteroid asthma therapy with minimal side-effects on the HPA axis. Eur Respir J. 1997;10;Suppl 25:175. [Not an intervention of interest]
697 Sudarshan S. Monotherapy vs. combination therapy for the management of mild asthma. Am Fam Phys. 2012;85(6):652. [Not a human study]
698 Suissa S, Ernst P. Comparison of inhaled beclomethasone and budesonide. studies of potencies of asthma drugs have methodological limitations. BMJ. 1999 Jul 10;319(7202):126. PMID: 10465595. [Not a human study]10465595
699 Sullivan SD, Buxton M, Andersson LF, . Budesonide increased symptom free days in patients with recent onset mild asthma at an additional cost of US$0.42/day. Evid -Based Med. 2004 May;9(3):90. [Not a human study]
700 Svedmyr J, Nyberg E, Asbrink-Nilsson E, . Intermittent treatment with inhaled steroids for deterioration of asthma due to upper respiratory tract infections. Acta Paediatr. 1995 Aug;84(8):884–8. PMID: 7488811. [Not in the target population]7488811
701 Syk J, Malinovschi A, Borres M, . Reduction of IgE by intensified antiinflammatory treatment in patients with atopic asthma. Allergy. 2014;69;Suppl 99:61. [Not an intervention of interest]
702 Syk J, Malinovschi A, Johansson G, . Anti-inflammatory treatment of atopic asthma guided by exhaled nitric oxide: A randomized, controlled trial. J Allergy Clin Immunol Pract. 2013 Nov–Dec;1(6):639,48.e1–8. PMID: 24565712. [Not an intervention of interest]24565712
703 Syk J, Malinovschi A, Johansson G, . Lower incidence of asthma exacerbations with FENO-guided anti-inflammatory treatment: a randomised controlled trial. Eur Respir J. 2012;40:4341. [Not an intervention of interest]
704 Syk J, Unden A, Alving K. Relationship between exhaled nitric oxide and IgE sensitisation in patients with asthma: Influence of steroid treatment. Clin Respir J. 2009 Jul;3(3):143–51. PMID: 20298397. [Excluded study design]20298397
705 Szefler SJ, Baker JW, Uryniak T, . Comparative study of budesonide inhalation suspension and montelukast in young children with mild persistent asthma. J Allergy Clin Immunol. 2007 Nov;120(5):1043–50. PMID: 17983871. [Not an intervention of interest]17983871
706 Szefler SJ, Carlsson L, Uryniak T, . Budesonide inhalation suspension versus montelukast in children aged 2 to 4 years with mild persistent asthma. J Allergy Clin Immunol Pract. 2013 Jan;1(1):58–64. PMID: 24229823. [Not an intervention of interest]24229823
707 Szefler SJ, Mitchell H, Sorkness CA, . Management of asthma based on exhaled nitric oxide in addition to guideline-based treatment for inner-city adolescents and young adults: A randomised controlled trial. Lancet. 2008 Sep 20;372(9643):1065–72. PMID: 18805335. [Not an intervention of interest]18805335
708 Tabachnik E, Zadik Z. Diurnal cortisol secretion during therapy with inhaled beclomethasone dipropionate in children with asthma. J Pediatr. 1991 Feb;118(2):294–7. PMID: 1993964. [Excluded study design]1993964
709 Tagaya E, Tamaoki J, Isono K, . Role of regular treatment with inhaled corticosteroid or leukotriene receptor antagonist in mild intermittent (step 1) asthma [Abstract]. American Thoracic Society International conference; 2008 May 16–21; Toronto. A70. [Not in the target population]
710 Takahashi K, Kotoh N, Soda R, . Usefulness of inhaled steroids in steroid-dependent intractable asthma--equivalent dose of oral steroid to inhaled steroid. Arerugi. 1994;43(9):1163–71. [Not an intervention of interest]7802600
711 Tal A, Simon G, Vermeulen JH, . Symbicort (budesonide and formoterol in a single inhaler) is more effective that budesonide alone in children with asthma. International Paediatric Respiratory and Allergy Congress; 2001. 84–5p. [Not an intervention of interest]
712 Tal A, Simon G, Vermeulen JH, . The benefit of the new single inhaler product containing both budesonide and formeterol in asthmatic children. Eur Respir J. 2000;16;Suppl 31:384. [Not an intervention of interest]
713 Tal A, Simon G, Vermeulen JH. Symbicort (budesonide and formoterol in a single inhaler) is effective and well tolerated in children with asthma. Annual Thoracic Society 97th International Conference; 2001 May 18–23; San Francisco CA. D29p. [Not an intervention of interest]
714 Tashkin D, Chipps B, Brown R, . Responder analysis evaluating the long-term treatment of budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pmdi) in patients with moderate to severe asthma with versus without fixed airflow obstruction (FAO). Chest. 2013;144;4 Meeting Abstracts:79A. [Not an intervention of interest]23392199
715 Tashkin DP, Chipps BE, Uryniak T, . Responder analysis evaluating the effect of budesonide/formoterol pressurized metered-dose inhaler (BUD/FM pMDI) in patients with moderate to severe asthma with versus without fixed airflow obstruction (FAO). J Allergy Clin Immunol. 2013;131(2):AB5. Embase 70984076. [Not an intervention of interest]
716 Telenga ED, Kerstjens HAM, ten Hacken NHT, . Inflammation and corticosteroid responsiveness in ex-, current- and never-smoking asthmatics. BMC Pulm Med. 2013 Sep;13(1):58. [Not an intervention of interest]24053453
717 Teper A, Murphy KR, Meltzer EO, . Reduction of relief medication use in children receiving inhaled mometasone fuorate for control of mild persistent asthma. J Allergy Clin Immunol. 2010;125;2 Suppl 1:AB195. [Not an intervention of interest]
718 Tereshchenko S, Bychkovskaya S, Nicolay S. “Stepping down” in mild-to-moderate asthmatic children being well controlled while receiving low doses of inhaled corticosteroids (ICS): daily vs. cyclical ICS administration (prospective, randomized, multicentre, open-label trial). Eur Respir J. 2013;42:P4300. [Abstract without full-text]
719 Terracciano L, Fiocchi A, Bouygue GR. Beclomethasone and albuterol in mild asthma. N Engl J Med. 2007 Aug 2;357(5):506–7. PMID: 17674456. [Not a human study]17674456
720 The use of newer asthma and allergy medications during pregnancy. the American College of Obstetricians and Gynecologists (ACOG) and the American College of Allergy, Asthma and Immunology (ACAAI). Ann Allergy Asthma Immunol. 2000 May;84(5):475–80. PMID: 10830999. [Not a human study]10830999
721 Thomas M, Pavord I. Single inhaler maintenance and reliever therapy (SMART) in general practice asthma management: where are we?. Prim Care Respir J. 2012 Mar;21(1):8–10. PMID: 22367253. [Not a human study]22367253
722 Thomas M, Prince D. High-dose inhaled corticosteroid versus long-acting beta-agonist addition in asthma. Chest. 2009 May;135(5):1404–5. PMID: 19420216. [Not a human study]19420216
723 Thomas M. Long-acting β-agonist step-up therapy is more likely to provide best response, compared to inhaled corticosteroid or leukotriene-receptor antagonist step-up in children with uncontrolled asthma receiving inhaled corticosteroids. Evid -Based Med. 2010;15(6):167–8. [Not a human study]20713541
724 Tivenius L, Kiviloog J, Glennow C. Effect of budesonide inhalation on airway obstruction at bronchial allergen provocation after varying lengths of pre-treatment. Allergy. 1984 Nov;39(8):639–40. PMID: 6528960. [Excluded study design]6528960
725 Tobin MJ. Asthma, airway biology, and allergic rhinitis in AJRCCM 2000. Am J Respir Crit Care Med. 2001 Nov;164(9):1559–80. [Not a human study]11719293
726 Tobin MJ. Asthma, airway biology, and nasal disorders in AJRCCM 2002. Am J Respir Crit Care Med. 2003 Feb;167(3):319–32. [Not a human study]12554621
727 Tobin MJ. Asthma, airway biology, and nasal disorders in AJRCCM 2001. Am J Respir Crit Care Med. 2002 Mar;165(5):598–618. [Not a human study]11874807
728 Tobin MJ. Pediatrics, surfactant, and cystic fibrosis in AJRCCM 2003. Am J Respir Crit Care Med. 2004 Jan;169(2):277–87. [Not a human study]14718241
729 Tobin MJ. Pediatrics, surfactant, and cystic fibrosis in AJRCCM 2002. Am J Respir Crit Care Med. 2003 2003 Feb;167(3):333–44. [Not a human study]12554622
730 Todd GR. Side-effects of high-dose fluticasone propionate in children. Eur Respir J. 1999 Mar;13(3):707–9. PMID: 10232453. [Not a human study]10232453
731 Tofts RPH. Steroids do not improve RSV-related wheeze in children. Thorax. 2009;64(9):769. [Not a human study]
732 Toth PP. Montelukast and fluticasone therapy in patients with mild persistent asthma. J Appl Res. 2005;5(3):ii. [Not a human study]
733 Trautmann M, Banik N, Jorres RA, . Acheivment of total control of asthma in clinical practice using the combination of inhaled salmeterol and fluticasone propionate. Eur Respir J. 2006;28;Suppl 50:616. [Not an intervention of interest]
734 Trautmann M, Banik N, Tews JT, . Efficacy of the combination of fluticasone propionate and salmeterol in patients with moderate persistent asthma within a “real-life” setting. Eur J Med Res. 2007 Jun 27;12(6):255–63. PMID: 17666315. [Not an intervention of interest]17666315
735 Treatment of asthma in children. J Invest Allergol Clin Immunol. 2010;20;Suppl 1:32–6. [Not a human study]
736 Treatment of persistent asthma: Novopulmon® 200 novolizer®, conceived to improve compliance with treatment. Eur Ann Allergy Clinical Immunol. 2005 Apr;37(4):152. [Not a human study]
737 Triamcinolone acetonide hydrofluoroalkane inhalation--aventis. Drugs R D. 2002;3(2):141–2. PMID: 12001820. [Not a human study]12001820
738 Turcotte H, Boulet LP, Prince FP, . Influence of inhaled fluticasone in asthma and asymptomatic airway hyperresponsiveness [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. F77p. [Irretrievable]
739 Turkas H, Levent E, Ouzulgen IK, . Effects of inhaler budesonide and nedocromil sodium on exhaled nitric oxide levels in mild asthmatic patients. Eur Respir J. 1998;12;Suppl 29:63. [Not an intervention of interest]
740 Turpeinen M, Pelkonen AS, Nikander K, . Bone mineral density in children treated with daily or periodical inhaled budesonide: The helsinki early intervention childhood asthma study. Pediatr Res. 2010 Aug;68(2):169–73. PMID: 20485203. [Not an intervention of interest]20485203
741 Turpeinen M, Pelkonen AS, Selroos O, . Continuous versus intermittent inhaled corticosteroid (budesonide) for mild persistent asthma in children--not too much, not too little. Thorax. 2012 Feb;67(2):100–2. PMID: 22038795. [Not a human study]22038795
742 Turpeinen M, Raitio H, Pelkonen AS, . Skin thickness in children treated with daily or periodical inhaled budesonide for mild persistent asthma. the helsinki early intervention childhood asthma study. Pediatr Res. 2010 Feb;67(2):221–5. PMID: 19858777. [Not an intervention of interest]19858777
743 Turpeinen M, Sorva R, Metso T, . Inhaled budesonide in adults with asthma - net formation of type I collagen is not decreased. Eur Respir J. 1994;7;Suppl 18:382. [Not an intervention of interest]
744 Turpeinen M, Sorva R. Inhaled beclomethasone dipropionate and growth in children with mild asthma. Am J Respir Crit Care Med. 1996 May;153(5):1726. PMID: 8630627. [Not a human study]8630627
745 Turpeinen M. Helsinki early intervention childhood asthma (HEICA) astudy: inhaled budesonide halved the number of asthma exacerbatoins compared with inhaled disodium cromoglycate during 18 months of treatment. Eur Respir J. 2000;16;Suppl 31:311. [Irretrievable]
746 Turton JA, Glasgow NJ, Brannan JD. Feasibility and acceptability of using bronchial hyperresponsiveness to manage asthma in primary care: A pilot study. Prim care respir j. 2012 Mar;21(1):28–34. PMID: 21938353. [Excluded study design]21938353
747 Udwadia ZF, Pinto LM. LABAs and asthma: From the SMART study to the SMART approach. Indian J Chest Dis Allied Sci. 2010 Oct–Dec;52(4):191–3. PMID: 21302593. [Not a human study]21302593
748 Utiger RD. Differences between inhaled and oral glucocorticoid therapy. N Engl J Med. 1993 Dec 2;329(23):1731–3. PMID: 8232464. [Not a human study]8232464
749 Vaessen-Verberne A, Van den Berg N, Brackel H, . Salmeterol/fluticasone propionate combination (SFC) versus doubling dose of fluticasone propionate (FP) in children with asthma insufficiently controlled on moderate doses of inhaled corticosteroids [Abstract]. European Respiratory Society Annual Congress; 2010 Sep 18–22; Barcelona, Spain. P2644. [Not an intervention of interest]
750 van den Berge M, Luijk B, Bareille P, . Fluticasone furoate, a novel inhaled corticosteroid (ICS) provides sustained protection against amp airway hyperresponsiveness (AHR) in mild asthma [Abstract]. European Respiratory Society Annual Congress; 2009 Sep 12–16; Vienna, Austria. 1804. [Not an intervention of interest]
751 van der Meer V, van Stel HF, Bakker MJ, . Weekly self-monitoring and treatment adjustment benefit patients with partly controlled and uncontrolled asthma: An analysis of the SMASHING study. Respir Res. 2010;11:74. PMID: 20537124. [Not an intervention of interest]20537124
752 van der Molen T, Foster JM, Mueller T. The effect of ciclesonide or fluticasone propionate on the perception of treatment-related side effects using the self--administered inhaled corticosteroid questionnaire (ICQ) [Abstract]. American Thoracic Society International Conference; 2007 May 18–23; San Francisco, California. L60p. [Irretrievable]
753 van Essen-Zandvliet EEM, Hughes MD, Waalkens HJ, . The effect of 30 months treatment with an inhaled corticosteroid and an inhaled beta2-agonist on airway responsiveness, airway calibre, bronchodilator response, symtoms and stage of remission in children with asthma. Eur Respir J. 1992;5;Suppl 15:180. [Not an intervention of interest]
754 van Schayck OCP, Haughney J, Aubier M, . Do asthmatic smokers benefit as much as non-smokers on budesonide/formoterol maintenance and reliever therapy? results of an open label study. Respir Med. 2012 Feb;106(2):189–96. PMID: 22119455. [Not an intervention of interest]22119455
755 Van Schoor J, Joos GF, Pauwels RA. The effects of inhaled fluticasone propionate on metacholine- and Neurokinin A-induced bronchoconstriction in asthmatics. European Respiratory Society; 1999 Oct 9–13; Madrid, Spain. 513s. [Irretrievable]
756 Vandenberg R, Tovey E, Love I, . Beclomethasone dipropionate. trial of a new inhalational steroid preparation in the treatment of steroid-dependent chronic asthmatics. Med J Aust. 1975 Feb 15;1(7):189–93. PMID: 1128399. [Excluded study design]1128399
757 Vandenberg R, Tovey E, Love I, . Beclomethasone dipropionate. trial of a new inhalational steroid preparation in the treatment of steroid-dependent chronic asthmatics. Med J Aust. 1975;1(7):189–93. [Excluded study design]1128399
758 Vander Leek TK. GOAL: What have we learned? Allergy Asthma Clin Immunol. 2005;1(3):117–9. [Not a human study]20529222
759 Varon J. Oral vs inhaled corticosteroids following emergency department discharge of patients with acute asthma. Chest. 2002;121(6):1735–6. [Not a human study]12065330
760 Vaz R, Senior B, Morris M, . Adrenal effects of beclomethasone inhalation therapy in asthmatic children. J Pediatr. 1982 Apr;100(4):660–2. PMID: 7062222. [Excluded study design]7062222
761 Ventura A, Strinati R, Longo G. Systemic effects and inhaled beclomethasone dipropionate. Lancet. 1986 Jun 14;1(8494):1393. PMID: 2872512. [Not a human study]2872512
762 Vermeulen JH, Simon G, Tal A, . Improved lung function and rapid control achieved with the new single inhaler product containing both budesonide and formeterol in asthmatic children aged 4–17 years. Eur Respir J. 2000;16;Suppl 31:384. [Not an intervention of interest]
763 Vidaurreta SM. Wheezing in infants: Can we separate the wheat from the chaff? Arch Argent Pediatr. 2013;111(3):188–9. [Not a human study]23732342
764 Virchow JC. Salmeterol powder provides significantly better benefit than montelukast in asthmatic patients receiving concomitant inhaled corticosteroid therapy. Chest. 2002 Jun;121(6):2083–4. PMID: 12065391. [Not a human study]12065391
765 Visser MJ, Brand PLP, Kamps AWA, . One year treatment with different schedules of inhaled fluticasone propionate in childhood asthma: effects on lung function and immunological parameters. Annual Thoracic Society 97th International Conference; 2001; San Francisco CA. D29p A846. [Not an intervention of interest]
766 Visser MJ, Postma DS, Arends LR, . One-year treatment with different dosing schedules of fluticasone propionate in childhood asthma. effects on hyperresponsiveness, lung function, and height. Am J Respir Crit Care Med. 2001 Dec 1;164(11):2073–7. PMID: 11739137. [Not an intervention of interest]11739137
767 Visser MJ, Postma DS, Brand PLP, . Influence of different dosage schedules of inhaled fluticasone propionate on peripheral blood cytokine concentrations in childhood asthma. Clin Exp Allergy. 2002 Oct;32(10):1497–503. PMID: 12372131. [Not an intervention of interest]12372131
768 Visser MJ, van der Veer E, Postma DS, . Side-effects of fluticasone in asthmatic children: no effects after dose reduction. Eur Respir J. 2004 Sep;24(3):420–5. [Not an intervention of interest]15358701
769 Volovitz B, Bentur L, Finkelstein Y, . Effectiveness and safety of inhaled corticosteroids in controlling acute asthma attacks in children who were treated in the emergency department: A controlled comparative study with oral prednisolone. J Allergy Clin Immunol. 1998 Oct;102(4 Pt 1):605–9. PMID: 9802368. [Not in the target population]9802368
770 Volovitz B, Bilavsky E, Nussinovitch M. Effectiveness of high repeated doses of inhaled budesonide or fluticasone in controlling acute asthma exacerbations in young children. J Asthma. 2008 Sep;45(7):561–7. PMID: 18773327. [Excluded study design]18773327
771 Volovitz B, Nussinovitch M, Finkelstein Y, . Effectiveness of inhaled corticosteroids in controlling acute asthma exacerbations in children at home. Clin Pediatr (Phila). 2001 Feb;40(2):79–86. PMID: 11261454. [Excluded study design]11261454
772 Volovitz B, Nussinovitch M. Effect of high starting dose of budesonide inhalation suspension on serum cortisol concentration in young children with recurrent wheezing episodes. J Asthma. 2003 Sep;40(6):625–9. PMID: 14579993. [Not an intervention of interest]14579993
773 Volovitz B, Nussinovitch M. Inhaled beta2-agonists and corticosteroids and the treatment of children with acute asthma attack. Isr Med Assoc J. 2002 Nov;4;SUPPL 11:891–2. [Irretrievable]12455174
774 Volovitz B, Soferman R, Blau H, . Rapid induction of clinical response with a short-term high-dose starting schedule of budesonide nebulizing suspension in young children with recurrent wheezing episodes. J Allergy Clin Immunol. 1998 Apr;101(4 Pt 1):464–9. PMID: 9564798. [Not an intervention of interest]9564798
775 Von Mutius E, Drazen JM. Choosing asthma step-up care. N Engl J Med. 2010 Mar;362(11):1042–3. [Not a human study]20197426
776 Voorend-van Bergen S, Vaessen-Verberne AA, Brackel HJ, . Monitoring strategies in children with asthma: A randomised controlled trial. Thorax. 2015 Jun;70(6):543–50. PMID: 25825006. [Not an intervention of interest]25825006
777 Vortkamp M, Ederle K, Hader S. Hydrofluoroalkane beclomethasone dipropionate extrafine aerosol efficacy response at reduced dose compared to other inhaled corticosteroids treatment regimens. Eur Respir J. 2001;18;Suppl 33:70. [Not an intervention of interest]
778 Wales JK, Barnes ND, Swift PG. Growth retardation in children on steroids for asthma. Lancet. 1991 Dec 14;338(8781):1535. PMID: 1683962. [Excluded study design]1683962
779 Wang CZ, Wang Y, Lin KX, . Comparison of inhaled corticosteroid combined with theophylline and double dose inhaled corticosteroid in moderate-severe persistent asthma. Eur Respir J. 2004;24;Suppl 48:127. [Not an intervention of interest]
780 Wang JH, Trigg CJ, Manolitsas N, . Long-term inhaled beclomethasone dipropionate (BDP) and bronchial inflammation in mild asthma. Eur Respir J. 1993;6;Suppl 17:601. [Not an intervention of interest]
781 Wanich NH, Kaplan. Management of asthma based on exhaled nitric oxide in addition to guideline-based treatment for inner-city adolescents and young adults: a randomised controlled trial. Pediatrics. 2009;124;Suppl 2:S147. DOI: 10.1542/peds.2009-1870OOO. [Not a human study]
782 Wanner A, Kumar SD, Brieva JL, . Adrenergic-glucocorticoid interactions in the regulation of airway blood flow. Arch Physiol Biochem. 2003;111(4):319–21. [Excluded study design]15764064
783 Ward C, Pais M, Reid DW, . The effect of 12 months treatment with inhaled fluticasone (FP) on diffuse sub-epitherlial collagen I and III in symptomatic steroid naïve asthmatics. Eur Respir J. 2000;16;Suppl 31:341. [Excluded study design]
784 Ward C, Pais M, Reid DW. The effect of 12 months treatment with inhaled fluticasone propionate (FP) on diffuse sub-epitherlial collagen I and III in symptomatic steroid naïve asthmatics. Eur Respir J. 2000;16;Suppl 31:341. [Not in the target population]
785 Webb J. High-dose beclomethasone inhaler in the treatment of asthma. Lancet. 1983 Apr 16;1(8329):872. PMID: 6132194. [Not a human study]6132194
786 Webb MS, Milner AD, Hiller EJ, . Nebulised beclomethasone dipropionate suspension. Arch Dis Child. 1986 Nov;61(11):1108–10. PMID: 3539031. [Not an intervention of interest]3539031
787 Weersink EJM, Meijer RJ, Kerstjens HAM, . Inhaled fluticasone. Thorax. 2000;55(7):628–9. [Not a human study]10917853
788 Weinberger M, Sherman B. Inhaled steroid aerosols and alternate-day prednisone. Lancet. 1979 Apr 21;1(8121):871–2. PMID: 86111. [Not a human study]86111
789 Weinberger M. Inhaled corticosteroids for infants. J Pediatr. 2006 Feb;148(2):284–5. PMID: 16492448. [Not a human study]16492448
790 Weinberger M. Inhaled steroid aerosols and alternate-day prednisone. Lancet. 1979 Jul 7;2(8132):48–9. PMID: 87931. [Not a human study]87931
791 Weinstein S, Murphy K, White M, . Treatment of severe asthma with a new mometasone furoate and formoterol (MF/F) combination administered with a pressurized metered-dose inhaler device. Am J Respir Crit Care Med. 2010;181;Meeting Abstracts:A5411. [Not an intervention of interest]
792 Weinstein SF, Berger WE, Noonan M, . Prevention of asthma worsening with inhaled mometasone furoate therapy in children. J Allergy Clin Immunol. 2009;123;2 Suppl 1:S66. [Not an intervention of interest]
793 Wennergren G, Nordvall SL, Hedlin G, . Nebulized budesonide for the treatment of moderate to severe asthma in infants and toddlers. Acta Paediatr. 1996 Feb;85(2):183–9. PMID: 8640047. [Not an intervention of interest]8640047
794 Wenzel SE. Efficacy versus effectiveness: Leukotriene receptor antagonists or inhaled corticosteroids. Eur Respir Rev. 2001;11(79):38–40. [Not a human study]
795 Westbroek J, Pasma HR, James MH, . Inhaled fluticasone propionate and oral zafirlukast in moderate asthma: a clinical and cost comparison. Am J Respir Crit Care Med. 1998;157;3 Suppl:A416. [Not an intervention of interest]
796 White M, Scott C, Herrle MR, . Salmeterol/fluticasone propionate 42/88mcg hfa-mdi improves asthma control in asthmatics previously treated with short- or long-acting beta2-agonists or inhaled corticosteroids. Ann Allergy Asthma Immunol. 2001;86:81. [Not an intervention of interest]
797 Wignarajah D, Zheng L, Reid D, . Fluticasone priopionate decreases airway vascularity in asthma. Respirology. 2004;9;Suppl 2:A24. [Not an intervention of interest]
798 Wilcox JB, Avery GS. Beclomethasone dipropionate corticosteroid inhaler: A preliminary report of its pharmacological properties and therapeutic efficacy in asthma. Drugs. 1973;6(2):84–93. PMID: 4753325. [Not a human study]4753325
799 Wildhaber JH, Möller A, Hall GL, . Levels of exhaled nitric oxide in recurrently wheezy infants are decreased following inhaled steroid therapy. Schweiz Med Wochenschr. 2000 Apr;130(15):529–34. [Not an intervention of interest]
800 Wilken-Jensen K. The effect of inhalations of beclomethasone dipropionate on plasma cortisol levels and growth hormone production. Postgrad Med J. 1975;51(Suppl 4):31–2. PMID: 1105515. [Excluded study design]1105515
801 Wilken-Jensen K. The effect of inhalations of beclomethasone dipropionate on plasma cortisol levels and growth hormone production. Postgrad Med J. 1975;51(Suppl 4):31–2. PMID: 1105515. [Not an intervention of interest]1105515
802 Williams C. Potency of inhaled corticosteroid fails to predict reduced emergency department visits. Arch Intern Med. 2003 Jan 27;163(2):247–8. PMID: 12546628. [Not a human study]12546628
803 Williams DM. What does potency actually mean for inhaled corticosteroids? J Asthma. 2005;42(6):409–17. [Not a human study]16293535
804 Wilson AM, Duong M, Pratt B, . An assessment of the anti-inflammatory properties of low dose inhaled ciclesonide in asthmatic patients [Abstract]. American Thoracic Society International Conference; 2005 May 20–25; San Diego, CA. C33 Poster: F64. [Not an intervention of interest]
805 Wilson E, McKeever T, Hargadon B, . Exhaled nitric oxide and inhaled corticosteroid dose reduction in asthma: A cohort study. Eur Respir J. 2014 Dec;44(6):1705–7. PMID: 25142486. [Not an intervention of interest]25142486
806 Wilson JW, Robertson CF. Inhaled steroids - too much of a good thing?. Med J Aust. 2002 Sep 16;177(6):288–9. PMID: 12225273. [Not a human study]12225273
807 Wilson N, Sloper K, Silverman M. Effect of continuous treatment with topical corticosteroid on episodic viral wheeze in preschool children. Arch Dis Child. 1995 Apr;72(4):317–20. PMID: 7763063. [Not an intervention of interest]7763063
808 Wilson NM, Silverman M. Treatment of acute, episodic asthma in preschool children using intermittent high dose inhaled steroids at home. Arch Dis Child. 1990 Apr;65(4):407–10. PMID: 2189367. [No outcomes of interest]2189367
809 Wisniewski J, Nowak-Wegrzyn A. Comparative study of budesonide inhalation suspension and montelukast in young children with mild persistent asthma. Pediatrics. 2008;122;Suppl 4:S219–20. [Not a human study]
810 Wohl ME, Majzoub JA. Asthma, steroids, and growth. N Engl J Med. 2000 Oct 12;343(15):1113–4. PMID: 11027747. [Not a human study]11027747
811 Wolthers OD, Allen DB. Inhaled corticosteroids, growth, and compliance. N Engl J Med. 2002 Oct 10;347(15):1210–1. PMID: 12374890. [Not a human study]12374890
812 Wolthers OD, Juul Riis B, Pedersen S. Bone turnover in asthmatic children treated with inhaled budesonide. Eur Respir J. 1992;5;Suppl 15:311. [Not an intervention of interest]
813 Wolthers OD, Pedersen S. Linear growth in asthmatic school children treated with inhaled budesonide. Eur Respir J. 1992;5;Suppl 15:311. [Not an intervention of interest]
814 Wolthers OD, Pedersen S. Short term linear growth in children with asthma during treatment with inhaled flutiscasone propionate and beclomethasone dipropionate. Eur Respir J. 1992;5;Suppl 15:181. [Not an intervention of interest]
815 Wolthers OD. It is still an open question whether inhaled glucocorticoid-induced effects may reduce adult height. Evid Based Med. 2013 Oct;18(5):195–6. PMID: 23335270. [Not a human study]23335270
816 Wolthers OD. Short term growth and hypopituity-adrenal axis function in asthmatic children treated with inhaled beclomethasone dipropionate. Eur Respir J. 2005;26;Suppl 49:A1059. [Not an intervention of interest]
817 Wood LJ, Gauvreau GM, Watson RM, . Effect of inhaled budesonide on allergen-induced bone marrow eosinophil progenitors in asthmatic subjects. Am J Respir Crit Care Med. 1998;157;Suppl 3:A871. [Not an intervention of interest]
818 Wu AC, Li L, Miroshnik I, . Outcomes after periodic use of inhaled corticosteroids in children. J Asthma. 2009 Jun;46(5):517–22. PMID: 19544175. [Not an intervention of interest]19544175
819 Yan XQ, Dai YR, Ong HX, . Observation of the efficacy of budesonide dry-powder inhalant in treatment of bronchial asthma. Chinese Journal of New Drugs. 2002;11(7):557–9. [Not an intervention of interest]
820 Yanagida N, Tomikawa M, Shukuya A, . Budesonide inhalation suspension versus methylprednisolone for treatment of moderate bronchial asthma attacks. World Allergy Organ J. 2015 2015;8(1). [Not in the target population]
821 Yoshihara S, Kanno N, Fukuda H, . Caregiver treatment satisfaction is improved together with children’s asthma control: Prospective study for budesonide monotherapy in school-aged children with uncontrolled asthma symptoms. Allergol intern. 2015 Oct;64(4):371–6. PMID: 26433534. [Excluded study design]26433534
822 Youkou A, Hasegawa T, Suzuki K, . Influence of obesity on control in asthmatic japanese patients defined by the japanese definition of obesity. Intern Med. 2011;50(18):1911–6. PMID: 21921368. [Excluded study design]21921368
823 Yousef E, Hossain J, Mannan S, . Early intervention with high-dose inhaled corticosteroids for control of acute asthma exacerbations at home and improved outcomes: A randomized controlled trial. Allergy Asthma Proc. 2012 Nov–Dec;33(6):508–13. PMID: 23394509. [Not an intervention of interest]23394509
824 Yu H, Lin H, Zhang X. Budesonide with terbutaline inhalation treatment of asthma care and nursing effect analysis. Chest. 2016;149;4 Suppl 1:A11. [Not an intervention of interest]
825 Yuksel B, Greenough A. Preterm infants with recurrent symptoms at follow up and prophlaxis with inhaled beclomethasone. Eur Resp J. 1992;5;Suppl 15:181. [Not an intervention of interest]
826 Zeiger RS, Mauger D, Bacharier LB. The authors reply. N Engl J Med. 2012 Feb;366(6):571. [Not a human study]
827 Zetterstrom O, Buhl R, Mellem H, . Efficacy and safety of a new single inhaler product containing both budesonide and formoterol in adult asthma. Eur Respir J. 2000;16;Suppl 31:455. [Not an intervention of interest]
828 Zetterstrom O, Buhl R, Mellem H, . The new single inhaler product containing both budesonide/formoterol improves asthma control in adults. Eur Respir J. 2000;16;Suppl 31:455. [Not an intervention of interest]
829 Zetterstrom O, Buhl R, Mellem H. Efficacy and safety of symbicort(R) budesonide and formoterol in a single inhaler in adults with asthma. Annual Thoracic Society 97th International Conference; 2001 May 18–23; San Francisco, CA. A863. [Not an intervention of interest]
830 Zhang J, Yu C, Holgate ST, . Variability and lack of predictive ability of asthma end-points in clinical trials. Eur Respir J. 2002 Nov;20(5):1102–9. PMID: 12449161. [Not an intervention of interest]12449161
831 Zhang L, Prietsch SOM. Effect of inhaled corticosteroids on linear growth in children with persistent asthma. Paediatr Respir Rev. 2014 2014/12;15(4):322–4. [Not a human study]25164572
832 Zhong N, Lin J, Mehta P, . Real-life effectiveness of budesonide/formoterol maintenance and reliever therapy in asthma patients across asia: SMARTASIA study. BMC Pulm Med. 2013;13:22. PMID: 23557023. [Excluded study design]23557023
833 Zhou X, Hong J, Cheng H, . Budesonide suspension nebulization treatment in chinese pediatric patients with cough variant asthma: A multi-center observational study. J Asthma. 2016 May;53(5):532–7. [Not in the target population]26517446
834 Zielen S, Christmann M, Kloska M, . Predicting short term response to anti-inflammatory therapy in young children with asthma. Curr Med Res Opin. 2010 Feb;26(2):483–92. PMID: 20001651. [Not an intervention of interest]20001651
835 Zielen S, Rose MA, Bez C, . Effectiveness of budesonide nebulising suspension compared to disodium cromoglycate in early childhood asthma. Curr Med Res Opin. 2006 Feb;22(2):367–73. PMID: 16466609. [Not an intervention of interest]16466609
836 Zimmerman B, Tsui F. Can the measurement of serum ECP be used to monitor treatment of childhood asthma with inhaled steroid?. Allergy. 1993 discussion 143–5;48(17 Suppl):129–32. PMID: 8109704. [Excluded study design]8109704
837 Zomer-Kooijker K, van der Ent CK, Ermers MJJ, . Lack of long-term effects of high-dose inhaled beclomethasone for respiratory syncytial virus bronchiolitis: A randomized placebo-controlled trial. Pediatr Infect Dis J. 2014 Jan;33(1):19–23. PMID: 24346594. [Not an intervention of interest]24346594
838 Zomer-Kooijker K, van der Ent K, Ermers M, . Effect of high dose inhaled beclomethasone for respiratory syncytial virus bronchiolitis during infancy on lung function and asthma at age 6 - A randomised placebo-controlled trial [Abstract]. European Respiratory Society Annual Congress; 2013 Sept 7–11; Barcelona, Spain. A61. [Not an intervention of interest]
839 Zomer-Kooijker K, Van Der Ent K, Ermers M, . Lack of long-term effects of high-dose inhaled beclomethasone for respiratory syncytial virus bronchiolitis: a randomized placebo-controlled trial. Pediatr Infect Dis J. 2014 Jan;33(1):19–23. [Not an intervention of interest]24346594

## LAMA Search

1 Afonso A, Schmiedl S, Becker C, . A methodological comparison of two European primary care databases and replication in a US claims database: inhaled long-acting beta-2-agonists and the risk of acute myocardial infarction. Eur J Clin Pharmacol. 2016 Sep;72(9):1105–16. PMID: 27216032. [Not an intervention of interest]27216032
2 Afonso ASM, Schmiedl S, Becker C, . Association between inhaled long-acting beta-2-agonists and the risk of acute myocardial infarction: a methodological comparison of two databases. Pharmacoepidemiol Drug Saf. 2014 Oct;23:390–1. DOI: 10.1002/pds.3701. [Not an intervention of interest]24677664
3 Antoniu SA. Aclidinium bromide in experimental asthma. Expert Opin Investig Drugs. 2011 Jun;20(6):871–3. PMID: 21417951. [Not a human study]21417951
4 Barnes PJ. Triple inhalers for obstructive airways disease: will they be useful? Expert Rev Respir Med. 2011 Jun;5(3):297–300. PMID: 21702649. [Not a human study]21702649
5 Beeh K, Ablinger O, Moroni-Zentgraf P, . Tiotropium in asthma: a dose-finding study in adult patients with moderate persistent asthma. Am J Respir Crit Care Med.2013;187:A1283. Embase 71980652. [No outcomes of interest]
6 Beeh KM, Ablinger O, MoroniZentgraf P, . Once-daily add-on tiotropium: A dose-finding trial in adult patients with moderate persistent asthma. Allergy. 2013;68;Suppl 97:376–7. DOI: 10.1111/all.12251. [No outcomes of interest]
7 Beeh K, Moroni-Zentgraf P, Ablinger O, . Tiotropium respimat in asthma: a double-blind, randomised, dose-ranging study in adult patients with moderate asthma. Respir Res. 2014 Jun 3;15:61. PMID: 24890738. [No outcomes of interest]24890738
8 Beeh KM, Kirsten AM, Dusser D, . Pharmacodynamics and Pharmacokinetics Following Once-Daily and Twice-Daily Dosing of Tiotropium Respimat(®) in Asthma Using Standardized Sample-Contamination Avoidance. Journal of Aerosol Medicine and Pulmonary Drug Delivery. 2016;Oct;29(5):406–415. PMID: 26859538 [not an intervention of interest]26859538
9 Bel EH. Tiotropium for asthma-promise and caution. N Engl J Med. 2012 Sep 27;367(13):1257–9. PMID: 22938707. [Not a human study]22938707
10 Buhl R, Moroni-Zentgraf P, Cornelissen P, . Tiotropium respimat in asthma: evaluation of dosing regimens by comparing once-daily 5 μg with twice-daily 2.5 μg. Am J Respir Crit Care Med. 2014;189:A1309. Embase 72043759. [No outcomes of interest]
11 Cates CJ. Safety of tiotropium. BMJ. 2011;342:d2970. DOI: http://dx.doi.org/10.1136/bmj.d2970. [Not a human study]21672998
12 Cazzola M, Matera MG, O’Donnell KM. Association of β2-adrenergic agonists and tiotropium: is the combination justified? Arch Bronconeumol. 2005;41;suppl 2:24–31. [Not a human study]
13 Chung KF. Tiotropium as an add-on therapy in patients with symptomatic asthma. Lancet Respir Med. 2015 May;3(5):331–3. PMID: 25682231. [Not a human study]25682231
14 Colice GL. Getting back to the basics: administering inhaled bronchodilators. Respir Care. 2009;54(4):455–7. PMID: 19327178. [Not a human study]19327178
15 Curfman GD, Morrissey S, Drazen JM. Products at risk. N Engl J Med. 2010 Oct 28;363(18):1763. PMID: 20979478. [Not a human study]20979478
16 Cydulka RK, Emerman CL. Effects of combined treatment with glycopyrrolate and albuterol in acute exacerbation of asthma. Ann Emerg Med. 1994 Feb;23(2):270–4. PMID: 8304607. [Not in the target population]8304607
17 Derom E, Van Durme Y, Salhi B, . Assessments of protective effects of tiotropium bromide against methacholine- and neurokinin A-induced bronchoconstriction in patients with asthma. Eur Respir J. 2011;38;Suppl 55:p872. [No outcomes of interest]
18 Derom E, Van Durme Y, Salhi B, . Tiotropium bromide protects against methacholine-, but not against neurokinin A-induced bronchoconstriction in patients with asthma: a randomized, double-blind, placebo-controlled, crossover study. Am J Respir Crit Care Med. 2011;183:A4500. Embase 70848807. [No outcomes of interest]
19 Domingo C. Ultra-LAMA, ultra-LABA, ultra-inhaled steroids? The future has landed. Arch Bronconeumol. 2013 Apr;49(4):131–4. PMID: 23415574. [Not a human study]23415574
20 Emerman CL, Cydulka RK. Changes in serum catecholamine levels during acute bronchospasm. Ann Emerg Med. 1993 Dec;22(12):1836–41. PMID: 8239104. [Not in the target population]8239104
21 Fardon T, Haggart K, Lee DKC, . A proof of concept study to evaluate stepping down the dose of fluticasone in combination with salmeterol and tiotropium in severe persistent asthma. Respir Med. 2007 Jun;101(6):1218–28. PMID: 17178217. [No outcomes of interest]17178217
22 Feshchenko Y, Iashyna L, Moskalenko S, . Clinical-functional effectiveness of different regimens of basic treatment in severe bronchial asthma patients. Allergy. 2014;69:517. DOI: 10.1111/all.12478. [Abstract without full-text]24611950
23 Gilman MJ, Meyer L, Carter J, . Comparison of aerosolized glycopyrrolate and metaproterenol in acute asthma. Chest. 1990 Nov;98(5):1095–8. PMID: 2225951. [Not in the target population]2225951
24 Haggart K, Fardon TC, Lee DKC, . Stepping down inhaled steroids in severe asthma with long acting bronchodilators: utilising effort dependent and independent measures of pulmonary function. Thorax. 2004 Dec;59;Suppl II:ii72–3. [No outcomes of interest]
25 Hansel TT, Neighbour H, Erin EM, . Glycopyrrolate causes prolonged bronchoprotection and bronchodilatation in patients with asthma. Chest. 2005 Oct;128(4):1974–9. PMID: 16236844. [Not an intervention of interest]16236844
26 Higashi A, Zhu S, Stafford RS, . National trends in ambulatory asthma treatment, 1997–2009. J Gen Intern Med. 2011 Dec;26(12):1465–70. PMID: 21769507. [Excluded study design]21769507
27 Hoshino M, Ohtawa J, Akitsu K. Effects of the addition of tiotropium on airway dimensions in symptomatic asthma. Allergy and asthma proceedings. 2016;37(6):e147–e153. PMID: 27931291 [no outcomes of interest]27931291
28 Huang J, Chen Y, Long Z, . Clinical efficacy of tiotropium in children with asthma. Pak J Med Sci. 2016;32(2):462–5. PMID: 27182262. [Not in the target population]27182262
29 Iwamoto H, Yokoyama A, Shiota N, . Tiotropium bromide is effective for severe asthma with noneosinophilic phenotype. Eur Respir J. 2008 Jun;31(6):1379–80. PMID: 18515562. [Excluded study design]18515562
30 Izco-Basurko I. Novelties in the treatment and management of thoracic disorders. Drug News Perspect. 2008 Sep;21(7):391–402. PMID: 19259552. [Not a human study]19259552
31 Jara M, Wentworth III C, Lanes S. A new user cohort study comparing the safety of long-acting inhaled bronchodilators in COPD. BMJ Open. 2012 May 22;2(3):pii:e000841. PMID: 22619266. [Not in the target population]22619266
32 Jara M, Lanes SF, Wentworth C3, . Comparative safety of long-acting inhaled bronchodilators: a cohort study using the UK THIN primary care database. Drug Saf. 2007;30(12):1151–60. PMID: 18035867. [Not in the target population]18035867
33 Johnson BE, Suratt PM, Gal TJ, . Effect of inhaled glycopyrrolate and atropine in asthma precipitated by exercise and cold air inhalation. Chest. 1984 Mar;85(3):325–8. PMID: 6697786. [Not in the target population]6697786
34 Kerstjens HA. Tiotropium improved lung function and delayed exacerbations in poorly controlled asthma. Ann Intern Med. 2012;157(12):J6–3. Embase 2012743126. [Not a human study]
35 Kerstjens HAM, Disse B, Schroder-Babo W, . Tiotropium improves lung function in patients with severe uncontrolled asthma: a randomized controlled trial. J Allergy Clin Immunol. 2011 Aug;128(2):308–14. PMID: 21636120. [No outcomes of interest]21636120
36 Kerstjens HAM, Moroni-Zentgraf P. Bronchodilator reversibility and cardiac considerations with use of tiotropium. Lancet Respir Med. 2015 Aug;3(8):e25–6. PMID: 26282477. [Not a human study]26282477
37 Kerstjens HAM, Moroni-Zentgraf P, Bateman ED. Tiotropium in asthma - authors’ reply. Lancet Respir Med. 2015 May;3(5):e17. PMID: 25969363. [Not a human study]25969363
38 Korelitz JJ, Zito JM, Gavin NI, . Asthma-related medication use among children in the United States. Ann Allergy Asthma Immunol. 2008 Mar;100(3):222–9. PMID: 18426141. [Excluded study design]18426141
39 Kuziemski K. Which dry powder inhaler should be chosen? Respiration. 2009;78(3):356. PMID: 19602872. [Not a human study]19602872
40 Lane M. Tiotropium bromide in asthma patients: an alternative to inhaled long-acting beta-agonists? J R Coll Physicians Edinb. 2010 Dec;40(4):321–2. PMID: 21132141. [Not a human study]21132141
41 Lee LA, Briggs A, Edwards LD, . A randomized, three-period crossover study of umeclidinium as monotherapy in adult patients with asthma. Respir Med. 2015 Jan;109(1):63–73. PMID: 25464907. [Not an intervention of interest]25464907
42 Limaye S, Kodgule R, Raskar S, . Single dose of of tiotropium bromide (18 mcg) produces a similar bronchodilator response as two doses of formoterol fumarate (12 mcg) over 24 hours in subjects with moderate-to-severe asthma [P1193]. Presented at: European Respiratory Society Annual Congress. 2010 Sep 19; Barcelona, Spain. [Not an intervention of interest]
43 Lipworth B. Tiotropium in asthma. Lancet Respir Med. 2015 May;3(5):e16–7. PMID: 25969362. [Not a human study]25969362
44 Lommatzsch M, Julius P, Virchow JC. Tiotropium step-up therapy in asthma. N Engl J Med. 2011 Feb 10;364(6):578–9. PMID: 21306255. [Not a human study]21306255
45 Magnussen H, Bugnas B, van Noord J, . Improvements with tiotropium in COPD patients with concomitant asthma. Respir Med. 2008 Jan;102(1):50–6. PMID: 17920256. [Not in the target population]17920256
46 Mariotti F, Ciurlia G, Spaccapelo L, . A two-period open-label, single-dose crossover study in healthy volunteers to evaluate the drug-drug interaction between cimetidine and inhaled extrafine CHF 5993. Eur J Drug Metab Pharmacokinet. 2016 May 21. Epub 2016 May 21. PMID: 27209586. [Not in the target population]27209586
47 Miller DR, Chetty M, Currie GP. Tiotropium step-up therapy in asthma. N Engl J Med. 2011 Feb 10;364(6):578–9. PMID: 21306256. [Not a human study]21306256
48 Mundy C, Kirkpatrick P. Tiotropium bromide. Nat Rev Drug Discov. 2004 Aug;3(8):643–4. PMID: 15317149. [Not a human study]15317149
49 Nair GB, Spiegler P. Role of anticholinergics in the treatment of asthma. Clin Pulm Med. 2011;18(2):95–6. [Not a human study]
50 Norris AA. 15th Annual Congress of European Respiratory Society. Expert Opin Invest Drugs. 2006;15(2):185–8. DOI: 10.1517/13543784.15.2.185. [Not a human study]
51 O’Connor BJ, Towse LJ, Barnes PJ. Prolonged effect of tiotropium bromide on methacholine-induced bronchoconstriction in asthma. Am J Respir Crit Care Med. 1996 Oct;154(4 Pt 1):876–80. PMID: 8887578. [Not in the target population]8887578
52 Park H, Yang M, Park C, . Additive role of tiotropium in severe asthmatics and Arg16Gly in ADRB2 as a potential marker to predict response. Allergy. 2009 May;64(5):778–83. PMID: 19183167. [Not an intervention of interest]19183167
53 Peters SP. Tiotropium plus beclomethasone was more effective than doubling beclomethasone for asthma. Ann Intern Med. 2011;154(4):J2–4. Embase 2011097331. [Not a human study]
54 Peters SP. Tiotropium bromide triple combination therapy improves lung function and decreases asthma exacerbations. Evid Based Med. 2013 Oct;18(5):179. PMID: 23349214. [Not a human study]23349214
55 Peters SP, Kunselman SJ, Icitovic N, . Tiotropium bromide step-up therapy for adults with uncontrolled asthma. N Engl J Med. 2010 Oct 28;363(18):1715–26. PMID: 20979471. [Duplicate]20979471
56 Prescott LM, Prescott SL. 101st International Conference of the American Thoracic Society. P&T. 2005 Aug;30(8):467–70. [Not a human study]
57 Price D, Kaplan A, Jones R, . Long-acting muscarinic antagonist use in adults with asthma: real-life prescribing and outcomes of add-on therapy with tiotropium bromide. J Asthma Allergy. 2015;8:1–13. PMID: 25609985. [Not in the target population]25609985
58 Price D, West D, Brusselle G, . Management of COPD in the UK primary-care setting: An analysis of real-life prescribing patterns. Int J Chron Obstruct Pulmon Dis. 2014;9:889–904. PMID: 25210450. [Not in the target population]25210450
59 Quijada C, Venegas M, Bernardine H. How long should tiotropium bromide be suspended before methacholine challenge? Eur Respir J. 2006;28;Suppl 50:218. [No outcomes of interest]
60 Ranaweera A. The 102nd Annual Conference of the American Thoracic Society. Int J Pharm Med. 2006;20(4):263–8. [Not a human study]
61 Sayal P, Adhikari T, Vijayan VK. The effects of inhaled tiotropium bromide on lung inflammation in bronchial asthma. Chest. 2007;132(4_MeetingAbstracts):509a. DOI: 10.1378/chest.132.4_MeetingAbstracts.509a. [Abstract without full-text]
62 Schelfhout V, Joos G, Garcia Gil E, . Bronchodilator/bronchoprotective effects of aclidinium bromide a novel long acting anticholinergic a phase 1 study. Eur Respir J. 2007;30;Suppl 51:356. [Not in the target population]
63 Schroeckenstein DC, Bush RK, Chervinsky P, . Twelve-hour bronchodilation in asthma with a single aerosol dose of the anticholinergic compound glycopyrrolate. J Allergy Clin Immunol. 1988 Jul;82(1):115–9. PMID: 3392363. [Not an intervention of interest]3392363
64 Self T, Joe R, Kellerman A. Glycopyrrolate for asthma. Am J Emerg Med. 1992 Jul;10(4):395–6. PMID: 1616535. [Not a human study]1616535
65 Sen IM, Ahuja V. Theophylline: A drug of caution. J Anaesthesiol Clin Pharmacol. 2007;23(4):433–4. [Excluded study design]
66 Shah S. Asthma & COPD - SMi’s Sixth Annual Conference. IDrugs. 201;13(6):376–8. [Not a human study]20506058
67 Slats AM, Janssen K, de Jeu R, . The effect of tiotropium bromide on deep inspiration-induced bronchodilation and airway responsiveness in asthma. Am J Respir Crit Care Med. 2009;179:A2427. DOI: http://dx.doi.org/10.1164/ajrccm-conference.2009.179.1_MeetingAbstracts.A2427. [No outcomes of interest]
68 Sposato B, Bruno S, Barzan R, . Comparison of the protective effect amongst anticholinergic drugs on methacholine-induced bronchoconstriction in asthma. J Asthma. 2008 Jun;45(5):397–401. PMID: 18569233. [Not an intervention of interest]18569233
69 Sridevi K, MohanaRao V, Vijaya N, . Safety and efficacy of tiotropium bromide in bronchial asthma and COPD patients, cross over studies by placebo. Int J Life Sci Biotechnol Pharma Res. 2012;1(4):250–62. Embase 2013173434. [Not in the target population]
70 Storms WW. Exercise-induced bronchospasm. Curr Sports Med Rep. 2009;8(2):45–6. PMID: 19276902. [Not a human study]19276902
71 Suffredini AF, Masur H, Lynch JP. Update in pulmonary and critical care medicine. Ann Intern Med. 2010 May 4;152(9):601–8. PMID: 20410448. [Not a human study]20410448
72 Terzano C, Petroianni A, Ricci A, . Early protective effects of tiotropium bromide in patients with airways hyperresponsiveness. Eur Rev Med Pharmacol Sci. 2004 Nov–Dec;8(6):259–64. PMID: 15745385. [Not an intervention of interest]15745385
73 Timmer W, Moroni-Zentgraf P, Cornelissen P, . Once-daily tiotropium respimat 5 μg is an efficacious 24-h bronchodilator in adults with symptomatic asthma. Respir Med. 2015 Mar;109(3):329–38. PMID: 25661281. [No outcomes of interest]25661281
74 Tochino Y, Kanazawa H, Ichimaru Y, . Nɛ-(carboxymethyl)lysine, a major advanced glycation end product in exhaled breath condensate as a biomarker of small airway involvement in asthma. J Asthma. 2007 Dec;44(10):861–6. PMID: 18097864. [Not an intervention of interest]18097864
75 Vogelberg C, Engel M, MoroniZentgraf P, . O05-once-daily tiotropium in adolescents with symptomatic asthma despite inhaled corticosteroid treatment: a dose-ranging study. Clin Transl Allergy. 2014;4;Suppl 1:O5. DOI: 10.1186/2045-7022-4-S1-O5. [No outcomes of interest]
76 Vogelberg C, Engel M, Moroni-Zentgraf P, . Tiotropium in asthmatic adolescents symptomatic despite inhaled corticosteroids: A randomised dose-ranging study. Respir Med. 2014 Sep;108(9):1268–76. PMID: 25081651. [No outcomes of interest]25081651
77 Vogelberg C, LeonaviciuteKlimantaviciene M, Vevere V, . Dose-ranging study of tiotropium as treatment for moderate persistent asthma in adolescents. Allergo J. 2013 Sep 7;22 (6):389. Embase 71405612. [No outcomes of interest]
78 Vogelberg C, LeonaviciuteKlimantaviciene M, Vevere V, . Dose-ranging study of tiotropium as treatment for moderate persistent asthma in adolescents. Am J Respir crit Care Med. 2012;185:A4069. Embase 71988705. [No outcomes of interest]
79 Vogelberg C, Moroni-Zentgraf P, Leonaviciute-Klimantaviciene M, . A randomised dose-ranging study of tiotropium respimat in children with symptomatic asthma despite inhaled corticosteroids. Respir Res. 2015 Feb 4;16:20. PMID: 25851298. [Not in the target population]25851298
80 Walker FB4, Kaiser DL, Kowal MB, . Prolonged effect of inhaled glycopyrrolate in asthma. Chest. 1987 Jan;91(1):49–51. PMID: 3792086. [Not an intervention of interest]3792086
81 Wark P. ACP journal club. Tiotropium reduced exacerbations more than salmeterol in moderate-to-very severe COPD. Ann Intern Med. 2011 Jul 19;155(2):JC1–3. PMID: 21768569. [Not a human study]21768569
82 Wenzel SE. Tiotropium for severe asthma: a step forward or more of the same? Pol Arch Med Wewn. 2012;122(11):525–6. PMID: 23207413. [Not a human study]23207413
83 Yaqub F. 2013 American Thoracic Society International Conference. Lancet Respir Med. 2013 Jul;1(5):359. PMID: 24429194. [Not a human study]24429194
84 Yoshida M, Inoue H, Iwanaga T. Effects of tiotropium on lung function in severe asthmatics with or without emphysematous changes. Am J Respir Crit Care Med. 2012;185:A3962. DOI: http://dx.doi.org/10.1164/ajrccm-conference.2012.185.1_MeetingAbstracts.A3962. [Not an intervention of interest]
85 Yoshida M, Nakano T, Fukuyama S, . Effects of tiotropium on lung function in severe asthmatics with or without emphysematous changes. Pulm Pharmacol Ther. 2013 Apr;26(2):159–66. PMID: 23073336. [Not an intervention of interest]23073336
86 Glycopyrronium bromide for chronic obstructive pulmonary disease. Aust Prescr. 2014;37:64–71. DOI: 10.18773/austprescr.2014.027. [Not a human study]
87 Spiriva: A new drug treatment for asthma? Tiotropium (spiriva), a drug prescribed for chronic obstructive pulmonary disease (COPD), may provide effective preventive care for individuals with moderate to severe asthma. Johns Hopkins Med Lett Health After 50. 2011 Jul;23(5):3. PMID: 27024143. [Not a human study]27024143
88 Asian Pacific Society of Respirology 19th Congress. Respirology. 2014 Nov;19;Suppl S3:1–270. Embase 71678388. [Abstract without full-text]