# Appendix A Search Strategy

## Search for KQ 1- Medline, Cochrane Central and Cochrane Database of Systematic Reviews- via Ovid

1. Asthma.mp or Asthma/
2. Wheez$.mp.
3. Bronchial spasm/or bronchospas$.mp.
4. Bronchoconstriction/or bronchoconstrict$.mp.
5. Bronchial hyperreactivity/
6. Reactive airway disease.mp.
7. 1 or 2 or 3 or 4 or 5 or 6
8. Inhaled corticosteroid.mp.
9. Inhal$.mp.
10. Ciclesonide.mp.
11. Fluticasone/or fluticasone.mp.
12. Flunisolide.mp.
13. Beclomethasone/or beclomethasone.mp.
14. Budesonide/or budesonide.mp.
15. Mometasone furoate/or mometasone.mp.
16. Triamcinolone/or triamcinolone.mp.
17. 9 AND (10 or 11 or 12 or 13 or 14 or 15 or 16)
18. “Single inhaler”.mp. OR “single maintenance and reliever therapy”.mp. OR SMART
19. 8 or 17 or 18
20. 7 and 19
21. Limit 20 to humans

## Search for KQ 1- Embase

1. ‘asthma’/de OR asthma
2. ‘wheezing’/de OR wheezing
3. ‘wheeze’/de OR wheeze
4. ‘bronchospasm’/de OR ‘bronchospasm’
5. ‘bronchoconstriction’/de OR ‘bronchoconstriction’
6. ‘bronchial hyperreactivity’/de OR
7. ‘reactive airway disease’
8. #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7
9. ‘ciclesonide’/exp/dd_ih
10. ‘budesonide’/exp/dd_ih
11. ‘fluticasone’/exp/dd_ih
12. ‘flunisolide’/exp/dd_ih
13. ‘beclomethasone’/exp/dd_ih
14. ‘mometasone’/exp/dd_ih
15. ‘triamcinolone’/exp/dd_ih
16. ‘single maintenance and rescue therapy’
17. ‘single inhaler therapy’
18. #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16 OR #17
19. #8 AND #18

## Search for KQ 2- Medline, Cochrane Central and Cochrane Database of Systematic Reviews- via Ovid

1. Asthma.mp or Asthma/
2. Wheez$.mp.
3. Bronchial spasm/or bronchospas$.mp.
4. Bronchoconstriction/or bronchoconstrict$.mp.
5. Bronchial hyperreactivity/
6. Reactive airway disease.mp.
7. 1 or 2 or 3 or 4 or 5 or 6
8. Long acting muscarinic antagonist.mp.
9. Tiotropium bromide/or tiotropium.mp.
10. Aclidinium.mp.
11. Glycopyrronium.mp. or glycopyrrolate/or glycopyrrolate.mp.
12. Umeclidinium.mp.
13. 9 or 10 or 11 or 12
14. 8 or 13
15. 7 and 14
16. Limit 15 to humans

## Search for KQ 2- Embase

20 ‘asthma’/de OR asthma
21 ‘wheezing’/de OR wheezing
22 ‘wheeze’/de OR wheeze
23 ‘bronchospasm’/de OR ‘bronchospasm’
24 ‘bronchoconstriction’/de OR ‘bronchoconstriction’
25 ‘bronchial hyperreactivity’/de OR
26 ‘reactive airway disease’
27 #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7
28 ‘long acting muscarinic antagonist’
29 ‘tiotropium’/exp/dd_ih
30 ‘aclidinium’/exp/dd_ih
31 ‘glycopyrronium’/exp/dd_ih
32 “glycopyrrolaye’/exp/dd_ih
33 ‘umeclidinium’/exp/dd_ih
34 #9 OR #10 OR #11 OR #12 OR #13 OR #14
35 #8 AND #15