# Abbreviations

Abbreviation: Definition
ACQ: Asthma Control Questionnaire
ACT: Asthma Control Test
AQLQ: Asthma Quality of Life Questionnaire
AQLQ(S): Standardized Asthma Quality of Life Questionnaire
AUC: Area Under the Curve
CBP: Conventional Best Practice
CI: Confidence Intervals
EPC: Evidence-based Practice Centers
EPR: Expert Panel Report
ER: Emergency Room
FEV1: Forced Expiratory Volume in 1 second
FVC: Forced Vital Capacity
HR: Hazard Ratio
ICS: Inhaled Corticosteroid
ICTRP: International Controlled Trials Registry Platform
KQ: Key Question
LABA: Long-acting β_2_ Agonists
LAMA: Long-acting Muscarinic Antagonists
LTRA: Leukotriene Receptor Antagonist
mAPI: modified Asthma Prediction Index
MD: Mean Difference
NAEPP: National Asthma Education and Prevention Program
NHLBI: National Heart, Lung and Blood Institute
OR: Odds Ratio
PACQLQ: Pediatric Asthma Caregivers Asthma Quality of Life Questionnaire
PAQLQ: Pediatric Asthma Quality of Life Questionnaire
PEF: Peak Expiratory Flow
PICOTS: Population, Intervention, Comparison, Outcomes, Timing, Setting
RCT: Randomized Controlled Trial
RR: Relative Risk
RTI: Respiratory Tract Infection
SABA: Short-acting β_2_ Agonists
SOE: Strength of Evidence
UK: United Kingdom
US: United States