# Results

## Results of Literature Searches

The search and selection of articles are summarized in the literature flow diagram (Figure 2). Database searches resulted in 1,934 potentially relevant articles. After dual review of abstracts and titles, 202 articles were selected for full-text dual review, and 13 studies were determined to meet inclusion criteria and were included in this review. In all studies meeting inclusion criteria, naloxone was administered by emergency medical services (EMS) personnel. No study reported funding from manufacturers of naloxone. Data extraction and risk of bias assessment tables for all included studies are available in Appendixes D and E.

Figure 2 Literature flow diagram

* Other sources include prior reports, references lists, referrals from experts, and grey literature

Figure 2 is a literature flow diagram depicting the search and selection of articles. The diagram shows that 1,934 abstracts of potentially relevant articles were identified through literature database searches. 202 full-text articles were reviewed after excluding 1,732 abstracts that did not meet inclusion criteria. From the full text articles reviewed, 120 were background articles and 69 were excluded for the following reasons: 19 wrong population, 3 wrong intervention, 7 wrong outcome, 10 wrong comparator, 2 wrong study design, 26 not a study, and 2 were systematic reviews used as a source document to identify individual studies. 13 publications were included for Key Questions 1 and 4. 7 publications were included for Key Question 1, no publications were included for Key Question 2, no publications were included for Key Question 3, and 6 publications were included for Key Question 4.

## Description of Included Studies

### Key Question 1 For patients with confirmed or suspected opioid overdose, what are the comparative benefits and harms of out-of-hospital administration of naloxone by EMS personnel using intravenous, intramuscular, subcutaneous, and intranasal routes of administration?

#### Key Points

- Intranasal versus intramuscular naloxone:
  ○ One trial found no difference between intranasal (IN) naloxone (2 mg, administered as a 2 mg/1 mL formulation) versus intramuscular (IM) naloxone (2 mg) in the likelihood of adequate response within 10 minutes (72% vs. 78%, adjusted Odds Ratio [OR] 0.7, 95% confidence interval [CI] 0.3 to 1.5), mean response time (8.0 vs. 7.9 minutes), or agitation/violence (6.0% vs. 7.9%, Relative Risk [RR] 0.77, 95% CI 0.25 to 2.3). IN naloxone was associated with increased likelihood of rescue naloxone use (18% vs. 4.5%, adjusted OR 4.8, 95% CI 1.4 to 16).
  ○ Another trial found lower concentration IN naloxone (2 mg administered as a 2 mg/5 mL formulation) associated with lower likelihood of spontaneous respirations within 8 minutes (63% vs. 82%, OR 0.38, 95% CI 0.18 to 0.81), higher likelihood of rescue naloxone use (26% vs. 13%, OR 2.4, 95% CI 1.0 to 5.7), longer time to respirations >10/minutes (8 vs. 6 minutes, p=0.006), and trend towards decreased likelihood of Glasgow Coma Scale (GCS) score >11 at 8 minutes (57% vs. 72%, OR 0.52, 95% CI 0.27 to 1.0) than IM naloxone (2 mg). IN naloxone was associated with decreased risk of agitation and/or irritation (2.4% vs. 14%, RR 0.19, 95% CI 0.04 to 0.83).
  ○ The strength of evidence (SOE) for this comparison was low, due to moderate study limitations and inconsistency.
- Intranasal versus intravenous naloxone:
  ○ One trial conducted in an Iranian emergency department (ED) setting found that IN naloxone (0.4 mg, administered as a 0.4 mg/2 mL formulation) was associated with a greater likelihood than intravenous (IV) naloxone (0.4 mg) of an adequate response (defined as level of consciousness following naloxone of lethargic or conscious, 100% vs. 60%, RR 1.7, 95% CI 1.3 to 2.1) and lower likelihood of agitation than IV naloxone (0% vs. 24%, RR 0.04, 95% CI 0.002 to 0.66). The SOE was insufficient, due to moderate study limitations, inability to assess consistency, and indirectness (poor applicability to U.S. field settings due to high proportion of overdoses related to use of opium and ED setting).
  ○ Two cohort studies reported few clear differences between IN and IV naloxone, but had serious methodological shortcomings, including failure to adjust for confounders (SOE: insufficient).

#### Detailed Synthesis

We identified three randomized controlled trials (RCTs) (n=100 to 182)^62–64^ (Table 2 and Appendix D, Table D-1) and four cohort studies (n=93 to 609)^65–68^ (Table 3 and Appendix D, Table D-2) that compared different routes of naloxone administration. Two of the RCTs,^62,63^ both of which were conducted in Australia, were performed in field settings and one RCT^64^ was performed in an ED setting in Iran. The field RCTs evaluated intranasal naloxone at concentrations of 2 mg/5 mL^62^ or 2 mg/1 mL^63^ administered at a dose of 1 mg per nostril versus intramuscular naloxone 2 mg, with intramuscular naloxone 0.8 mg administered in both groups for failure to respond after 8 minutes. None of the studies reported industry funding. The ED RCT compared intranasal naloxone 0.4 mg/2 mL at a dose of 0.2 mg per nostril versus IV naloxone 0.4 mg, with repeat administration of the same dose using the same route of administration for failure to respond within 5 minutes.^64^ No trial evaluated the recently U.S. Food and Drug Administration (FDA)-approved formulations of IN or IM (via auto-injector) naloxone. In the field studies, concomitant drugs or alcohol were present or suspected in 30 to 50 percent of patients; the type and dose of opioid associated with the overdose episode were not reported.^62,63^ In the ED trial, the proportion of patients with concomitant drugs or alcohol was not reported.^64^ The field trials did not report the opioid involved in the overdose; in the ED trial, the opioid causing the overdose was opium in 44 to 48 percent of patients, heroin in 24 to 28 percent of patients, and methadone in 16 to 20 percent of patients; diphenoxylate, “crack” (defined in the study as heroin combined with other opioid agents), and buprenorphine were reported in small numbers of patients. All trials were rated moderate risk of bias (Appendix E). Methodological shortcomings included unblinded design and baseline between-group differences.

Table 2 Characteristics and results of randomized controlled trials comparing routes of naloxone administration

Author, Year Country Risk of Bias | Intervention (Sample Size) | Population Characteristics by Treatment Group | Results | Adverse Events
Kelly, 2005^62^ Australia Medium | A: Naloxone intranasal 2 mg/5 mL with mucosal atomization device, 1 mg each nostril (n=84) B: Naloxone intramuscular 2 mg × 1(preparation not described) (n=71) Paramedics administered naloxone. Both groups received naloxone intramuscular 0.8 mg for failure to respond after 8 minutes | Age: 28 vs. 30 years Male: 70% vs. 73% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported | A vs. B Spontaneous respirations within 8 minutes: 63% (53/84) vs. 82% (58/71), OR 0.38 (95% CI 0.18 to 0.81) Patients requiring rescue naloxone after 8 minutes: 26% (22/84) vs. 13% (9/71), OR 2.4 (95% CI 1.0 to 5.7) Glasgow Coma Score (GCS) >11 at 8 minutes: 57% (48/84) vs. 72% (51/71), OR 0.52 (95% CI 0.27 to 1.0) Transported to hospital: 17% (14/84) vs. 21% (15/71), OR 0.75 (95% CI 0.33 to 1.68) Time to respirations >10/minute (minutes): 8 vs. 6 minutes, p=0.006 Time to GCS score >11: p=0.38, data not reported | Major adverse event: 0% (0/84) vs. 0% (0/71) Minor adverse event: 12% (10/84) vs. 21% (15/71), RR 0.56 (95% CI 0.27 to 1.18) Agitation and/or irritation: 2.4% (2/84) vs. 14% (10/71); RR 0.19 (95% CI 0.04 to 0.83) Nausea and/or vomiting: 7.1% (6/84) vs. 5.6% (4/71), RR 1.3 (95% CI 0.37 to 4.3) Headache: 0% (0/84) vs. 2.8% (2/71), RR 0.17 (95% CI 0.008 to 3.5) Tremor: 1.2% (1/84) vs. 1.4% (1/71), RR 0.85 (95% CI 0.05 to 13) Sweating: 1.2% (1/84) vs. 0% (0/71), RR 2.5 (95% CI 0.11 to 61)
Kerr, 2009^63^ Australia Medium | A: Naloxone intranasal 2 mg/1 mL with mucosal atomization device, 1 mg each nostril (n=83) B: Naloxone intramuscular 2 mg/5 mL ‘min-i-jet’ preparation × 1 (n=89) Paramedics administered naloxone. Both groups received naloxone intramuscular 0.8 mg for failure to respond after 10 minutes | Age: 31 vs. 32 years Male: 77% vs. 71% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported | A vs. B Adequate response at ≤10 minutes (respiratory rate ≥10 per minute and/or GCS ≥13): 72% (60/83) vs. 78% (69/89), difference −5.2% (95% CI −18 to 7.7%); adjusted OR 0.7 (95% CI 0.3 to 1.5) Rescue naloxone for inadequate response: 18% (15/83) vs. 4.5% (4/89), difference 14% (95% CI 4.2 to 23%); adjusted OR 4.8 (95% CI 1.4 to 16) Hospitalization: 29% (24/83) vs. 26% (23/89); difference 3.1% (95% CI −10 to 16%); adjusted OR 1.3 (95% CI 0.6 to 2.7) Mean response time (minutes): 8.0 vs. 7.9, difference 0.1 (95% CI −1.3 to 1.5) | Major adverse event: 1.2% (1/83) vs. 0% (0/89), RR 3.2 (95% CI 0.13 to 78) Minor adverse event: 19% (16/83) vs. 19% (17/89); difference 0.2% (−12 to 12%); adjusted OR 1.1 (95% CI 0.5 to 2.5) Agitation and/or violence: 6.0% (5/83) vs. 7.9% (7/89), RR 0.77 (95% CI 0.25 to 2.3) Nausea and/or vomiting: 8.4% (7/83) vs. 7.9% (7/89), RR 1.07 (95% CI 0.39 to 2.9) Headache: 4.8% (4/83) vs. 3.3% (3/89), RR 1.4 (95% CI 0.33 to 6.2) Needle stick injuries: None
Sabzghabaee, 2014^64^ Iran High | A: Naloxone intranasal 0.4 mg in 2mL (n=50) B: Naloxone intravenous 0.4 mg (n=50) All patients who failed to respond within 5 minutes were given a further 0.4 mg naloxone by the same administration route as the first dose | Age: 30 vs. 33 years Male: 78% vs. 74% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported | A vs. B: Systolic blood pressure: 106 ±14.7 vs. 112±9.6, p=0.18 Diastolic blood pressure: 78±7.1 vs. 77±4.5, p=0.18 Heart rate (per minute): 90±8.3 vs. 97±12.9, p=0.003 Respirator rate (per minute): 18±2.4 vs. 19±2.8, p=0.17 Glasgow Coma Scale: 14.3±0.73 vs. 13.2±1.5, p<0.001 Length of hospital stay (days): 1.53±0.16 vs. 1.2±0.15, p=0.15 | Agitation: 0 vs. 12

CI = confidence interval; GCS = Glasgow Coma Scale; OR = odds ratio; RR = relative risk

Table 3 Characteristics and results of cohort studies comparing routes of naloxone administration

Author, Year Country Risk of Bias | Comparison Group (Sample Size) | Population Characteristics by Comparison Group | Results
Merlin, 2010^65^ United States High | A: Intravenous naloxone between 0.4 and 2.0 mg (n=55) B: Intranasal naloxone at 1 mg per nostril at the discretion of the paramedics (n=38) Naloxone administered by Advanced Life Support personnel | Age: 42 vs. 38 years Male: 67% vs. 61% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 100% vs. 100% | A vs. B: Median change in breaths per minute from baseline: 6 vs. 4, Difference 2 (95% CI −0.001 to 5), p= 0.08 Median change in Glasgow Coma Scale (GCS) from baseline: 4 vs. 3, Difference 1 (95% CI −0.001 to 3), p=0.19
Robertson, 2009^66^ United States High | A: Intravenous naloxone as first line treatment, dose protocol not reported (n=104) B: Intranasal naloxone as first line treatment, 2 mg (1 mg per nostril) using mucosal atomizer device (n=50) EMS administered naloxone, training not specified Patients in first year were treated with intravenous naloxone and patients in last 5 months were treated with intranasal naloxone. | Age: 44 vs. 41 years Male: 60% vs. 71% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 100% vs. 100% | A vs. B: Positive clinical response (increase in respirations of at least 6 breaths/minute or in GCS of at least 6 points): 58/104 (56%) vs. 33/50 (66%), p=0.3 Time from naloxone administration to effect: 8.1 vs. 12.9 minutes, p=0.02 Time from patient contact to effect: 20.7 vs. 20.3 minutes, p=0.9 Second dose of naloxone given: 19/104 (18%) vs. 17/50 (34%), p=0.05
Sporer, 1996^67^ United States High | A: Intravenous naloxone 2 mg (n=69) B: Intramuscular naloxone 2 mg (n=487) Repeat dose given if no response is seen in 1–2 minutes | Not reported by treatment group Age: <20: 3%; 20–29: 15%; 30–39: 40%; 40–49: 34%; >50: 9% Male: 78% Race: Unknown: 51%; White: 28%; Black: 14%; Hispanic: 6%; Asian: 1% Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 99.8% | A vs. B: Response rate (GCS ≥14 and RR≥10/minute within 5 minutes of naloxone administration): 488/518 (94%) vs. 69/73 (95%), RR 1.0 (95% CI 0.94 to 1.1)
Wanger, 1998^68^ Canada High | A: Subcutaneous naloxone 0.8 mg into upper arm or thigh, with 0.4 mg IV available if no improvement after 5 minutes (n=139) B: Intravenous naloxone 0.4 mg, with an additional 0.4 mg available if no improvement after 5 minutes (n=83) Overdose treated by British Columbia Ambulance Service attendants (basic life support, IV and advanced life support levels); unclear who administered naloxone | A vs. B Age: 33 vs. 36 years Male: 80% vs. 78% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 100% | Time interval from drug administration to respiratory rate ≥10 breaths per minute: 5.5 vs. 3.8 minutes, p=0.001 Time interval from arrival at patient’s side to respiratory rate ≥10 breaths per minute: 9.6 vs. 9.3 minutes, p=0.67 Proportion requiring multiple naloxone doses: 15% (18/122) vs. 35% (26/74), RR 0.42 (95% CI 0.25 to 0.71)

CI = confidence interval; GCS = Glasgow Coma Scale; IV = intravenous; RR = relative risk

Two cohort studies compared IV (0.4 to 2.0 mg or dose not reported) versus IN naloxone (2 mg, concentration not reported),^65,66^ one compared IM (2 mg) versus IV (2 mg) naloxone,^67^ and one compared SC (0.8 mg) versus IV (0.4 mg) naloxone.^68^ All of the studies were conducted prior to 2015, and before FDA approval of new formulations of IN and IM naloxone. Three studies were conducted in the U.S.^65–67^ and one study in Canada.^68^ No study reported the type or dose of opioid associated with the overdose, or presence of concomitant drugs or alcohol. All of the observational studies were rated high risk of bias (Appendix E). No study adjusted for potential confounders, reported missing data, or attempted to blind outcome assessors; some studies also reported important baseline between-group differences. None of the studies reported industry funding, though one study did not report a funding source.

##### Intranasal Versus Intramuscular Naloxone

The two field trials of IN versus IM naloxone reported somewhat inconsistent results, which could be related to the use of IN naloxone preparations with different concentrations.^62,63^ In the first, earlier trial, which used a less-concentrated naloxone preparation (2 mg/5 mL), IN naloxone was associated with lower likelihood of spontaneous respirations within 8 minutes (63% vs. 82%, OR 0.38, 95% CI 0.18 to 0.81), higher likelihood of rescue naloxone use (26% vs. 13%, OR 2.4, 95% CI 1.0 to 5.7), and longer time to respirations >10/minutes (8 vs. 6 minutes, p=0.006) than IM naloxone.^62^ The difference in likelihood of Glasgow Coma Scale score >11 at 8 minutes (57% vs. 72%, OR 0.52, 95% CI 0.27 to 1.0) favored IM naloxone, but was of borderline statistical significance. The 2 mg/5 mL formulation is lower in concentration than formulations used in the U.S. The IN naloxone was associated with decreased risk of agitation and/or irritation (2.4% vs. 14%, RR 0.19, 95% CI 0.04 to 0.83), with no difference in risk of nausea or vomiting, or other adverse events. In the second trial, which used a more-concentrated IN naloxone preparation (2 mg/1 mL), there was no difference between IN versus IM naloxone in the likelihood of adequate response (defined as effective and spontaneous respirations at a rate ≥10/minute or Glasgow Coma Scale [GCS] score ≥13) within 10 minutes (72% vs. 78%, adjusted OR 0.7, 95% CI 0.3 to 1.5) or mean response time (8.0 vs. 7.9 minutes), though IN naloxone was associated with increased likelihood of rescue naloxone use (18% vs. 4.5%, adjusted OR 4.8, 955 CI 1.4 to 16).^63^ There was no difference in risk of agitation and/or violence (6.0% vs. 7.9%, RR 0.77, 95% CI 0.25 to 2.3), nausea or vomiting, or other adverse events. The 2 mg/1 mL formulation appears to have been manufactured specifically for this trial, and is not available in any product otherwise.

##### Intranasal Versus Intravenous Naloxone

One RCT^64^ and two observational studies^65,66^ evaluated IN versus IV naloxone. The RCT, conducted in an ED setting, found IN naloxone associated with greater likelihood than IV naloxone of an adequate response (defined as level of consciousness following naloxone of lethargic or conscious, 100% vs. 60%, RR 1.7, 95% CI 1.3 to 2.1).^64^ IN naloxone was also associated with greater likelihood of achieving full consciousness (44% vs. 24%, RR 1.8, 95% CI 1.0 to 3.3). The mean response time was longer with IN than IV naloxone by about 1 minute (2.56 vs. 1.48 minutes, p<0.001), with no difference in length of hospital stay (1.53 vs. 1.2 days, p=0.15). However, the point from which response time was measured was not clear. The IN naloxone was associated with lower likelihood of agitation than IV naloxone (0% vs. 24%, RR 0.04, 95% CI 0.002 to 0.66).

The two cohort studies of IN versus IV naloxone reported few clear differences.^65,66^ One study found no difference in median change in breaths per minute (4 vs. 6, p=0.08) or Glasgow Coma Scale score (3 vs. 4, p=0.19) from baseline.^65^ The other found no difference in likelihood of a positive clinical response (increase in respirations of ≥6 breaths/minute or Glasgow Coma Scale score ≥6 points) (66% vs. 56%, p=0.3) or time from patient contact to effect (20 vs. 21 minutes, p=0.9), though IN naloxone was associated with longer time from administration to effect (13 vs. 8.1 minutes, p=0.3).^66^

##### Other Route of Administration Comparisons

Other comparisons involving different routes of naloxone administration were evaluated in one cohort study each. One cohort study found no difference between IM versus IV naloxone in likelihood of a positive response (GCS ≥14 and respiratory rate ≥10/minute within 5 minutes of naloxone administration) (94% vs. 95%, RR 1.0, 95% CI 0.94 to 1.1).^67^ Another cohort study found SC naloxone associated with longer time from administration to respiratory rate ≥10/minute (5.5 vs. 3.8 minutes, p=0.001) than IV naloxone, but no difference in time from arrival at patient’s side to respiratory rate ≥10/minute (9.6 vs. 9.3 minutes, p=0.67).^68^ The SC naloxone was associated with lower likelihood than IV naloxone of requiring multiple doses (15% vs. 35%, RR 0.42, 95% CI 0.25 to 0.71).

##### Subgroup Effects

No study evaluated how comparative benefits and harms of different routes of naloxone administration differed according to age, sex, race, type of opioid involved in overdose, dose of opioid involved in overdose, presence of other drugs or substances contributing to overdose, estimated time since overdose, concomitant psychiatric comorbidities, or prior overdose episodes. Two trials^62,63^ and one cohort study^65^ reported that naloxone was administered by paramedics or Advanced Life Support personnel; one cohort study^68^ reported the level of training of EMS personnel as ranging from Basic to Advanced Life Support, but it was not clear who administered the naloxone. There was insufficient evidence to determine how level of EMS training affected findings regarding route of administration comparisons.

### Key Question 1a For patients with confirmed or suspected opioid overdose who receive naloxone in the out-of-hospital setting from EMS personnel, what are the comparative benefits and harms of different intravenous, intramuscular, subcutaneous, or intranasal doses of naloxone?

#### Key Point

- No study compared different doses of naloxone administered via the same route; there was too much clinical heterogeneity to determine effects of dose from indirect comparisons (SOE: insufficient).

#### Detailed Synthesis

No study compared different doses of naloxone administered via the same route. In the trials of different naloxone routes of administration described in Key Question 1, the doses, concentration of formulation, and routes of administration varied, making it difficult to interpret potential differences based on indirect comparisons.

In two RCTs of IN versus IM naloxone, the concentration of IN naloxone was 2 mg/5 mL in one trial and 2 mg/1 mL in the other, though the total dose administered (2 mg) was the same^62,63^ (Table 1). The difference in concentration could help explain the inconsistency in trial results—the less-concentrated formulation of IN naloxone was associated with worse outcomes than IM naloxone, probably related to the ability of each nostril to absorb a maximum volumes of ≤0.5 mL. Therefore, the effective dose of naloxone was probably lower in this trial than in the trial that evaluated the higher concentration formulation, even though the total administered dose was the same. No study evaluated the new FDA-approved, highly-concentrated reformulation of naloxone (4 mg/0.1 mL).

In one RCT^64^ and two cohort studies^65,66^ of IN versus IV naloxone, the doses and formulations of naloxone varied or were not well described (Tables 1 and 2). The RCT compared intranasal naloxone 0.4 mg/2 mL at a dose of 0.2 mg per nostril versus IV naloxone 0.4 mg; the two observational studies did not report the concentration of intranasal naloxone formulation (dose 2 mg) and the dose of IV naloxone ranged from 0.4 to 2.0 mg or was not reported. Therefore, no conclusions could be drawn regarding the association between naloxone dose for each route of administration and outcomes.

### Key Question 2 For patients with confirmed or suspected opioid overdose in out-of-hospital settings, what are the comparative benefits and harms of titration of naloxone administered by EMS personnel until the patient resumes sufficient spontaneous respiratory effort versus until the patient regains consciousness?

#### Key Point

- No study compared benefits and harms of titration of naloxone until the patient resumes sufficient spontaneous respiratory effort versus until the patient regains consciousness (SOE: insufficient).

#### Detailed Synthesis

No study compared benefits and harms of titration of naloxone until the patient resumes sufficient spontaneous respiratory effort versus until the patient regains consciousness. One RCT defined a response to naloxone not requiring repeat administration as improvement in respiratory rate ≥10 and Glasgow Coma Scale score ≥13.^63^ Other studies that compared different routes of naloxone administration did not specify titration targets, or targets were unclear. Therefore, there was insufficient indirect evidence to assess effects of different titration strategies on effectiveness.

### Key Question 3 For patients with confirmed or suspected opioid overdose in out-of-hospital settings treated with multiple doses of naloxone (including patients who do not improve after an initial dose of intranasal naloxone), what are the effects on benefits and harms of differences in timing of repeat dosing?

#### Key Point

- No study compared benefits and harms of differences in timing of repeat dosing of naloxone (SOE: insufficient).

#### Detailed Synthesis

No study compared benefits and harms of differences in timing of repeat dosing of naloxone. Among five studies that compared different routes of naloxone administration, timing of repeat dosing was 1 to 2 minutes in one study^67^ and 5 to 10 minutes in the others; due to other differences between trials (e.g. different doses and formulations, routes of administration, study design), it was not possible to assess effects of differences in redosing interval on effectiveness.

### Key Question 4 For patients with confirmed or suspected opioid overdose in out-of-hospital settings who regain sufficient spontaneous respiratory effort and are alert and oriented after naloxone administration by EMS personnel, what are the benefits and harms of transporting patients to a health care facility versus nontransport?

#### Key Points

- Among patients who were successfully treated for opioid overdose by naloxone in the field and not transported to a hospital, uncontrolled studies reported rates of deaths within 0 to 2 days were 0 percent in three studies (total N=1867), 0.6 percent (14/2241) in one study and 0.49 percent (1/205) in another study; one study reported one case of a life-threatening adverse event (1.25% [1/84]) (SOE: insufficient).
- No study evaluated outcomes such as linkage to treatment for opioid use disorder or subsequent repeat opioid overdose episodes.

#### Detailed Synthesis

No study compared outcomes among patients with confirmed or suspected opioid overdose who responded to naloxone administration and were transported to a health care facility versus not transported. Six studies (n=84 to 2241) reported on outcomes in patients who received naloxone for opioid overdose who were not transported to a health care facility (Table 4 and Appendix D, Table D-3). One study was conducted in Finland,^69^ one in The Netherlands^70^ and the others in the United States. None of the studies reported industry funding, though four of five studies did not report funding source. In the U.S. studies, patients declined transport to a hospital. In the European studies, reasons for nontransport were unclear or could vary (physician discretion or patient refusal). Ascertainment of naloxone administration was based on a retrospective review of EMS records and medical examiner databases, cardiac arrest registries and/or hospital records were used to assess outcomes. The studies did not describe how long patients were observed following successful reversal or opioid overdose. All of the studies were rated high risk of bias due to uncontrolled design, failure to blind outcome assessors to exposure status, and failure to report missing data (Appendix E). The uncontrolled design makes interpretation of findings difficult, since patients who refuse transport are likely to differ from those who are transported in important ways. For example, one study reported that 100 percent of patients who were not transported had Glasgow Coma Scale scores of 14 or 15, compared with about 50 percent of patients who were transported to an emergency department.^69^ Another methodological shortcoming is that the studies relied on medical examiner or hospital records to identify serious harms, rather than seeking to identify patients for followup. Reliance on medical examiner or hospital records requires that patients be accurately identified at the time of naloxone administration as well as at the time of death and that they remain in the same geographic area.

Table 4 Characteristics and results of uncontrolled studies of patients not transported to hospitals after naloxone administration

Author, Year Country Risk of Bias | Comparison Group (Sample Size) | Population Characteristics by Comparison Group | Results
Boyd, 2006^69^ Finland High | Refused transport to emergency department (n=84) | Overall population characteristics (includes patients who were transported to the emergency department) Age: 26 years Male: 83% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Received out-of-hospital naloxone: 85% vs. 85% | Life-threatening adverse event within 12 hours: 1/84 (1.19%, 95% CI 0.21 to 6.44)
Levine, 2016^74^ United States High | Refused Transport to emergency department (n=205) | Age: 41 years (29–53) Male: 87% Race: Not reported Psychiatric Comorbidities: Not reported Prior Overdoses: Not reported | Death within 24 hours:1/205 (0.49%, 95% CI 0.09–2.71%) Additional deaths within 30 days: 2/205 (0.98%, 95% CI 0.27–3.49%) Additional deaths within 6 months: None
Rudolph, 2011^70^ The Netherlands High | Physician released patient at scene or patient refused transport to emergency department (n=2241) | Age: Not reported Sex: Not reported Race: Not reported Psychiatric Comorbidities: Not reported Prior Overdoses: Not reported | Death within 48 hours: 14/2241 (0.62%, 95% CI 0.37–1.04%); 3 likely rebound overdoses, 10 new overdose, 1 natural death
Vilke, 1999^71^ United States High | Refused transport to emergency department (n=317) | Age: 37 Years (18–79) Male: 82.7% Race: Not reported Psychiatric Comorbidities: Not reported Prior Overdoses: Not reported | Death within 12 hours: 0 (95% CI 0 to 1.2)
Vilke, 2003^72^ United States High | Refused transport to emergency department (n=998) | Age: 37.7 years (16–83) Male: 83.8% Race: Not reported Psychiatric Comorbidities: Not reported Prior Overdoses: Not reported | Death within 12 hours: 0/998 (0%, 95% CI 0–0.38%)
Wampler, 2011^73^ United States High | Refused transport to emergency department (n= 552) | Age: 38± 15 years (13–91) Male: 72% Race: Not reported Psychiatric Comorbidities: Not reported Prior Overdoses: Not reported | Deaths within 48 hours: 0/552 (0%, 95% CI 0–0.69%) Deaths from 4–372 days: 9/592 (1.6%, 95% CI 0.5% to 2.7%)

CI = confidence interval

Rates of serious adverse events, including deaths, were low in all of the studies (Table 3). Within 0 to 2 days of naloxone administration, the proportion of patients was 0 percent in three studies^71–73^ (n=317, 552, and 998), one study^74^ reporting one death (0.49% [1/205]), and one study^70^ reporting 14 deaths (0.6% [14/2241]): three attributed to likely rebound overdose (0.13%), ten to new overdose, and one to a natural death. The final study reported one case of a life-threatening adverse event (1.2% [1/84]).^69^ One study^74^ reported two additional deaths at 30 days (1% [2/205]) and another^73^ found nine deaths through up to 1 year (1.6% [9/552]). No study evaluated outcomes such as linkage to treatment for opioid use disorder or subsequent repeat opioid overdose episodes.