# References

1 Macrae J, Hyde P, Slavitt A. HHS launches multi-pronged effort to combat opioid abuse Washington, DC: U.S. Department of Health & Human Services; July 27, 2015. http://www.hhs.gov/blog/2015/07/27/hhs-launches-multi-pronged-effort-combat-opioid-abuse.html. Accessed August 29, 2016.
2 Centers for Disease Control and Prevention. Vital signs: overdoses of prescription opioid pain relievers---United States, 1999--2008. FIGURE 2. Rates of opioid pain reliever (OPR) overdose death, OPR treatment admissions, and kilograms of OPR sold --- United States, 1999--2010. MMWR Morb Mortal Wkly Rep. 2011 Nov 4;60(43):1487–92. PMID: 22048730.22048730
3 Rudd RA, Seth P, David F, . Increases in drug and opioid overdose deaths--United States, 2010–2015. MMWR Morb Mortal Wkly Rep. 2016;65(50–51):1445–52.28033313
4 National Center for Health Statistics. Drug-poisoning deaths involving opioid analgesics: United States, 1999–2011. NCHS Data Brief 166. Atlanta, GA: Centers for Disease Control and Prevention; September 2014. https://www.cdc.gov/nchs/products/databriefs/db166.htm. Accessed May 25, 2016.
5 Angst MS, Lazzeroni LC, Phillips NG, . Aversive and reinforcing opioid effects: a pharmacogenomic twin study. Anesthesiology. 2012 Jul;117(1):22–37. doi: 10.1097/ALN.0b013e31825a2a4e. PMID: 22713632.22713632
6 Bohnert AS, Valenstein M, Bair MJ, . Association between opioid prescribing patterns and opioid overdose-related deaths. JAMA. 2011 Apr 6;305(13):1315–21. doi: 10.1001/jama.2011.370. PMID: 21467284.21467284
7 Darke S, Hall W. Heroin overdose: research and evidence-based intervention. J Urban Health. 2003 Jun;80(2):189–200. doi: 10.1093/jurban/jtg022. PMID: 12791795.12791795
8 Dilokthornsakul P, Moore G, Campbell JD, . Risk factors of prescription opioid overdose among Colorado Medicaid beneficiaries. J Pain. 2016 Apr;17(4):436–43. doi: 10.1016/j.jpain.2015.12.006. PMID: 26721613.26721613
9 Hall AJ, Logan JE, Toblin RL, . Patterns of abuse among unintentional pharmaceutical overdose fatalities. JAMA. 2008 Dec 10;300(22):2613–20. doi: 10.1001/jama.2008.802. PMID: 19066381.19066381
10 Zedler B, Xie L, Wang L, . Risk factors for serious prescription opioid-related toxicity or overdose among Veterans Health Administration patients. Pain Med. 2014 Nov;15(11):1911–29. doi: 10.1111/pme.12480. PMID: 24931395.24931395
11 Schumann H, Erickson T, Thompson TM, . Fentanyl epidemic in Chicago, Illinois and surrounding Cook County. Clin Toxicol. 2008 Jul;46(6):501–6. doi: 10.1080/15563650701877374. PMID: 18584361.18584361
12 Frank RG, Pollack HA. Addressing the fentanyl threat to public health. N Engl J Med. 2017 Feb 16;376(7):605–7. doi: 10.1056/NEJMp1615145. PMID: 28199808.28199808
13 Tomassoni AJ, Hawk KF, Jubanyik K, . Multiple fentanyl overdoses - New Haven, Connecticut, June 23, 2016. MMWR Morb Mortal Wkly Rep. 2017 Feb 03;66(4):107–11. doi: 10.15585/mm6604a4. PMID: 28151928.28151928
14 Somerville NJ, O’Donnell J, Gladden RM, . Characteristics of fentanyl overdose - Massachusetts, 2014–2016. MMWR Morb Mortal Wkly Rep. 2017 Apr 14;66(14):382–6. doi: 10.15585/mmwr.mm6614a2. PMID: 28406883.28406883
15 Sutter ME, Gerona RR, Davis MT, . Fatal fentanyl: One pill can kill. Acad Emerg Med. 2016 Jun 20doi: 10.1111/acem.13034. PMID: 27322591.27322591
16 Bailey JE, Campagna E, Dart RC, . The underrecognized toll of prescription opioid abuse on young children. Ann Emerg Med. 2009 Apr;53(4):419–24. doi: 10.1016/j.annemergmed.2008.07.015. PMID: 18774623.18774623
17 Bond GR, Woodward RW, Ho M. The growing impact of pediatric pharmaceutical poisoning. J Pediatr. 2012 Feb;160(2):265–70 e1. doi: 10.1016/j.jpeds.2011.07.042. PMID: 21920539.21920539
18 Darke S, Mattick RP, Degenhardt L. The ratio of non-fatal to fatal heroin overdose. Addiction. 2003 Aug;98(8):1169–71. PMID: 12873254.12873254
19 Dunn KM, Saunders KW, Rutter CM, . Opioid prescriptions for chronic pain and overdose: a cohort study. Ann Intern Med. 2010 Jan 19;152(2):85–92. doi: 10.7326/0003-4819-152-2-201001190-00006. PMID: 20083827.20083827
20 Boyer EW. Management of opioid analgesic overdose. N Engl J Med. 2012 Jul 12;367(2):146–55. doi: 10.1056/NEJMra1202561. PMID: 22784117.22784117
21 Strang J, McDonald R, Alqurshi A, . Naloxone without the needle - systematic review of candidate routes for non-injectable naloxone for opioid overdose reversal. Drug Alcohol Depend. 2016 Jun 1;163:16–23. doi: 10.1016/j.drugalcdep.2016.02.042. PMID: 26996745.26996745
22 FDA approves new hand-held auto-injector to reverse opioid overdose. FDA news release, April 3, 2014. Silver Spring, MD: U.S. Food and Drug Administration; 2014. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm391465.htm. Accessed February 15, 2017.
23 FDA moves quickly to approve easy-to-use nasal spray to treat opioid overdose. FDA news release, Nov. 18, 2015. Silver Spring, MD: U.S. Food and Drug Administration; 2015. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm473505.htm. Accessed August 29, 2016.
24 Mueller SR, Walley AY, Calcaterra SL, . A review of opioid overdose prevention and naloxone prescribing: implications for translating community programming into clinical practice. Subst Abus. 2015;36(2):240–53. doi: 10.1080/08897077.2015.1010032. PMID: 25774771.25774771
25 Walley AY, Xuan Z, Hackman HH, . Opioid overdose rates and implementation of overdose education and nasal naloxone distribution in Massachusetts: interrupted time series analysis. BMJ. 2013;346:f174. doi: 10.1136/bmj.f174. PMID: 23372174.23372174
26 Wheeler E, Jones TS, Gilbert MK, . Opioid overdose prevention programs providing naloxone to laypersons - United States, 2014. MMWR Morb Mortal Wkly Rep. 2015 Jun 19;64(23):631–5. PMID: 26086633.26086633
27 Kim D, Irwin KS, Khoshnood K. Expanded access to naloxone: options for critical response to the epidemic of opioid overdose mortality. Am J Public Health. 2009 Mar;99(3):402–7. doi: 10.2105/AJPH.2008.136937. PMID: 19150908.19150908
28 Wermeling DP. Review of naloxone safety for opioid overdose: practical considerations for new technology and expanded public access. Ther Adv Drug Saf. 2015 Feb;6(1):20–31. doi: 10.1177/2042098614564776. PMID: 25642320.25642320
29 Clarke SF, Dargan PI, Jones AL. Naloxone in opioid poisoning: walking the tightrope. Emerg Med J. 2005 Sep;22(9):612–6. PMID: 16113176.16113176
30 Buajordet I, Naess AC, Jacobsen D, . Adverse events after naloxone treatment of episodes of suspected acute opioid overdose. Eur J Emerg Med. 2004 Feb;11(1):19–23. PMID: 15167188.15167188
31 EMS1. 5 things EMS providers need to know about opioid overdose and respiratory compromise. 2016. http://www.ems1.com/ems-products/Capnography/articles/47753048-5-things-EMS-providers-need-to-know-about-opioid-overdose-and-respiratory-compromise/. Accessed October 7, 2016.
32 Alcorn T. America embraces treatment for opioid drug overdose. Lancet. 2014 Jun 7;383(9933):1957–8. PMID: 24936622.24936622
33 Fala L, Welz JA. New perspectives in the treatment of opioid-induced respiratory depression. Am Health Drug Benefits. 2015 Oct;8(6 Suppl 3):S51–63. PMID: 26629261.26629261
34 National EMS Information System (NEMSIS). Create a report (NEMSIS Cube). 2017. http://nemsis.org/reportingTools/reports/nationalReports/createAReport.html. Accessed Februrary 15, 2017.
35 National Highway Traffic Safety Administration. The national EMS scope of practice model. DOT HS 810 657. Washington, DC: U.S. Department of Transportation; February 2007. http://www.ems.gov/education/EMSScope.pdf Accessed August 29, 2016.
36 Davis CS, Southwell JK, Niehaus VR, . Emergency medical services naloxone access: a national systematic legal review. Acad Emerg Med. 2014 Oct;21(10):1173–7. doi: 10.1111/acem.12485. PMID: 25308142.25308142
37 Faul M, Dailey MW, Sugerman DE, . Disparity in naloxone administration by emergency medical service providers and the burden of drug overdose in US rural communities. Am J Public Health. 2015 Jul;105 Suppl 3:e26–32. doi: 10.2105/AJPH.2014.302520. PMID: 25905856.25905856
38 Weiner SG, Mitchell PM, Temin ES, . Use of intranasal naloxone by basic life support providers. Prehosp Emerg Care. 2017:1–5. doi: 10.1080/10903127.2017.1282562.
39 Lavonas EJ, Drennan IR, Gabrielli A, . Part 10: Special circumstances of resuscitation: 2015 American Heart Association guidelines update for cardiopulmonary resuscitation and emergency cardiovascular care. Circulation. 2015 Nov 3;132(18 Suppl 2):S501–18. doi: 10.1161/CIR.0000000000000264. PMID: 26472998.26472998
40 National Association of State EMS Officials. National model EMS clinical guidelines. 2014. https://www.nasemso.org/Projects/ModelEMSClinicalGuidelines/documents/National-Model-EMS-Clinical-Guidelines-23Oct2014.pdf. Accessed August 29, 2016.
41 World Health Organization (WHO). Community management of opioid overdose. Geneva, Switzerland; 2014. http://www.who.int/substance_abuse/publications/management_opioid_overdose/en/.
42 Connors NJ, Nelson LS. The evolution of recommended naloxone dosing for opioid overdose by medical specialty. J Med Toxicol. 2016 Sep;12(3):276–81. doi: 10.1007/s13181-016-0559-3. PMID: 27271032.27271032
43 EVZIO (naloxone HCl injection) 2 mg auto-injector Intelligent Voice Guidance^TM^. Reach for voice guidance. https://evzio.com/patient/about-evzio/index.php. Accessed February 15, 2017.
44 Strang J, McDonald R, Tas B, . Clinical provision of improvised nasal naloxone without experimental testing and without regulatory approval: imaginative shortcut or dangerous bypass of essential safety procedures? Addiction. 2016 Apr;111(4):574–82. doi: 10.1111/add.13209. PMID: 26840916.26840916
45 Morrone WR. President’s message: Food and Drug Administration approved naloxone and continued use of improvised nasal naloxone: What is a treatment advocate and educator to do? J Addict Dis. 2016 Oct–Dec;35(4):339–45. doi: 10.1080/10550887.2016.1226582. PMID: 27731792.27731792
46 Traynor K. FDA approves first intranasal naloxone product. Am J Health Syst Pharm. 2016;73(1):e2–e3. doi: 10.2146/news160002. PMID: 2668367526683675
47 ADAPT Pharma Operations Limited. NARCAN^R^ (naloxone HCl) nasal spray 2mg approved y U.S. Food and Drug Administration (FDA). 2016. http://adaptpharma.com/adapt_press_release/january-25-2017-narcan-nasal-spray-2mg-approved-by-us-food-and-drug-administration/. Accessed Februrary 15, 2017.
48 INVDIVIOR. Indivior feceives complete response letter from FDA not approving naloxone nasal spray new drug application for opioid overdose. 2015. http://www.indivior.com/wp-content/uploads/2015/11/Nasal-Naloxone-Final-Release_112415.pdf Accessed January 23, 2017.
49 CDC Health Alert Network. Influx of fentanyl-laced counterfeit pills and fentanyl-related compounds further increases risk of fenanyl-related overdose and fatalities. 2016. https://emergency.cdc.gov/han/han00395.asp. Accessed October 7, 2016.
50 Faul M. Trends in multiple naloxone administrations among EMS personnel: FDA Anesthetic and Analgesic Drug Products Advisory Committee and the Drug Safety and Risk Management Advisory Committee. 2016. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM524338.pdf Accessed January 20, 2017.
51 Millin MG, Brown LH, Schwartz B. EMS provider determinations of necessity for transport and reimbursement for EMS response, medical care, and transport: combined resource document for the National Association of EMS Physicians position statements. Prehosp Emerg Care. 2011 Oct–Dec;15(4):562–9. doi: 10.3109/10903127.2011.598625. PMID: 21797787.21797787
52 Agency for Healthcare Research and Quality. Methods guide for effectiveness and comparative effectiveness reviews. 2014. www.effectivehealthcare.ahrq.gov. Accessed January 23, 2017.
53 U.S. Food and Drug Administration. 2016 Meeting Materials, Anesthetic and Analgesic Drug Products Advisory Committee. 2016. http://www.fda.gov/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/ucm486848.htm.
54 Adapt Pharma Operations Limited. FDA Advisory Committee on the most appropriate dose or doses of naloxone to reverse the effects of life-threatening opiod overdose in the community settings. 2016. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM522688.pdf.
55 U.S. Food and Drug Administration. Joint meeting of anesthetic and analgesic drug products advisory committee and drug safety and risk management advisory committee. 2016. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM522687.pdf.
56 Amphastar Pharmaceuticals. FDA Advisory Committee Briefing Materials. Intranasal naloxone intended for use in the community. Joint meeting of the anesthetic and analgesic drug products advisory committee and the drug safety and risk management advisory committee. 2016. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM522689.pdf.
57 Amphastar Pharmaceuticals. Naloxone meeting: Joint meeting of the anesthetic and alagesic drug products advisory committee and the drug safety and risk management advisory committee. 2016. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM524334.pdf.
58 Insys Development Company Inc. Naloxone for treatment of opioide overdose 2016. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM522690.pdf Accessed December 19, 2016.
59 Kaleo Inc. Joint meeting of the anesthetic and analgesic drug products and the drug safety and risk management advisory committees. 2016. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM522691.pdf.
60 McDonagh M, Peterson K, Raina P, . Avoiding bias in selecting studies. Methods guide for comparative effectiveness reviews. (Prepared by the Oregon Health & Science University, McMaster University, and Southern California Evidence-based Practice Centers under Contract No. 290-2007-10057-I.) AHRQ Publication No. 13-EHC045-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm Accessed August 29, 2016.
61 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force procedure manual. 2008. http://www.uspreventiveservicestaskforce.org/uspstf08/methods/procmanual.htm.
62 Kelly AM, Kerr D, Dietze P, . Randomised trial of intranasal versus intramuscular naloxone in prehospital treatment for suspected opioid overdose. Med J Aust. 2005 Jan 3;182(1):24–7. PMID: 15651944.15651944
63 Kerr D, Kelly AM, Dietze P, . Randomized controlled trial comparing the effectiveness and safety of intranasal and intramuscular naloxone for the treatment of suspected heroin overdose. Addiction. 2009 Dec;104(12):2067–74. doi: 10.1111/j.1360-0443.2009.02724.x. PMID: 19922572.19922572
64 Sabzghabaee AM, Eizadi-Mood N, Yaraghi A, . Naloxone therapy in opioid overdose patients: intranasal or intravenous? a randomized clinical trial. Arch Med Sci. 2014 May 12;10(2):309–14. doi: 10.5114/aoms.2014.42584. PMID: 24904666.24904666
65 Merlin MA, Saybolt M, Kapitanyan R, . Intranasal naloxone delivery is an alternative to intravenous naloxone for opioid overdoses. Am J Emerg Med. 2010 Mar;28(3):296–303. doi: 10.1016/j.ajem.2008.12.009. PMID: 20223386.20223386
66 Robertson TM, Hendey GW, Stroh G, . Intranasal naloxone is a viable alternative to intravenous naloxone for prehospital narcotic overdose. Prehosp Emerg Care. 2009 Oct–Dec;13(4):512–5. doi: 10.1080/10903120903144866. PMID: 19731165.19731165
67 Sporer KA, Firestone J, Isaacs SM. Out-of-hospital treatment of opioid overdoses in an urban setting. Acad Emerg Med. 1996 Jul;3(7):660–7. PMID: 8816181.8816181
68 Wanger K, Brough L, Macmillan I, . Intravenous vs subcutaneous naloxone for out-of-hospital management of presumed opioid overdose. Acad Emerg Med. 1998 Apr;5(4):293–9. PMID: 9562190.9562190
69 Boyd JJ, Kuisma MJ, Alaspaa AO, . Recurrent opioid toxicity after pre-hospital care of presumed heroin overdose patients. Acta Anaesthesiol Scand. 2006 Nov;50(10):1266–70. PMID: 17067327.17067327
70 Rudolph SS, Jehu G, Nielsen SL, . Prehospital treatment of opioid overdose in Copenhagen--is it safe to discharge on-scene? Resuscitation. 2011 Nov;82(11):1414–8. doi: 10.1016/j.resuscitation.2011.06.027. PMID: 21745532.21745532
71 Vilke GM, Buchanan J, Dunford JV, . Are heroin overdose deaths related to patient release after prehospital treatment with naloxone? Prehosp Emerg Care. 1999 Jul–Sep;3(3):183–6. PMID: 10424852.10424852
72 Vilke GM, Sloane C, Smith AM, . Assessment for deaths in out-of-hospital heroin overdose patients treated with naloxone who refuse transport. Acad Emerg Med. 2003 Aug;10(8):893–6. PMID: 12896894.12896894
73 Wampler DA, Molina DK, McManus J, . No deaths associated with patient refusal of transport after naloxone-reversed opioid overdose. Prehosp Emerg Care. 2011 Jul–Sep;15(3):320–4. doi: 10.3109/10903127.2011.569854. PMID: 21612385.21612385
74 Levine M, Sanko S, Eckstein M. Assessing the risk of prehospital administration of naloxone with subsequent refusal of care. Prehosp Emerg Care. 2016;20(5):566–9. PMID: 27018626.27018626
75 Willman MW, Liss DB, Schwarz ES, . Do heroin overdose patients require observation after receiving naloxone? Clin Toxicol (Phila). 2017 Feb;55(2):81–7. doi: 10.1080/15563650.2016.1253846. PMID: 27849133.27849133
76 Fiore K. FDA splits on naloxone dose. 2016. http://www.medpagetoday.com/Neurology/GeneralNeurology/60632.
77 Dowling J, Isbister GK, Kirkpatrick CM, . Population pharmacokinetics of intravenous, intramuscular, and intranasal naloxone in human volunteers. Ther Drug Monit. 2008 Aug;30(4):490–6. doi: 10.1097/FTD.0b013e3181816214. PMID: 18641540.18641540
78 Krieter P, Chiang N, Gyaw S, . Pharmacokinetic properties and human use characteristics of an FDA-approved intranasal naloxone product for the treatment of opioid overdose. J Clin Pharmacol. 2016 Oct;56(10):1243–53. doi: 10.1002/jcph.759. PMID: 27145977.27145977
79 Faul M, Lurie P, Kinsman J, . Multiple naloxone administrations among EMS Providers is increasing. Prehosp Emerg Care. 2017(8):1–8. doi: 10.1080/10903127.2017.1315203. PMID: 28481656.28481656
80 New York State Public Safety. Retrospective analysis of data from NY and NJ. Amphastar Pharmaceuticals. http://www.fda.gov/downloads/AdvisoryCommittees/CommitteesMeetingMaterials/Drugs/AnestheticAndAnalgesicDrugProductsAdvisoryCommittee/UCM522689.pdf. Accessed January 23, 2017. p. 26.
81 Barton ED, Colwell CB, Wolfe T, . Efficacy of intranasal naloxone as a needleless alternative for treatment of opioid overdose in the prehospital setting. J Emerg Med. 2005 Oct;29(3):265–71. PMID: 16183444.16183444
82 Edwards ET, Edwards ES, Davis E, . Comparative usability study of a novel auto-injector and an intranasal system for naloxone delivery. Pain Ther. 2015 Jun;4(1):89–105. doi: 10.1007/s40122-015-0035-9. PMID: 25910473.25910473
83 Gupta R, Shah ND, Ross JS. The rising price of naloxone - risks to efforts to stem overdose deaths. N Engl J Med. 2016 Dec 08;375(23):2213–5. doi: 10.1056/NEJMp1609578. PMID: 27959694.27959694
84 Leonard K. Major changes could be coming to overdose-reversal drugs. U.S. News & World Report: 2016. http://www.usnews.com/news/articles/2016-10-06/fda-panel-more-naloxone-needed-in-overdose-reversal-device Accessed January 23, 2017.
85 Department of Health and Human Services. NDA 209862 approval. 2016. http://www.accessdata.fda.gov/drugsatfda_docs/appletter/2016/209862Orig1s000ltr.pdf Accessed January 23, 2017.
86 Rando J, Broering D, Olson JE, . Intranasal naloxone administration by police first responders is associated with decreased opioid overdose deaths. Am J Emerg Med. 2015 Sep;33(9):1201–4. doi: 10.1016/j.ajem.2015.05.022. PMID: 26095132.26095132
87 Fisher R, O’Donnell D, Ray B, . Police officers can safely and effectively administer intranasal naloxone. Prehosp Emerg Care. 2016;20(6):675–80. doi: 10.1080/10903127.2016.1182605. PMID: 27218446.27218446
88 Davis C. Naloxone for community opiod overdose reversal. http://prescribetoprevent.org/wp2015/wp-content/uploads/PHLRKnowledgeAsset_Naloxone_FINALfull_8June15.pdf Accessed February 15, 2017.
89 Giglio RE, Li G, DiMaggio CJ. Effectiveness of bystander naloxone administration and overdose education programs: a meta-analysis. Inj Epidemiol. 2015;2(1):10. doi: 10.1186/s40621-015-0041-8. PMID: 27747742.27747742
90 Mahoney K. FDA supports greater access to naloxone to help reduce opioid overdose deaths. 2016. http://blogs.fda.gov/fdavoice/index.php/2016/08/fda-supports-greater-access-to-naloxone-to-help-reduce-opioid-overdose-deaths/. Accessed February 15, 2017.
91 Brennan Z. OTC opioid overdose antidote: why is it not FDA approved? ; 2016. http://www.raps.org/Regulatory-Focus/News/2016/02/24/24400/OTC-Opioid-Overdose-Antidote-Why-is-it-not-FDA-Approved/. Accessed February 15, 2017.
92 Davis CS, Carr D. Legal changes to increase access to naloxone for opioid overdose reversal in the United States. Drug & Alcohol Dependence. 2015 Dec 1;157:112–20. doi: 10.1016/j.drugalcdep.2015.10.013. PMID: 26507172.26507172
93 Dailey M. Report of a Field Trial for Comparason of Two Intranasal Naloxnoe Delivery Devices: An Equipoise Trial. Society of Academic Emergency Medicine; 2017 Friday, May 19; Hyatt Regency, Orlando.
94 National EMS Information System (NEMSIS). The project. 2005. http://nemsis.org/theProject/index.html. Accessed February 15, 2017.
95 Weber JM, Tataris KL, Hoffman JD, . Can nebulized naloxone be used safely and effectively by emergency medical services for suspected opioid overdose? Prehosp Emerg Care. 2012 Apr–Jun;16(2):289–92. doi: 10.3109/10903127.2011.640763. PMID: 22191727.22191727
96 Callaway CW, Soar J, Aikiki M, . Part 4: advanced life support 2015 international consensus on cardiopulmonary resuscitation and emergency cardiovascular care science with treatment recommendations. Cardiac arrest in special circumstances. 2015. http://circ.ahajournals.org/content/132/16_suppl_1/S84#sec-173. Accessed February 15, 2017.