# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Steven Aks, D.O., FACMT, FACEP
  Toxicon Consortium,
  Cook County Health and Hospitals System
  Chicago, IL
- Jeffrey Bratberg, Pharm.D.
  University of Rhode Island
  Kingston, RI
- Christian Martin-Gill, M.D., M.P.H.
  University of Pittsburgh
  Pittsburgh, PA
- Jennifer Plumb, M.D., M.P.H.
  University of Utah
  Salt Lake City, UT
- Ken Sternig, M.S.-E.H.S., B.S.N., Paramedic
  Office of Emergency Management
  Milwaukee, WI