# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicting opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Caleb Banta-Green, Ph.D., M.P.H., M.S.W.
  University of Washington
  Seattle, WA
- Michael Dailey,^*^ M.D., FACEP, FAEMS
  Albany Medical College
  Albany, NY
- Corey Davis,^*^ J.D., M.S.P.H., EMT-B
  Network for Public Health Law
  Los Angeles, CA
- James J. Gasper,^*^ Pharm.D., BCPP
  California Department of Healthcare Services
  Sacramento, CA
- Christopher Jones, Pharm.D., Ph.D.
  U.S. Department of Health and Human Services
  Washington, DC
- Scott Russell,^*^ R.N., B.S.N., EMT-P
  Metrohealth
  Cleveland, OH
- Karl Sporer, M.D.
  University of California, San Francisco
  San Francisco, CA
- Sharon Stancliff,^*^ M.D.
  Harm Reduction Coalition
  New York, NY
- Gregory Terman,^*^ M.D., Ph.D.
  University of Washington
  Seattle, WA
- U.S. Food and Drug Administration^*^
  Center for Drug Evaluation and Research
  Office of New Drugs
  Division of Analgesia, Anesthesia, and Addiction Products
  Silver Spring, MD
- Alexander Walley, M.D., M.Sc.
  Boston University
  Boston, MA

* Provided input on Draft Report.