# Key Informants

Key Informants were not involved in the development of this report.