# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elaine Graham, M.L.S.; Tracy Dana, M.L.S.; Leah Williams, BS; and Hyon Hildebrant, B.A.