# Discussion

## Key Findings and Strength of Evidence

While naloxone is generally effective for reversing suspected opioid overdose, evidence to inform optimal management of suspected opioid overdose with naloxone by emergency medical services (EMS) personnel is limited (Appendix F). Three randomized controlled trials (RCTs) directly compared different routes of naloxone administration, but all had methodological shortcomings, including use of unblinded design.^62–64^ Among the three trials, two compared intranasal (IN) with intramuscular (IM) naloxone^62,63^ and one trial evaluated IN versus intravenous (IV) naloxone.^64^ No trial evaluated the recently U.S. Food and Drug Administration (FDA)-approved naloxone auto-injectors for IM administration or highly-concentrated (4 mg/0.1 mL or 2 mg/0.1 mL) IN formulations of naloxone.

For IN versus IM naloxone, results suggest that a higher concentration formulation of IN (2 mg/1 mL) naloxone is similar in efficacy to IM naloxone^62,63^ (strength of evidence [SOE]: low). Although 2 mg of IN naloxone was administered in both trials, one trial evaluated a lower concentration formulation (total of 5 mL instilled),^62^ compared with a higher concentration formulation (total of 1 mL instilled) in the other trial.^63^ In the trial that used a more-concentrated formulation of IN naloxone, there was no difference versus IM naloxone in the likelihood of an adequate response to naloxone (reversal of overdose symptoms with resumption of spontaneous respirations or level of consciousness), mean response time, or adverse events, though IN naloxone was associated with increased likelihood of rescue naloxone use (18% vs. 4.5%, adjusted OR 4.8, 95% CI 1.4 to 16)^63^ (SOE: low). By contrast, in the trial that used a less-concentrated formulation, IN naloxone was associated with lower response rates, longer time to response, and decreased risk of agitation and/or irritation compared with IM naloxone.^62^ This could be due to a lower effective dose of IN naloxone in the latter trial, since the ideal volume of delivery via the IN route is ≤0.5 mL per nostril. Efficacy was based on effects on overdose symptoms (likelihood of an adequate response, time to reversal, and recurrence of symptoms). The trials did not evaluate effects on healthcare utilization or other clinical outcomes (e.g., function or quality of life) and were not designed to assess risk of serious injuries, such as needle stick, though no cases were reported.

While naloxone is generally effective for reversing suspected opioid overdose, evidence regarding other route of administration comparisons is even more limited. One trial of IN versus IV naloxone found IN naloxone associated with greater likelihood than IV naloxone of an adequate response (defined as level of consciousness “lethargic” or “conscious,” 100% vs. 60%, RR 1.3 to 2.1), slightly longer response time (difference ~1 minute), and lower likelihood of agitation (0% vs. 24%, RR 0.04, 95% CI 0.002 to 0.66).^64^ However, the trial was conducted in an Iranian emergency department (ED) setting, limits generalizability to field settings in the United States (SOE: insufficient).

Observational studies were of very limited usefulness for informing route of administration comparisons. The four observational studies that compared different routes of naloxone administration in field settings had serious methodological shortcomings, including failure to adjust for potential confounders.^65–68^ In addition, the route of administration comparisons varied across the studies. No study compared IN versus IM naloxone or evaluated recently FDA-approved formulations; all studies were conducted prior to the recent FDA approvals.

Studies comparing different routes of naloxone administration were not designed to assess risk of serious injuries, such as needle stick (potentially resulting in exposure to highly potent synthetic opioids or infectious diseases in naloxone administering personnel). However, no cases of serious injuries were reported in the RCTs or observational studies. Evidence was insufficient to determine how comparative benefits and harms of different routes of naloxone administration differed according to demographics or clinical factors, such as the type and dose of opioid involved in overdose (including whether fentanyl or a fentanyl analogue was involved), presence of other drugs or substances, estimated time since overdose, concomitant psychiatric comorbidities, or prior overdose episodes. There was also insufficient evidence to determine how the type or training of EMS personnel administering naloxone impacted comparisons involving different routes of administration or doses of naloxone. Most studies that provided information regarding the level of training of EMS personnel who administered naloxone reported that they were paramedics or had Advanced Life Support certification, reflecting the scope of practice for EMS personnel. Only one study comparing different routes of administration reported the type of opioid involved in suspected overdoses;^64^ it was conducted in Iran, with a high proportion of overdoses related to use of opium.

There was insufficient evidence to determine the optimal dose of naloxone by route of administration. No study directly compared different doses of naloxone administered via the same route. It was not possible to determine effects of dose via indirect comparisons from studies of one route of administration versus another, given the small number of studies and differences across in factors other than dose, such as the concentration of IN naloxone formulation, field versus ED setting administration of naloxone, and methodological limitations in the studies.

Evidence was too limited to reliably determine effects of hospital transport versus nontransport following successful treatment of opioid overdose. Although six studies reported low rates (0 to 1.2%) of death or serious adverse events among patients who received naloxone for opioid overdose and were not transported to a health care facility,^69–74^ there was no comparison group of patients who were transported, and the studies provided limited details regarding the characteristics of the nontransported patients. This makes interpretation of findings difficult, as patients who refuse transport or are assessed as not requiring transport are likely to be at lower risk of opioid overdose-related complications than patients who are transported. For example, one study reported that 100 percent of patients who were not transported to an ED had a Glasgow Coma Scale Score of 14 or 15 following naloxone administration, compared with about half of patients were transported.^69^ In addition, the studies relied on medical examiner and hospital records to identify serious outcomes, which could underestimate event rates. The studies were not designed to evaluate outcomes such as linkage to treatment for opioid use disorder or subsequent repeat opioid overdose episodes.

No study compared titration of naloxone administered by EMS personnel until the patient resumes sufficient spontaneous respiratory effort versus until the patient regains consciousness or differences in timing of repeat naloxone dosing.

## Findings in Relationship to What Is Already Known

Our findings are consistent with a systematic review that found a total of 4 deaths due to rebound opioid toxicity among 5,443 patients not transported following reversal of opioid overdose with naloxone ^75^. We identified no previously published systematic review addressing the other Key Questions in our report. Our findings are generally consistent with the conclusions of a recent FDA meeting that focused on naloxone dosing for devices intended for use by laypeople.^53^ The committee convened by the FDA generally found a lack of evidence to determine optimal dosing of naloxone.^76^ This meeting included additional data and information submitted by manufacturers of naloxone. At the meeting, evidence to support higher dosing of naloxone was largely based on pharmacokinetic data and considerations regarding increased reports of overdose episodes related to high potency synthetic opioids. The current pharmacokinetic standard for new naloxone products is that they achieve levels comparable to or greater than the approved starting dose of 0.4 mg of naloxone administered by the IV, IM, or subcutaneous (SC) routes. Clinical data suggest that lower amounts of naloxone (0.05 to 0.1 mg) may be sufficient to produce sufficient opioid antagonism in most cases, though the amount required may vary depending on the dose, potency, and duration of action of the opioid involved in the overdose.^77^ One randomized pharmacokinetic study found that the mean naloxone concentration area under the receiver operating characteristic curve was similar for a single IM/SC injection of 0.4 mg naloxone using the recently FDA-approved auto-injector and using a standard syringe, though the maximum concentration of naloxone was 15 percent higher with administration using the autoinjector.^59^ A pharmacokinetic study of IN naloxone found that the plasma concentration AUROC and peak plasma concentration for a single dose of concentrated IN naloxone (4 mg/0.1 mL) exceeded that of 0.4 mg IM, and was similar to a 2 mg IM dose, or the highest recommended initial dose of IM naloxone.^78^ Factors potentially affecting the bioavailability of IN naloxone include the volume administered per nostril (larger volumes are swallowed and not bioavailable), whether the patient is conscious or unconscious (less of the intranasal dose may be swallowed by unconscious patients), position of the patient, differences in nasal physiology (e.g. obstruction, anatomical variation), drug interactions (e.g., use of IN cocaine), and certain diseases.^59,77^

Clinical evidence at the FDA meeting of some relevance to this report include a study of national EMS registry data that found that the proportion of overdose episodes requiring repeat doses of naloxone increased from 14 to 18 percent from 2012 to 2015, potentially suggesting a need for higher initial doses in order to reduce the need for repeat dosing;^50^ this study has subsequently been published.^79^ Another retrospective study found that approximately one-third of cases involving administration of off-label IN naloxone (2 mg/2 mL) by first responders in New York and New Jersey involved multiple doses.^80^ However, interpretation of these studies is a challenge. In both studies, it was unclear if repeat doses were administered because of failure of initial doses, changes in EMS protocols regarding repeat dosing, differences in the threshold for repeat dosing, or other factors. The studies, moreover, were not designed to assess differences in clinical outcome between patients receiving single versus multiple doses. In contrast to community settings in which patients may not receive adequate ventilatory support, in EMS administration settings the negative clinical consequences of requiring repeat naloxone dosing may be less important. One study presented at the FDA meeting found that survival rates were very similar following IN administration of one, two, or ≥three doses of IN naloxone (93% to 95% in all groups).^56,57^ The studies were not designed to determine the specific opioids involved in the overdose episodes.

Regarding route of administration, our finding regarding the effectiveness of higher concentration IN naloxone when administered by EMS personnel appears consistent with some data presented at the FDA meeting. The retrospective survey of first responder administration of off-label IN naloxone (2 mg/2 mL) for suspected opioid overdose in New York and New Jersey reported high rates of survival (93% to 97%). A prior uncontrolled study found that^80^ approximately 83 percent of patients responded to IN naloxone (2 mg/2 mL) administered by EMS personnel.^81^ For the recently approved naloxone auto-injector (0.4 mg), post-marketing surveillance data indicate very few spontaneously reported adverse events related to drug ineffectiveness (4 cases, or 0.0015%); these data include cases of auto-injector use in community settings by laypeople.^59^

Unpublished data presented at the FDA meeting have not undergone independent peer review. In addition, some studies were funded by industry.

## Applicability

Several factors limited the applicability of our findings. A key applicability limitation is that all studies meeting inclusion criteria evaluated older and/or off-label formulations of naloxone. No study evaluated the FDA-approved naloxone auto-injector for IM administration, at either a dose of 0.4 mg or the very recently approved 2 mg dose. Therefore, studies that involved IM naloxone were unable to assess potential benefits of the auto-injector with regard to ease of use, higher plasma concentrations compared with the same dose administered without the auto-injector, or decreased risk of needle-stick, or evaluate effects of the higher (2 mg) dose. Similarly, no study evaluated the recently FDA-approved formulations of highly-concentrated IN naloxone. One trial evaluated IN naloxone at a concentration lower (2 mg/5 mL) than used off-label in the United States (2 mg/2 mL)^62^ and another trial evaluated IN naloxone at a concentration (2 mg/1 mL) that appears to have been formulated specifically for that study, and is not available in any product otherwise.^63^ The concentration of naloxone in FDA-approved formulations (4 mg/0.1 mL or the very recently approved 2 mg/0.1 mL) are substantially higher than the typical concentration used off-label for IN administration (2 mg/2 mL), requiring a lower volume in a system designed to deliver an accurate dose. Studies indicate very high usability rates (>90%) with the auto-injector and IN reformulation compared with older/off-label devices, even without prior training.^78,82^

The settings of some studies may also limit applicability to use of naloxone in U.S. field settings by EMS personnel. All of the RCTs that compared naloxone routes of administration were conducted in non-U.S. settings (Australia and Iran), where EMS and ED management of opioid overdose, and characteristics of opioid overdose may differ from the United States. For example, in the Iranian trial, a high proportion of opioid overdoses was related to use of opium.^64^

Applicability was also limited by the populations evaluated in the studies. In almost all studies, characteristics of the opioid overdose, such as the specific opioid involved (including whether it was a sustained-release/long-acting opioid), opioid dose, time since overdose, concomitant substances and drugs were not reported, and subgroup analyses were not reported. In addition, almost all studies were conducted before the recent increase in availability of and exposure to illicitly manufactured high potency synthetic opioids. In studies regarding patients who received naloxone for opioid overdose who were not transported to a health care facility, details regarding the characteristics of patients were limited. This poses a challenge for interpreting the results of these studies, because patients who refuse transport or are not transported for other reasons are likely to differ substantially from patients who are transported. One study reported that 100 percent of patients who were not transported to an ED had a Glasgow Coma Scale score of 14 or 15, compared with about 50 percent of patients who were transported, but did not compare outcomes in patients transported versus those not transported.^69^

## Implications for Clinical and Policy Decisionmaking

Although we found limited evidence to address the questions in our report, our findings have potential implications for clinical and policy decisionmaking. Regarding the route of administration, limited evidence suggests that higher concentration IN naloxone and IM naloxone may be similarly effective for field treatment of suspected overdose by EMS personnel. As noted previously, a factor complicating clinical and policy decisionmaking regarding the optimal route of administration is that no study included in this report has evaluated the recently FDA-approved naloxone auto-injectors or highly-concentrated formulations of IN naloxone. Assuming similar effectiveness, factors that might inform decisions regarding naloxone route of administration include ease of use, safety concerns (e.g., reduced risk of needle stick, reduced risk of agitation post-administration), and pharmacokinetics. Data indicate very high usability for both the naloxone auto-injector and reformulated IN naloxone;^78,82^ in fact, these products were designed to be used by laypeople with no medical training, suggesting that they could be used by basic as well as more advanced levels of EMS providers. A high level of concern regarding potential exposure of EMS personnel to infections or high potency opioids due to needle stick injuries would seem to favor needleless routes of administration such as IN naloxone, though the auto-injector is designed to provide needle stick protection to the naloxone administrator. Other factors that might impact decisions regarding the route of administration include availability and costs for different formulations/delivery systems. In 2016, the price was $4,500 for the naloxone 0.4 mg auto-injector increased from $690 in 2014), $150.00 for IN naloxone 4 mg/0.1 ml (2 pack), $14 to $24 for 0.4 mg dose of naloxone 0.4 mg/mL and ~$40 for a 2 mg dose of naloxone (1 mg/mL).^83^ Therefore, the high costs of the new, easier-to-use formulations may represent a significant barrier to their uptake. Although IV administration of naloxone also remains an option, it appears to be on the decline, due to the need to attain IV access, which can be difficult in injection drug users and cause delays in administration. In addition, Basic Life Support EMS providers are generally not permitted to initiate IV therapy, limiting such personnel to naloxone administration via the IN or IM routes. The effective half-life of naloxone is longer for IM versus IV administration, which may be a factor in patients on high doses of opioids or those exposed to long-acting/extended-release or high potency opioids.

There was very little evidence to inform decisions regarding optimal dose of naloxone. An important current factor for informing decisions regarding naloxone dose is the increasing availability of high potency synthetic opioids, which may require higher naloxone doses to reverse. At the recent FDA meeting, the Advisory Committee voted by a slight majority to recommend an increase in the minimum dose of parenteral naloxone from 0.4 mg in devices approved for laypeople use.^84^ Potential trade-off with higher doses include a higher rate of successful opioid overdose versus a higher risk and severity of withdrawal. In addition to the discomfort that withdrawal causes in patients, it can also result in agitation, with potential for injury to patients or EMS personnel, as well as vomiting with the potential for aspiration. A factor that distinguishes administration of naloxone by laypeople from administration by EMS personnel is that EMS personnel are more likely to be able to provide adequate ventilatory support in cases in which initial doses of naloxone are too low, potentially decreasing the risk of inadequately treated overdose due to lower initial doses in EMS settings. Recently, the FDA approved a 2 mg auto-injector for IM administration, which is thought to be pharmacokinetically similar to the 4 mg/0.1 mL IN dose.^85^ Even more recently, the FDA approved a 2 mg/0.1 mL formulation of IN naloxone, underscoring ongoing uncertainty regarding optimal dosing. Factors that could inform the use of higher dose naloxone in EMS settings is the prevalence of overdoses associated with high potency opioids or the proportion of patients requiring repeated doses.

We found no evidence with which to guide timing of repeat dosing or whether to dose to full consciousness or until having adequate respirations. The optimum timing of repeat dosing is likely to depend on the ability of EMS personnel to provide adequate ventilatory support in patients who do not respond to initial doses, the time required for naloxone to reach plasma concentrations sufficient to reverse overdose symptoms (which varies according to route of administration and dose), and the likelihood of precipitating acute withdrawal with repeat doses. However, EMS personnel vary with regard to their ability to provide ventilatory support, and may not have uniform access to tools to assess for adequate ventilation. With regard to whether it is necessary to dose patients until they reach full consciousness, trade-offs to consider include the likelihood of precipitating withdrawal or complications related to assisted ventilation (e.g., gastric insufflation with risk of emesis and aspiration) versus a reduction in risk of recurrence of opioid overdose symptoms or complications related to decreased level of consciousness (e.g., aspiration, upper airway obstruction). In addition, negative pressure ventilation (i.e., patients breathing on their own) is more likely to achieve adequate oxygenation than manual positive pressure ventilation. In overdoses involving opioids plus nonopioid substances and drugs, attempting to dose naloxone to achieve full consciousness may be futile and cause more severe withdrawal and agitation.

With regard to need for hospital transport following successful treatment of opioid overdose, very limited evidence suggests a low likelihood of serious adverse outcomes in patients who refuse hospital transport. It is not known whether hospital transport is associated with beneficial effects on outcomes such as linkage to treatment for opioid use disorder or decreased risk of subsequent opioid overdose episodes. It is likely that patients who weren’t transported were at low risk of adverse outcomes compared to those who were transported; studies were not designed to address comparative benefits and harms of hospital transport versus nontransport in patients with similar characteristics. Factors that may impact policies regarding need for transport include whether patients are dosed until they are fully conscious, the presence of comorbidities, involvement of other substances in the overdose, likelihood of recurrence of opioid overdose symptoms (e.g., in patients exposed to long-acting opioids), the ability of EMS personnel to identify patients at high risk for recurrence for opioid overdose symptoms or other complications, and medico-legal considerations, such as mandated transport in some communities.

Policy decisions related to expansion of the scope of EMS practice for basic life support EMS personnel to include administration of naloxone could be informed by the successful use of naloxone by non-EMS first responders and laypeople.^86–89^ The FDA is supporting efforts to make naloxone available over the counter, though no over-the-counter naloxone preparation is currently FDA-approved.^90^ In a number of states, naloxone is already available without an individual prescription, through standing orders or collaborative practice agreements with prescribers.^91,92^

## Limitations of the Systematic Review Process

Our review had potential limitations. We limited inclusion to English language articles, which could result in language bias. However, we did not identify any foreign language studies that appeared to meet inclusion criteria in our literature searches or in reference lists. Because there were few RCTs addressing the Key Questions, we included observational studies, which are more susceptible to bias, even when designed and conducted well. The observational studies included in this report were assessed as having high risk of bias due to serious methodological shortcomings, including failure to adjust for potential confounders or failure to include a control group, and were of limited usefulness for reaching more reliable conclusions. Because of the small number of studies conducted in field settings, we modified the protocol to include studies performed in the ED setting; this resulted in inclusion of only one additional trial.^64^ Although we broadened inclusion criteria to include lay professionals (e.g., police, non-EMS firefighters, and others) administering naloxone in field settings, no additional studies in which naloxone was administered by such professionals met inclusion criteria.

We attempted to identify potentially relevant unpublished studies through searches on clinicaltrials.gov, reviewing materials presented at a recent FDA meeting on naloxone dosing, sending requests to manufacturers of naloxone for Scientific Information Packets, and contacting federal agencies that have funded naloxone research. Although we did not identify additional studies that met inclusion criteria, it is possible that some unpublished studies remained unidentified. Due to the small number of studies, clinical heterogeneity, and methodological limitations, we did not attempt meta-analysis.

## Limitations of the Evidence Base

The major limitation of the evidence base is the lack of evidence to adequately address the Key Questions. Importantly, no study evaluated the recently FDA-approved auto-injectors or highly-concentrated IN reformulation. In addition, studies varied in how an adequate response to naloxone was defined, or did not define adequate response. No study evaluated health care utilization indicators and longer-term follow-up data was generally lacking. Studies of outcomes in patients who were not transported to a health care facility following successful treatment of overdose with naloxone did not have a comparison group of similar patients who were transported, making interpretation of findings a challenge. Further, these studies focused on immediate or short-term risk of serious harms such as death, and were not designed to assess other potential outcomes impacted by transport to a health care facility, such as linkage to treatment for opioid use disorder or subsequent future overdose events.

## Research Recommendations

Opioid overdoses have increased dramatically, have potentially devastating consequences, and are potentially reversible. Additional research is urgently needed to optimize administration of naloxone by EMS personnel via parenteral versus needleless routes. Key areas for future research and methodological considerations include the following:

- Randomized trials in U.S. field settings that compare the FDA-approved IN formulation of highly-concentrated, low-volume naloxone versus the IM auto-injector would be very helpful for understanding the relative benefits and harms of alternative routes of administration.
- Investigators designing future RCTs on dose or route of administration might consider whether to utilize a blinded design, in order to reduce risk of bias in ascertainment of outcomes or management of opioid overdose. However, such a study design could pose ethical and logistical challenges in field settings. For example, an RCT would require an exception to informed consent, since patients would not be able to provide consent, or would need to provide consent prior to an overdose event occurring. The latter would also pose a challenge since the at-risk population includes injection drug users, who can be difficult to reach and engage.
- In addition to studies of naloxone administration by EMS personnel, studies of naloxone administration by non-EMS first responders and laypeople with limited medical training could also be informative for understanding optimal use of naloxone by Basic Life Support personnel.
- Studies are needed to compare effects of the FDA-approved versions of IN and IM naloxone versus non-FDA approved versions, which remain commonly used in clinical practice; a field trial in which ALS EMS providers in New York state used IN naloxone 2 mg/2 mL and 4 mg/0.1 mL on alternating weeks is ongoing.^93^
- Studies that compare different doses (e.g., 0.4 vs. 2 mg doses of the IM auto-injector) are needed to determine the optimal dose for various routes of administration.
- Ideally, studies would include (to the extent possible) information regarding the opioids involved in the overdoses and other patient factors, and perform subgroup analyses to evaluate for potential differential effects based on these factors. Of particular interest is whether overdoses related to illicit fentanyl or fentanyl analogues require higher doses of naloxone.
- Studies should also include information regarding the type of EMS personnel administering naloxone, in order to assess whether the level of training impacts benefits and harms or whether effects are similar across different levels of EMS training.
- Studies should evaluate benefits as well as important harms, including withdrawal, agitation, and injury (to the patient or EMS personnel), as well as risk of exposure of EMS personnel to high potency opioids, in order to provide balanced assessments of the trade-offs involved.
- Although IN and IM administration appears to be of greatest interest currently, studies could also address comparisons involving IV or SC administration (in some cases whether someone receives an IM or SC injection may not be clear since this depends on the length of the needle and the thickness of the subcutaneous layer in the patient receiving the injection), for which data are extremely sparse.
- Future research could leverage existing EMS data registries with naloxone administration data, which are available from a number of local and state agencies. In addition, the NHTSA funded National Emergency Medical Services Information System (NEMSIS) contains data from EMS agencies across the United States.^94^
- Although current registries provide important descriptive and epidemiological information regarding naloxone administration by EMS personnel, they were not designed to address the comparative effectiveness questions in this review. For example, although a study of national EMS registry data that found that the proportion of overdose episodes requiring repeat doses of naloxone increased from 14 to 18 percent from 2012 to 2015, it was not designed to determine the optimal interval for repeat dosing or if the observed increase was related to greater risk of failure of initial naloxone dosing, variability in thresholds for repeat dosing, changes in dosing protocols, or other factors.^50^ Ideally, registry studies should include information about the dose, formulation, and route of administration of naloxone; opioid involved in exposure; training of EMS personnel administering naloxone; clinical response to initial and repeat dosing; protocol for initial and repeat naloxone dosing; and clinical outcomes, including response rates using predefined criteria, risk for recurrence of opioid overdose symptoms, and adverse outcomes.
- Importantly, registry and other observational studies should utilize methods to reduce risk of confounding and bias, including statistical adjustment or matching. For example, studies on clinical outcomes associated with single versus multiple doses of naloxone should account for severity of overdose symptoms prior to initial naloxone administration to reduce confounding by indication.
- Research is needed to determine optimal timing of repeat dosing and strength of dose(s) as well as whether to dose until fully conscious or until patients have adequate respirations (e.g., in situations in which adequate ventilatory support is not available). For studies addressing either of these questions, the protocols used for naloxone dosing will need to be clearly defined, including indications for additional “rescue” dosing. Registry and pilot studies would be helpful for informing appropriate naloxone dosing protocols, to aid in the design of future clinical trials.
- For comparing effects of nontransport following successful treatment of opioid overdose with naloxone, RCTs may not be logistically or ethically feasible. However, comparative observational studies would better inform this question than the noncomparative studies currently available. For example, studies could identify patients who are not transported to a hospital and match them with patients who are transported, based on factors such as age, sex, suspected opioid involved in overdose, response to naloxone (e.g., based on Glasgow Coma Scale score), other substances and drugs involved in overdose, or other factors. Studies should supplement use of medical examiner and hospital records to identify outcomes with formal followup assessments, and evaluate outcomes such as linkage to treatment for opioid use disorder and risk of future overdose episodes, in addition to serious adverse outcomes associated with the current overdose episode, such as death and any serious complications.
- Future research could address alternative routes of administration, such as needleless administration via mask nebulization,^95^ sublingually, or buccally.^21^ An important drawback of nebulized naloxone is potential ineffectiveness if the subject is not breathing. Potential challenges in sublingual and buccal administration are that they require access to the mouth and could be impacted by vomiting or swallowing; sublingual administration in addition requires positioning under the tongue, which may be difficult.^21^ Endotracheal administration is a needleless route that is no longer recommended,^96^ since the intubated patient should be receiving adequate ventilatory support and naloxone administration with successful reversal of overdose could result in severe agitation; furthermore, endotracheal absorption is inconsistent.
- Given the changing epidemiology of opioid overdoses, particularly with regard to overdoses related to fentanyl and related substances, future systematic reviews on this topic may be warranted in the near future to incorporate new studies.