# Conclusions

Low-strength evidence suggested that intranasal (IN) naloxone at a dose of 2 mg and concentration of 2 mg/1 mL is similar in efficacy to intramuscular (IM) naloxone at a dose of 2 mg, with no difference in adverse events. Research is needed on the comparative effectiveness of the U.S. Food and Drug Administration–approved naloxone auto-injectors and highly-concentrated IN naloxone formulations, different doses, and dosing strategies. Uncontrolled studies suggest that nontransport of patients following successful naloxone reversal of overdose is associated with a low rate of serious harms, but patients were probably at low risk for such events, and no study evaluated risk of transport versus nontransport.