# Appendix F Strength of Evidence

Table F-1 Strength of evidence

Key Question Outcome | Study Design Number of Studies (N) | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence
1. For patients with confirmed or suspected opioid overdose, what is the comparative benefit and harms of out-of-hospital administration of naloxone by EMS personnel using intravenous, intramuscular, subcutaneous, and intranasal routes of administration?
IN vs. IM Naloxone | 2 RCTs | Moderate | Inconsistent | Direct | Precise | Not detected | Low
IN vs. IV Naloxone | 1 RCT | Moderate | Unable to assess | Indirect | Precise | Not detected | Insufficient
IN vs. IV Naloxone | 2 cohort studies | High | Consistent | Direct | Precise | Not detected | Insufficient
1a. For patients with confirmed or suspected opioid overdose who receive naloxone in the out-of-hospital setting from EMS personnel, what are the comparative benefits and harms of different intravenous, intramuscular, subcutaneous, or intranasal, or intramuscular doses of naloxone? | No studies | -- | -- | -- | -- | -- | Insufficient
2. For patients with confirmed or suspected opioid overdose in out-of-hospital settings, what is the comparative benefit and harms of titration of naloxone administered by EMS personnel until the patient resumes sufficient spontaneous respiratory effort versus until the patient regains consciousness? | No studies | -- | -- | -- | -- | -- | Insufficient
3. For patients with confirmed or suspected opioid overdose in out-of-hospital settings treated with multiple doses of naloxone (including patients who do not improve after an initial dose of intranasal naloxone), what are the effects on benefits and harms of differences in timing of repeat dosing? | No studies | -- | -- | -- | -- | -- | Insufficient
4. For patients with confirmed or suspected opioid overdose in out-of-hospital settings who regain sufficient spontaneous respiratory effort and are alert and oriented after naloxone administration by EMS personnel, what are the benefits and harms of transporting patients to a health care facility versus nontransport?
Death, serious adverse events | 6 uncontrolled studies | High | Consistent | Direct | Precise | Not detected | Insufficient

EMS = emergency medical services; IM = intramuscular; IN = intranasal; RCT = randomized controlled trial