# Appendix D Data Abstraction

Table D-1 Key Question 1: Data abstraction of randomized controlled trials

Author, Year | Key Question | Country Setting Study Years | Eligibility Criteria | Intervention Characteristics (experimental vs. control groups: dose, duration and route of treatment; training/background of personnel administering drug; timing of administration) | Number of Treatment and Control Subjects (randomized, analyzed, lost to followup) | Population Characteristics (Age, sex, race, psychiatric comorbidities, prior overdose episodes) | Exposure Characteristics (type of opioid involve, dose of opioid involved, other contributing drugs, time since overdose) | Results | Duration of Followup | Adverse Events | Funding Source | Comments
Kerr, 2009 | KQ1 | Australia Prehospital ambulance service 2006–2008 | Patients requiring treatment for suspected opioid overdose: Altered conscious state (pinpoint pupils, respirations <10/minute) GCS ≤12 No major facial trauma, blocked nasal passages, or epistaxis | A: Naloxone intranasal 2 mg/1 ml with mucosal atomization device, 1 mg each nostril (n=83) B: Naloxone intramuscular 2 mg/5 ml ‘min-i-jet’ preparation × 1 (n=89) Paramedics administered naloxone. Both groups received naloxone intramuscular 0.8 mg for failure to respond after 10 minutes | Randomized: 178 (88 vs. 90) Analyzed: 169 (83 vs. 89) Lost to followup: None reported | Age: 31 vs. 32 years Male: 77% vs. 71% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported | Type of opioid: Not reported Dose of opioid: Not reported Concomitant alcohol: 30% vs. 35% Concomitant drugs: 22% vs. 9.0% (p<0.05) Concomitant alcohol ± drugs: 47% vs. 37% Time since overdose: Not reported | A vs. B Adequate response at ≤10 minutes (respiratory rate ≥10 per minute and/or GCS ≥13): 72% (60/83) vs. 78% (69/89), difference −5.2% (95% CI −18 to 7.7%); adjusted OR 0.7 (95% CI 0.3 to 1.5) Rescue naloxone for inadequate response: 18% (15/83) vs. 4.5% (4/89), difference 14% (95% 4.2 to 23%); adjusted OR 4.8 (95% CI 1.4 to 16) Hospitalization: 29% (24/83) vs. 26% (23/89); difference 3.1% (95% CI −10 to 16%); adjusted OR 1.3 (95% CI 0.6 to 2.7) Mean response time (minutes): 8.0 vs. 7.9, difference 0.1 (95% CI −1.3 to 1.5) | Out-of-hospital | Major adverse event: 1.2% (1/83) vs. 0% (0/89), RR 3.2 (95% CI 0.13 to 78) Minor adverse event: 19% (16/83) vs. 19% (17/89); difference 0.2% (−12 to 12%); adjusted OR 1.1 (95% CI 0.5 to 2.5) Agitation and/or violence: 6.0% (5/83) vs. 7.9% (7/89), RR 0.77 (95% CI 0.25 to 2.3) Nausea and/or vomiting: 8.4% (7/83) vs. 7.9% (7/89), RR 1.07 (95% CI 0.39 to 2.9) Headache: 4.8% (4/83) vs. 3.3% (3/89), RR 1.4 (95% CI 0.33 to 6.2) Needlestick injuries: None | Drug Policy and Services, Department of Human Services, Melbourne, Victoria, Australia | Adjusted risk estimates adjusted for age, gender, and suspected concomitant alcohol and/or drugs; results similar to unadjusted Site of IM administration not specified, difference between the IN and IM arms with regard to rescue naloxone despite no response at 10 minutes, possible bias favoring more use of rescue in IN arm. Unblinded study. No concerns about randomization or concealment.
Kelly, 2005 | KQ1 | Australia Ambulance service 2002–2003 | Suspected opiate overdose: ≤10 respirations per minute Not rousable | A: Naloxone intranasal 2 mg/5 mL with mucosal atomization device, 1 mg each nostril (n=84) B: Naloxone intramuscular 2 mg × 1 (preparation not described) (n=71) Paramedics administered naloxone. Both groups received naloxone intramuscular 0.8 mg for failure to respond after 8 minutes | Randomized: 182 (98 vs. 84) Analyzed: 155 (84 vs. 71) Lost to followup: None reported; 4 vs. 8 with incomplete data. | Age: 28 vs. 30 years Male: 70% vs. 73% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported | Type of opioid: Not reported Dose of opioid: Not reported Suspicion of concomitant drugs/alcohol: 37% vs. 28% Time since overdose: Not reported | A vs. B Spontaneous respirations within 8 minutes: 63% (53/84) vs. 82% (58/71), OR 0.38 (95% CI 0.18 to 0.81) Patients requiring rescue naloxone after 8 minutes: 26% (22/84) vs. 13% (9/71), OR 2.4 (95% CI 1.0 to 5.7) Glasgow Coma Score >11 at 8 minutes: 57% (48/84) vs. 72% (51/71), OR 0.52 (95% CI 0.27 to 1.0) Transported to hospital: 17% (14/84) vs. 21% (15/71), OR 0.75, 95% CI 0.33 to 1.68 Time to respirations >10/minute (minutes): 8 vs. 6 minutes, p=0.006 Time to GCS score >11: p=0.38, data not reported | Out-of-hospital | Major adverse event: 0% (0/84) vs. 0% (0/71) Minor adverse event: 12% (10/84) vs. 21% (15/71), RR 0.56 (95% CI 0.27 to 1.18) Agitation and/or irritation: 2.4% (2/84) vs. 14% (10/71); RR 0.19 (95% CI 0.04 to 0.83) Nausea and/or vomiting: 7.1% (6/84) vs. 5.6% (4/71), RR 1.3 (95% CI 0.37 to 4.3) Headache: 0% (0/84) vs. 2.8% (2/71), RR 0.17 (95% CI 0.008 to 3.5) Tremor: 1.2% (1/84) vs. 1.4% (1/71), RR 0.85 (95% CI 0.05 to 13) Sweating: 1.2% (1/84) vs. 0% (0/71), RR 2.5 (95% CI 0.11 to 61) | William Buckland Foundation | Site of IM administration not specified, difference between the IN and IM arms with regard to rescue naloxone despite no response at 8 minutes, possible bias favoring more use of rescue in IN arm. Unblinded study. No concerns about randomization or concealment. Same formulation used in both groups 5 mg/2 ml. Sample size predetermined to be 166 for 60 second difference but mITT analysis had 155 cases. GCS and need for rescue nearly achieved statistical significance.
Sabzghabaee, 2014 | KQ1 | Iran Emergency Department 2007 | Age 15–50 years Suspected opioid overdose: Myotic pupils Loss of consciousness with or without respiratory depression | A: Naloxone intranasal 0.4 mg in 2 mL B: Naloxone intravenous 0.4 mg All patients who failed to respond within 5 minutes were given a further 0.4mg naloxone by the same administration route as the first dose | Randomized: 100 (50 vs. 50) Analyzed: Not reported Lost to followup: Not reported | Age: 30 vs. 33 years Male: 78% vs. 74% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported | Type of opioid: Diphenoxylate 0 vs. 8% Crack (in Iran Crack contains heroin with other opiates): 4% vs. 0 Methadone: 16% vs. 20% Heroin: 28% vs. 24% Opium: 44% vs. 48% Dose involved: Not reported Concomitant drugs: Not reported Time since overdose: Not reported | A vs. B: Systolic blood pressure: 106 ±14.7 vs. 112±9.6, p=0.18 Diastolic blood pressure: 78±7.1 vs. 77±4.5, p=0.18 Heart rate (per minute): 90±8.3 vs. 97±12.9, p=0.003 Respirator rate (per minute): 18±2.4 vs. 19±2.8, p=0.17 Glasgow Coma Scale: 14.3±0.73 vs. 13.2±1.5, p<0.001 Length of hospital stay (days): 1.53±0.16 vs. 1.2±0.15, p=0.15 | Upon hospital discharge | A vs. B Agitation: 0 vs. 12 | University support | The study does not report number of excluded patients, but states that patients failing to respond to the first 0.4 mg naloxone with an increased level of consciousness or a reversal of respiratory depression were excluded from the study.

CI = confidence interval; GCS = Glasgow Coma Scale; IM = intramuscular; IN = intranasal; KQ = Key Question; mITT = modified intention to treat; OR = odds ratio; RR = relative risk

Table D-2 Key Question 1: Data abstraction of observational studies

Author, Year Study Design | Key Question | Country Setting Study Years | Eligibility Criteria | Intervention Characteristics by Comparison Group (dose, duration and route of treatment; training/background of personnel administering drug; timing of administration) | Screened Eligible Enrolled Analyzed Loss to Followup | Population Characteristics (age, sex, race, psychiatric comorbidities, prior overdose episodes, receipt of out-of-hospital naloxone, response to out-of-hospital naloxone) | Exposure Characteristics (type of opioid involve, dose of opioid involved, other contributing drugs, time since overdose, naloxone dosing) | Method for Assigning Exposures | Method For Assessing Outcomes and Confounders | Duration of Followup | Adjusted Variables For Statistical Analysis | Results | Funding Source | Comments
Merlin, 2010 Retrospective cohort | KQ1 | United States Out-of-hospital 2005–2007 | Opioid intoxication determined by at least one of the following: Patient admission of illegal or nontherapeutic opioid use; Witness testimony; Evidence of opioid use observed by paramedics; Positive urine toxicologic screen for opioids Excluded patients with cardiac arrest, intubation before naloxone administration, sedation by paramedics before naloxone administration | A: Intravenous naloxone between 0.4 and 2.0 mg (n=55) B: Intranasal naloxone at 1 mg per nostril at the discretion of the paramedics (n=38) Naloxone administered by Advanced Life Support personnel | Screened: 344 Eligible: 96 Enrolled: 96 Analyzed: 93 (55 vs. 38) Lost to followup: 0 | Age: 42 vs. 38 years Male: 67% vs. 61% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 100% vs. 100% | Type of opioid: Not reported Dose of opioid: Not reported Other contributing drugs: 58% vs. 34%, p=0.02 Time since overdose: Not reported Naloxone dosing, mean: 1.71 mg vs. 1.95 mg, p=0.01 (likely due to IV titration to effect from 0.4 to 2 mg and IN naloxone 2 mg given as 1 mg in each nostril) | Advance Life Support unit record review | ALS and hospital records for outcomes, confounders not assessed | Hospital discharge | No adjustment performed | A vs. B: Median change in breaths per minute from baseline: 6 vs. 4, difference 2 (95% CI −0.001 to 5), p=0.08 Median change in Glasgow Coma Scale from baseline: 4 vs. 3, difference 1 (95% CI −0.001 to 3), p=0.19 | No grants or financial support | Only ALS personnel may administer naloxone in this site. Median dose in the both groups was 2 mg. Mean was slightly different as noted. Formulation not specified. Complicated analysis suspect related to retrospective study design. Study done in New Jersey, NJ, USA.
Robertson, 2009 Retrospective cohort | KQ1 | United States Out-of-hospital 2003–2004 | Patients treated with naloxone for suspected opioid overdose: clinically suspected of opiate intoxication and ≤8 breaths per minute | A: Intravenous naloxone as first line treatment, dose protocol not reported (n=104) B: Intranasal naloxone as first line treatment, 2 mg (1 mg per nostril) using mucosal atomizer device (n=50) EMS administered naloxone, training not specified Patients in first year were treated with intravenous naloxone and patients in last 5 months were treated with intranasal naloxone. | Screened: Not reported Eligible: 154 Enrolled: 154 Analyzed: 154 (104 vs. 50) Lost to followup: 0 | Age: 44 vs. 41 years Male: 60% vs. 71% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 100% vs. 100% | Type of opioid: Not reported Dose of opioid: Not reported Other contributing drugs: Not reported Time since overdose: Not reported Naloxone dosing: Not reported | EMS records | EMS records, confounders not assessed | End of EMS contact | No adjustment performed | A vs. B: Positive clinical response (increase in respirations of at least 6 breaths/minute or in GCS of at least 6 points): 58/104 (56%) vs. 33/50 (66%), p=0.3) Time from naloxone administration to effect: 8.1 vs. 12.9 minutes, p=0.02 Time from patient contact to effect: 20.7 vs. 20.3 minutes, p=0.9 Second dose of naloxone given: 19/104 (18%) vs. 17/50 (34%), p=0.05 | Not reported | EMS records in this system were all electronic. Definition of clinical response increase in RR of 6 or GCS of 6. There were 3 IN patients that received rescue naloxone via an alternate route. Although retrospective, looked at a protocol change from IV as first line to IN as first line. Similar in a way to Wanger which was prospective. Study done in Fresno, CA, USA.
Sporer, 1996 Retrospective cohort | KQ1 | United States Out-of-hospital 1993 | Presumed opioid overdose required at least 3 of the following: Circumstantial evidence of parenteral drug use Respiratory rate <6 per minute Cyanosis prior to oxygenation Glasgow Coma Scale score ≤12 Pinpoint pupils | A: Intravenous naloxone 2 mg B: Intramuscular naloxone 2 mg Repeat dose given if no response is seen in 1–2 minutes | Screened: 1,856 Eligible: 609 Analyzed: 609 Lost to followup: Not reported, but 166 patients not transported to the hospital do not have clinical outcomes | Not reported by treatment group Age: <20: 3%; 20–29: 15%; 30–39: 40%; 40–49: 34%; >50: 9% Male: 78% Race: Unknown: 51%; White: 28%; Black: 14%; Hispanic: 6%; Asian: 1% Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 99.8% | Type of opioid: IV opioid: 58%; Unknown: 40% Dose of opioid: Not reported Other contributing drugs: Not reported Time since overdose: Not reported Naloxone dosing: 0.4mg: 1%; 1 mg: 6%; 2 mg: 58%; 3–4 mg: 28%; >4 mg: 7% | EMS, hospital and medical examiner records | EMS records, confounders not assessed | Not reported | No adjustment performed | A vs. B: Response rate (GCS ≥14 and RR≥10/minute within 5 minutes of naloxone administration): 488/518 (94%) vs. 69/73 (95%), RR 1.0 (95% CI 0.94 to 1.1) | CDC grant | Data on hospital transport, but does not include data on those not transported. Study done in San Francisco, CA, USA. Race data unknown in a large number of patients in the study. Response defined as improvement to a GCS ≥14 and RR +1-within 5 minutes of naloxone administration. 52 patients received both IM and IV with a response rate of 98%. Not clear why this group got both, authors presume use of a larger dose of opioid. Most common routes of use for opioid were IV and unknown. Formulation of naloxone not specified but presumably same one used for IV and IM administration.
Wanger, 1998 Prospective cohort with historical control | KQ1 | Canada Out-of-hospital IV naloxone: June 1–30, 1996 SQ naloxone: July 1–September 1, 1996 | Out-of-hospital patients with presumed opioid overdose who received naloxone: Decreased consciousness History suggestive of opioid use Respiratory rate <10 breaths per minute Excluded patients in cardiac arrest | A: Subcutaneous naloxone 0.8 mg into upper arm or thigh, with 0.4 mg IV available if no improvement after 5 minutes (n=139) B: Intravenous naloxone 0.4 mg, with an additional 0.4 mg available if no improvement after 5 minutes (n=83) Naloxone administered by British Columbia Ambulance Service attendants (basic life support, IV and advanced life support levels) | Screened: Not reported Eligible: Not reported Enrolled: 222 Analyzed: 196 (122 vs. 74) Lost to followup: Not reported | A vs. B Age: 33 vs. 36 years Male: 80% vs. 78% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Receipt of out-of-hospital naloxone: 100% | Type of opioid: Not reported Dose of opioid: Not reported Other contributing drugs: Not reported Time since overdose: Not reported Naloxone dosing: Patients requiring at least 2 doses of naloxone prior to hospital arrival: 15% vs. 35% | Ambulance service records | Ambulance service records, confounders not assessed | Hospital discharge | No adjustment performed | Time interval from drug administration to respiratory rate ≥10 breaths per minute: 5.5 vs. 3.8 minutes, p=0.001 Time interval from arrival at patient’s side to respiratory rate ≥10 breaths per minute: 9.6 vs. 9.3 minutes, p=0.67 Proportion requiring multiple naloxone doses: 15% (18/122) vs. 35% (26/74), RR 0.42 (95% CI 0.25 to 0.71) | Medical Research Council/University of British Columbia | No comment on formulation but presumably the same was use for IV and SC. The administration of medications is usually restricted to paramedics but this was not specified clearly in the paper. Similar improvement in RR related to time required to establish IV. Study conducted in city of Vancouver, BC, Canada.

ALS = advance life support; CI = confidence interval; EMS = emergency medical services; GCS = Glasgow Coma Scale; IN = intranasal; IV = intravenous; KQ = Key Question; RR = relative risk; SQ = subcutaneous

Table D-3 Key Question 4: Data abstraction of observational studies

Author, Year Study Design | Key Question | Country Setting Study Years | Eligibility Criteria | Intervention Characteristics by Comparison Group (dose, duration and route of treatment; training/background of personnel administering drug; timing of administration) | Screened Eligible Enrolled Analyzed Loss to Followup | Population Characteristics (age, sex, race, psychiatric comorbidities, prior overdose episodes, receipt of out-of-hospital naloxone, response to out-of-hospital naloxone) | Exposure Characteristics (type of opioid involve, dose of opioid involved, other contributing drugs, time since overdose, naloxone dosing) | Method for Assigning Exposures | Method For Assessing Outcomes and Confounders | Duration of Followup | Adjusted Variables For Statistical Analysis | Results | Funding Source | Comments
Boyd, 2006 Retrospective cohort | KQ4 Transport | Finland Out-of-hospital 1995–2000 | Patients with signs and symptoms of opioid overdose: Respirations <12 breaths/minute Peripheral oxygen saturation <90% without supplemental oxygen or <95% with oxygen Cyanosis on arrival of first responding unit GCS ≤8 and witnessed using heroin or with circumstantial evidence of drug use Excluded patients with cardiac arrest, polydrug or alcohol use, or use of opioids other than heroin | Refused transport to emergency department (n=84) | Screened: 269 Eligible: 162 Enrolled: 163 (79 vs. 84) Analyzed: 145 (61 vs. 84) Lost to followup: 18 (18 vs. 0) | Overall population characteristics (not reported by intervention group) Age: 26 years Male: 83% Race: Not reported Psychiatric comorbidities: Not reported Prior overdose episodes: Not reported Received out-of-hospital naloxone: 85% | Type of opioid: Heroin only Dose of opioid: IV: 43/145 (29.7%) Sniffed: 3/145 (2.2%) Smoked: 2/145 (1.4%) Unreported: 97/145 (66.9%) Other contributing drugs: None suspected Time since overdose: Not reported Naloxone dosing, not reported by comparison group: Naloxone dose ≤ 0.4mg: 87/123 (70.7%) Naloxone dose 0.4–0.8 mg: 36/123 (29.3%) Prehospital route of administration: IV: 46/123 (37.4%) IM/SQ: 35/123 (28.5%) IV + IM/SQ: 33/123 (26.8%) Not reported: 9/123 (7.3%) | EMS records | EMS and hospital records for outcomes; confounders not assessed | 12 hours for patients who refused transport | No adjustment performed | Recovery by ventilatory assistance alone: (9.5%) 8/84 Spontaneous recovery: (6.0%) 5/84 Life-threatening adverse event within 12 hours: 1/84 (1.19%, 95% CI 0.21–6.44%) | Not reported
Levine, 2016 Retrospective Cohort | KQ4 Transport | United States Out-of-hospital 2011–2013 | Patients who had a respiratory rate lower than 12 who received naloxone and who signed out against medical advice. Excluded patients who were transported to the hospital. | Refused transport to emergency department (n=205) | Screened = NR Eligible = 205 Enrolled = 205 Analyzed = 205 | Age 41 years (29–53) Male 87% Race = NR Psychiatric Comorbidities= NR Prior Overdoses = NR | Type of Opioid: Opioid toxicity Dose = NR Route = NR Other contributing drugs = NR Time since overdose = NR Naloxone dosing When a patient is suspected of opiate toxicity, there are standing orders permitting the paramedic to administer 0.8–2 mg of naloxone intramuscularly, or intranasally prior to establishing intravenous access. The dose can be repeated if needed. Exact Doses NR Route = NR per patient | EMS Records | EMS and medical examiners records for outcomes; confounders not assessed | 24 hours, 30 days and 6 months | No adjustment performed | Death within 24 hours: 1/205 (0.49%; 95% CI 0.09–2.71%) Additional deaths within 30 days: 2/205 (0.98%; 95% CI 0.27–3.49%) Additional deaths within 6 months: none | Not reported | Los Angeles Fire Department, LA, CA, USA. Very little data presented in this paper. Main difference is that in addition to name and DOB, they also used SSN when available to match EMS refusals of care following naloxone use with ME records. Extended time frame to 24 hours, 30 days and 6 months. Intentional overdose patients often provide false names and SSN and so this does not completely eliminate the matching challenges. Unlike prior papers they did find some matches. No details on dose or route of naloxone.
Rudolph, 2011 Retrospective cohort | KQ4 Transport | The Netherland Out-of-hospital 1994–2003 | Patients treated by physician-based medical emergency unit for opioid overdose and not transferred to hospital. Patients who were transported to hospital were excluded. | Not transported to hospital (n=2241) | Screened: 4762 Eligible: 2241 Enrolled: 2241 Analyzed: 2241 | Age, sex, race: Not reported Type of Opioid, Dose, Route: Not reported | Type of opioid: Not reported Dose of opioid: Not reported Other contributing drugs: Not reported Time since overdose: Not reported Naloxone dosing: Intravenous 0.8 mg, supplemented with 0.4 mg intramuscular or subqutaneous at physician’s discretion; naloxone titrated to effect. Exact doses not reported. | EMS and medical examiner records for outcomes | EMS and medical examiner records for outcomes | 48 hours | No adjustment performed | Death within 48 hours: 14/2241 (0.62%, 95% CI 0.37–1.04%); 3 likely rebound overdoses, 10 new overdose, 1 natural death | Not reported
Vilke, 1999 Retrospective Cohort | KQ4 Transport | United States Out-of-hospital 1996 | Patients who received naloxone and were released against medical advice. Patients who were transported were excluded. | Refused transport to emergency department(n=317) | Screened = 1714 Eligible = 317 Enrolled = 317 Analyzed = 317 | Age 37 Years (18–79) Male 82.7% Race = NR Psychiatric Comorbidities = NR Prior Overdoses = NR | Type of Opioid: Suspected heroin and opiate overdose Dose = NR Route = NR Other contributing drugs = NR Time since overdose = NR Naloxone Dosing Protocols give medics the authority to treat with 2 mg naloxone IV/IM or 4 mg via endotracheal tube and may repeat the dose if no response. Dose = 59 (18.6%) single dose Route = 41(69.5%) IV 18(30.5%) IM Two Doses = 249 (78.6%) IV- IM = 180 IM - IV = 28 IM - IM = 11 IV - IV = 30 Three Doses = 9 (2.8%) IV-IV-IM = 7 IM-IM-IM = 1 IV-IM-IM = 1 | EMS Records | EMS and medical examiners records for outcomes; confounders not assessed | 12 hours | No adjustment performed | Death within 12 hours: 0/317 (95% CI: 0% to 1.2%) | Not reported | Includes patients from Vilke 2003 below San Diego County USA, EMS Database queried for AMA patients (5702) and field Naloxone (1714). Combined group was 317. ME database looked at for morphine related deaths. These 2 then cross referenced to determine death within 12 hours of treatment by EMS. Majority of cases got 2 doses (2 mg per dose) = 249. In most of these cases the sequence was 2 mg IV followed by 2 mg IM. Important in that the IM has a potentially longer effective half-life designed to provide additional protection against the recurrent respiratory depression.
Vilke, 2003 Retrospective Cohort | KQ4 Transport | United States Out-of-hospital 1996–2000 | Patients who received naloxone and were released AMA. Patients who were transported were excluded. | Refused transport to emergency department (n=998) | Screened = 8366 Eligible = 998 Enrolled = 998 Analyzed = 998 | Age 37.7 years (16–83) Male 83.8% Race = NR Psychiatric Comorbidities = NR Prior Overdoses = NR | Type of Opioid: Suspected heroin and opiate overdose Dose = NR Route = NR Other contributing drugs = NR Time since overdose = NR Naloxone Dosing Protocols give medics the authority to treat with 2 mg naloxone IV/IM or 4 mg via endotracheal tube and may repeat the dose if no response. Dose = 260 (26.1%) single dose Route = 179 (68.6%) IV 80(30.8%) IM Two Doses = 714 (71.5%) IV- IM = 552 IM - IV = 40 IM - IM = 47 IV - IV = 74 IM -? = 1 Three Doses = 24 (2.4%) IV-IV-IM = 16 IM-IM-IM = 1 IV-IM-IM = 3 IV-IV-IV = 2 IM-IV-IM = 1 IM-IV-IV = 1 | EMS Records | EMS and medical examiners records for outcomes; confounders not assessed | 12 hours | No adjustment performed | Death within 12 hours: 0/998 (95% CI: 0% to 0.38%) | Not reported | Includes patients from Vilke 1996 above Databases from ME and EMS cross referenced again. No cases found with death within 12 hours. There were 62 cases that required detailed review by 2 independent investigators but none were associated with prior EMS care. Of the 714 that received 2 doses, most got this in the IV-IM sequence (2 and 2). Location of IM administration and formulation not specified. Nearly identical to 1999 except for 1 vs. 5 years.
Wampler, 2011 Retrospective Cohort | KQ4 Transport | United States Out-of-hospital 2007–2009 | Patients who received naloxone | Refused transport to emergency department (n= 552) | Screened = 1700 Eligible = 592 (40 of the not transported died on scene) Enrolled = 552 Analyzed = 552 16 Individuals treated/refused more than once | Age 38± 15 years (13–91) Male 72% Race = NR Psychiatric Comorbidities = NR Prior Overdoses = NR | Type of opioid: Apparent or suspected narcotic overdose Dose = NR Route = NR Other contributing drugs = NR Time since overdose = NR Naloxone Dosing Dose and Route = 2 mg IM with an additional 2 mg IV infusion. A third dose (2 mg IM) is given with medical consultation | EMS Records | EMS and medical examiners records for outcomes; confounders not assessed | 48 hours, 30 days, and up to 372 days | No adjustment Performed | Deaths within 48 hours: 0/552 0%, 95% CI 0% to 0.69%) Deaths in field prior to transport: 40/552 (7.2%) None of the patients were examined within the 2 day endpoint. Deaths from 4–372 days: 9/592 (1.6%, 95% CI 0.5% to 2.7%) | Office of the Medical Director for the San Antonio Department of Emergency Medicine | All patients receiving Naloxone included. 20 month study period Nov 2997 to June 2009. 1,700 cases with naloxone administration. 592 nontransported. 40 of these were cardiac arrest that had field termination of resuscitation leaving 552 with naloxone administration and against medical advice release. Cross referenced EMS cases with ME cases. No deaths within 48 hours, 2 deaths within 30 days (one from heroin+cocaine OD on day 4, other from gunshot wound) During the 20 month study period (600 days or so), total of 9 deaths cross referenced. Average time from EMS presentation to ME office death was 170 days, range 4–372. Some of the nontransported cases were released to law enforcement officer as were some of the presumed deaths as outline in Table 1 and 2. Limitation as with other ME cross reference studies are that age and DOB can be inaccurate due to falsification. There dosing protocol is also aggressive 2 mg IM, followed by 2 mg IV and then if the patient agrees to it another 2 mg IM prior to signing against medical advice. Results like Vilke but looking at 48 hours, 30 day and then 20 months.

CI = confidence interval; DOB = date of birth; EMS = emergency medical services; GCS = Glasgow Coma Scale; IM = intramuscular; IV = intravenous; KQ = Key Question; ME = medical examiner; NR = not reported; OD = overdose; SQ = subcutaneous; SSN = social security number