# Appendix C Excluded Studies List

1 Alexander JL, Burton JH, Bradshaw JR, . Suspected opioid-related emergency medical services encounters in a rural state, 1997–2002. Prehosp Emerg Care. 2004 Oct–Dec;8(4):427–30. PMID: 15626007. Excluded for wrong outcome.15626007
2 Ashton H, Hassan Z. Best evidence topic report. Intranasal naloxone in suspected opioid overdose. Emerg Med J. 2006 Mar;23(3):221–3. PMID: 16498165. Excluded; not a study.16498165
3 Baca CT, Grant KJ. Take-home naloxone to reduce heroin death. Addiction. 2005 Dec;100(12):1823–31. PMID: 16367983. Excluded for wrong population.16367983
4 Barton ED, Colwell CB, Wolfe T, . Efficacy of intranasal naloxone as a needleless alternative for treatment of opioid overdose in the prehospital setting. J Emerg Med. 2005 Oct;29(3):265–71. PMID: 16183444. Excluded for wrong comparator.16183444
5 Barton ED, Ramos J, Colwell C, . Intranasal administration of naloxone by paramedics. Prehosp Emerg Care. 2002 Jan–Mar;6(1):54–8. PMID: 11789651. Excluded for wrong comparator.11789651
6 Bird SM, McAuley A, Perry S, . Effectiveness of Scotland’s national naloxone programme for reducing opioid-related deaths: a before (2006–10) versus after (2011–13) comparison. Addiction. 2016 May;111(5):883–91. doi: 10.1111/add.13265. PMID: 26642424. Excluded for wrong population.26642424
7 Breedvelt JJF, Tracey DK, Dickenson EC, . “Take home” naloxone: what does the evidence base tell us? Drugs Alcohol Today. 2015;15(2):67–75. doi: 10.1108/DAT-03-2015-0017. Excluded; not a study.
8 Buajordet I, Naess AC, Jacobsen D, . Adverse events after naloxone treatment of episodes of suspected acute opioid overdose. Eur J Emerg Med. 2004 Feb;11(1):19–23. PMID: 15167188. Excluded for wrong comparator.15167188
9 Cantwell K, Dietze P, Flander L. The relationship between naloxone dose and key patient variables in the treatment of non-fatal heroin overdose in the prehospital setting. Resuscitation. 2005 Jun;65(3):315–9. PMID: 15919568. Excluded for wrong comparator.15919568
10 Centers for Disease Control and Prevention. Increases in Fentanyl Drug Confiscations and Fentanyl-related Overdose Fatalities U.S. Department of Health & Human Services. Atlanta, GA: 2016. https://emergency.cdc.gov/han/han00384.asp Accessed December 19, 2016. Excluded; not a study.
11 Clark AK, Wilder CM, Winstanley EL. A systematic review of community opioid overdose prevention and naloxone distribution programs. J Addict Med. 2014 May–Jun;8(3):153–63. doi: 10.1097/ADM.0000000000000034. PMID: 24874759. Excluded for wrong population.24874759
12 Clarke A, Eustace A. External evaluation of the naloxone demonstration project: health service executive. Office HSEHNSI; 2016. Excluded for wrong population.
13 Clarke S, Dargan P. Intravenous bolus or infusion of naloxone in opioid overdose. Emerg Med J. 2002:249–50. PMID: 11971842. Excluded; not a study.11971842
14 Clarke S, Dargan P. Intravenous or intramuscular/subcutaneous naloxone in opioid overdose. Emerg Med J. 2002:249-. PMID: 11971843. Excluded; not a study.11971843
15 Clarke SF, Dargan PI, Jones AL. Naloxone in opioid poisoning: walking the tightrope. Emerg Med J. 2005 Sep;22(9):612–6. PMID: 16113176. Excluded; systematic review or meta-analysis used as a source document to identify individual studies.16113176
16 Creed C. Use of intranasal drug administration in the pre-hospital setting. J Adv Pract Oncol. 2012;4(12):699–704. Excluded; not a study.
17 Dixon P. Managing acute heroin overdose. Emerg Nurse. 2007 May;15(2):30–5. PMID: 17542332. Excluded; not a study.17542332
18 Etherington J, Christenson J, Innes G, . Is early discharge safe after naloxone reversal of presumed opioid overdose? CJEM. 2000 Jul;2(3):156–62. PMID: 17621393. Excluded for wrong comparator.17621393
19 Evans A, Snooks H, Russell D, . P69 How to stop drug users dying from an overdose: a systematic review of treatment and prevention interventions in the community. J Epidemiol Community Health. 2010;64:A60–A. Excluded; not a study.
20 Faul M, Lurie P, Kinsman J, . Multiple naloxone administrations among EMS Providers is increasing. In Press. Excluded for wrong outcome.
21 Fisher R, O’Donnell D, Ray B, . Police Officers Can Safely and Effectively Administer Intranasal Naloxone. Prehospital Emergency Care. 2016:1–6. Excluded for wrong outcome.
22 Gjersing L, Bretteville-Jensen AL. Are overdoses treated by ambulance services an opportunity for additional interventions? A prospective cohort study. Addiction. 2015;110(11):1767–74. doi: 10.1111/add.13026. PMID: 2618947. Excluded for wrong population.26118947
23 Glaser A, Arakaki D, Chan GM, . Randomised trial of intranasal versus intramuscular naloxone in prehospital treatment for suspected opioid overdose. Med J Aust. 2005 Apr 18;182(8):427; author reply, 9. PMID: 15850442. Excluded; not a study.15850442
24 Glass PS, Jhaveri RM, Smith LR. Comparison of potency and duration of action of nalmefene and naloxone. Anesth Analg. 1994 Mar;78(3):536–41. PMID: 8109774. Excluded for wrong population.8109774
25 Goicoechea C, Sanchez E, Cano C, . Analgesic activity and pharmacological characterization of N-[1-phenylpyrazol-3-yl]-N-[1-(2-phenethyl)-4-piperidyl] propenamide, a new opioid agonist acting peripherally. Eur J Pharmacol. 2008 Oct 24;595(1–3):22–9. doi: 10.1016/j.ejphar.2008.07.052. PMID: 18706410. Excluded for wrong intervention.18706410
26 Goldfrank L, Weisman RS, Errick JK, . A dosing nomogram for continuous infusion intravenous naloxone. Ann Emerg Med. 1986 May;15(5):566–70. PMID: 3963538. Excluded for wrong comparator.3963538
27 Hansen A. Norway tries naloxone in spray form to prevent deaths from drug overdose. BMJ. 2014;348:g1686. doi: 10.1136/bmj.g1686. PMID: 24555965. Excluded; not a study.24555965
28 Heyerdahl F, Hovda KE, Bjornaas MA, . Pre-hospital treatment of acute poisonings in Oslo. BMC Emerg. 2008;8:15. doi: 10.1186/1471-227X-8-15. PMID: 19025643. Excluded for wrong intervention.19025643
29 Horowitz Z. Subcutaneous naloxone: a less rude awakening? Acad Emerg Med. 1998 Apr;5(4):283–5. PMID: 9562188. Excluded; not a study.9562188
30 Hussain A, Kimura R, Huang CH. Nasal absorption of naloxone and buprenorphine in rats. Int J Pharm. 1984;21:233–7. Excluded for wrong population.
31 Ishiyama D, Jones J. Towards evidence based emergency medicine: best BETs from the Manchester Royal Infirmary. BET 3: Is nebulised naloxone effective in opioid overdose? Emerg Med J. 2013 Oct;30(10):860. doi: 10.1136/emermed-2013-203100.3. PMID: 24014692. Excluded; not a study.24014692
32 Kaplan JL, Marx JA, Calabro JJ, . Double-blind, randomized study of nalmefene and naloxone in emergency department patients with suspected narcotic overdose. Ann Emerg Med. 1999 Jul;34(1):42–50. PMID: 10381993. Excluded for wrong comparator.10381993
33 Kelly AM, Koutsogiannis Z. Intranasal naloxone for life threatening opioid toxicity. Emerg Med J. 2002 Jul;19(4):375. PMID: 12101174. Excluded; not a study.12101174
34 Kerr D, Dietze P, Kelly AM. Intranasal naloxone for the treatment of suspected heroin overdose. Addiction. 2008 Mar;103(3):379–86. doi: 10.1111/j.1360-0443.2007.02097.x. PMID: 18269360. Excluded; systematic review or meta-analysis used as a source document to identify individual studies.18269360
35 Kim D, Irwin KS, Khoshnood K. Expanded access to naloxone: options for critical response to the epidemic of opioid overdose mortality. Am J Public Health. 2009 Mar;99(3):402–7. doi: 10.2105/AJPH.2008.136937. PMID: 19150908. Excluded; not a study.19150908
36 Kirane H, Ketteringham M, Bereket S, . Awareness and attitudes toward intranasal naloxone rescue for opioid overdose prevention. J Subst Abuse Treat. 2016;69:44–9. PMID: 27568509. Excluded for wrong population.27568509
37 Kitch BB, Portela RC. Effective use of naloxone by law enforcement in response to multiple opioid overdoses. Prehosp Emerg Care. 2016;20(2):226–9. doi: 10.3109/10903127.2015.1076097. PMID: 27002349. Excluded for wrong study design for Key Question.27002349
38 Knowlton A, Weir BW, Hazzard F, . EMS runs for suspected opioid overdose: implications for surveillance and prevention. Prehosp Emerg Care. 2013 Jul–Sep;17(3):317–29. doi: 10.3109/10903127.2013.792888. PMID: 23734988. Excluded for wrong outcome.23734988
39 Kouyoumdjian F, Orkin AM, Bingham K, . Quality assessment errors and study misclassification threaten systematic eview validity: community opioid overdose prevention and naloxone distribution programs review. J Addict Med. 2015;9(6):502–3. doi: 10.1097/ADM.0000000000000161. PMID: 26517325. Excluded; not a study.26517325
40 Lindstrom HA, Clemency BM, Snyder R, . Prehospital naloxone administration as a public health surveillance tool: a retrospective validation study. Prehosp Disaster Med. 2015 Aug;30(4):385–9. doi: 10.1017/S1049023X15004793. PMID: 26061280. Excluded for wrong outcome.26061280
41 Lobmaier PP, Clausen T. Radical red tape reduction by government supported nasal naloxone: the Norwegian pilot project is innovative, safe and an important contribution to further development and dissemination of take-home naloxone. Addiction. 2016 Apr;111(4):586–7. doi: 10.1111/add.13261. PMID: 26995169. Excluded; not a study.26995169
42 Loimer N, Hofmann P, Chaudhry HR. Nasal administration of naloxone is as effective as the intravenous route in opiate addicts. Int J Addict. 1994 Apr;29(6):819–27. PMID: 8034388. Excluded for wrong population.8034388
43 M J, C S. Notes on naloxone...August issue article “Armed with Naloxone: The first responders’ ultimate weapon in the war on opioid use? JEMS. 2014;39(11):12-. Excluded; not a study.
44 Massachusetts Department of Public Health. Opioid-related EMS Transports Massachusetts Residents: 2013–2015. May, 2016. http://www.mass.gov/eohhs/docs/dph/quality/drugcontrol/county-level-pmp/emergency-medical-services-data-may-2016.pdf Accessed Decmeber 19, 2016. Excluded for wrong outcome.
45 McDermott C, Collins NC. Prehospital medication administration: a randomised study comparing intranasal and intravenous routes. Emerg Med Int. 2012;2012:476161. doi: 10.1155/2012/476161. PMID: 22953064. Excluded for wrong population.22953064
46 McDonald R, Strang J. Are take-home naloxone programmes effective? Systematic review utilizing application of the Bradford Hill criteria. Addiction. 2016 Jul;111(7):1177–87. doi: 10.1111/add.13326. PMID: 27028542. Excluded for wrong population.27028542
47 Merlin MA, Ariyaprakai N, Arshad FH. Assessment of the safety and ease of use of the naloxone auto-injector for the reversal of opioid overdose. Open Access Emerg Med. 2015;7:21–4. doi: 10.2147/OAEM.S82133. PMID: 27147886. Excluded; not a study.27147886
48 Naloxone distribution saves more than 400 lives in SF OD project. ADAW. 2010;22(42):3–4. Excluded; not a study.
49 Naloxone distribution saves more than 400 lives in SF overdose project. Brown Univ Dig Addict Theory Appl. 2010;29(12):4–5. Excluded; not a study.
50 Naloxone for heroin overdose reversal. Ann Intern Med. 2013;158(1):I–30. doi: 10.7326/0003-4819-158-1-201301010-00001. Excluded for wrong population.
51 News: clinical digest: a weekly round-up of the latest research and scientific reports from the nursing and medical journals. Intranasal naloxone effective in patients who overdose. Nurs Stand. 2005;19(24):10-. Excluded; not a study.
52 Neale J, Strang J. Naloxone--does over-antagonism matter? Evidence of iatrogenic harm after emergency treatment of heroin/opioid overdose. Addiction. 2015 Oct;110(10):1644–52. doi: 10.1111/add.13027. PMID: 26119038. Excluded for wrong population.26119038
53 Nielsen S, Menon N, Larney S, . Community pharmacist knowledge, attitudes and confidence regarding naloxone for overdose reversal. Addiction. 2016 PMID: 27367125. Excluded for wrong population.27367125
54 Osterwalder JJ. Patients intoxicated with heroin or heroin mixtures: how long should they be monitored? Eur J Emerg Med. 1995 Jun;2(2):97–101. PMID: 9422191. Excluded for wrong intervention.9422191
55 Osterwalder JJ. Naloxone--for intoxications with intravenous heroin and heroin mixtures--harmless or hazardous? a prospective clinical study. J Toxicol Clin Toxicol. 1996;34(4):409–16. PMID: 8699555. Excluded for wrong comparator.8699555
56 Purviance D, Ray B, Tracy A, . Law enforcement attitudes towards naloxone following opioid overdose training. Subst Abus. 2016 PMID: 27715714. Excluded for wrong population.27715714
57 Roberts JR. Providing naloxone to non-medical personnel can prevent OD deaths without increasing abuse. Emergency Medicine News. 2014;36(9):12–4. Excluded; not a study.
58 Robertson TM. Intranasal versus intravenous naloxone for prehospital narcotic overdose. Academic Emergency Medicine. 2005;12:166–7. Excluded; not a study.
59 Romac DR. Safety of prolonged, high-dose infusion of naloxone hydrochloride for severe methadone overdose. Clin Pharm. 1986 Mar;5(3):251–4. PMID: 3956131. Excluded for wrong study design for Key Question.3956131
60 Rowe C, Santos GM, Vittinghoff E, . Predictors of participant engagement and naloxone utilization in a community-based naloxone distribution program. Addiction. 2015 Aug;110(8):1301–10. doi: 10.1111/add.12961. PMID: 25917125. Excluded for wrong population.25917125
61 Rupreht J, Dworacek B, Oosthoek H, . Physostigmine versus naloxone in heroin-overdose. J Toxicol Clin Toxicol. 1983;21(3):387–97. PMID: 6676478. Excluded for wrong comparator.6676478
62 Salvucci A, Jr. IN vs. IM naloxone. Emergency Medical Services. 2005;34(8):64–6. Excluded; not a study.
63 Sanaei-Zadeh H. Is transdermal iontophoretic delivery of naloxone sufficient for the management of intoxication in opioid-overdosed patients? Int J Pharm. 2012 May 30;428(1–2):187. doi: 10.1016/j.ijpharm.2012.02.045. PMID: 22426321. Excluded; not a study.22426321
64 Smith DA, Leake L, Loflin JR, . Is admission after intravenous heroin overdose necessary? Ann Emerg Med. 1992 Nov;21(11):1326–30. PMID: 1416327. Excluded for wrong population.1416327
65 Sutter ME, Gerona RR, Davis MT, . Fatal Fentanyl: One Pill Can Kill. Acad Emerg Med. 2016 Jun 20doi: 10.1111/acem.13034. PMID: 27322591. Excluded for wrong outcome.27322591
66 Walley AY, Xuan Z, Hackman HH, . Opioid overdose rates and implementation of overdose education and nasal naloxone distribution in Massachusetts: interrupted time series analysis. BMJ. 2013;346:f174. doi: 10.1136/bmj.f174. PMID: 23372174. Excluded for wrong population.23372174
67 Wasiak J, Clavisi O. Is subcutaneous or intramuscular naloxone as effective as intravenous naloxone in the treatment of life-threatening heroin overdose? Med J Aust. 2002 May 20;176(10):495. PMID: 12065016. Excluded; not a study.12065016
68 Willman MW, Liss DB, Schwarz ES, . Do heroin overdose patients require observation after receiving naloxone? Clin Toxicol. 2017 Feb;55(2):81–7. PMID: 27849133. Excluded; wrong population.27849133
69 Yealy DM, Paris PM, Kaplan RM, . The safety of prehospital naloxone administration by paramedics. Ann Emerg Med. 1990 Aug;19(8):902–5. PMID: 2372173. Excluded for wrong comparator.2372173