# Appendix B Included Studies List

1 Boyd JJ, Kuisma MJ, Alaspaa AO, . Recurrent opioid toxicity after pre-hospital care of presumed heroin overdose patients. Acta Anaesthesiol Scand. 2006 Nov;50(10):1266–70. PMID: 17067327.17067327
2 Kelly AM, Kerr D, Dietze P, . Randomised trial of intranasal versus intramuscular naloxone in prehospital treatment for suspected opioid overdose. Med J Aust. 2005 Jan 3;182(1):24–7. PMID: 15651944.15651944
3 Kerr D, Kelly AM, Dietze P, . Randomized controlled trial comparing the effectiveness and safety of intranasal and intramuscular naloxone for the treatment of suspected heroin overdose. Addiction. 2009 Dec;104(12):2067–74. doi: 10.1111/j.1360-0443.2009.02724.x. PMID: 19922572.19922572
4 Levine M, Sanko S, Eckstein M. Assessing the risk of prehospital administration of naloxone with subsequent refusal of care. Prehosp Emerg Care. 2016;20(5):566–9. PMID: 2701862627018626
5 Merlin MA, Saybolt M, Kapitanyan R, . Intranasal naloxone delivery is an alternative to intravenous naloxone for opioid overdoses. Am J Emerg Med. 2010 Mar;28(3):296–303. doi: 10.1016/j.ajem.2008.12.009. PMID: 20223386.20223386
6 Robertson TM, Hendey GW, Stroh G, . Intranasal naloxone is a viable alternative to intravenous naloxone for prehospital narcotic overdose. Prehosp Emerg Care. 2009 Oct–Dec;13(4):512–5. doi: 10.1080/10903120903144866. PMID: 19731165.19731165
7 Rudolph SS, Jehu G, Nielsen SL, . Prehospital treatment of opioid overdose in Copenhagen--is it safe to discharge on-scene? Resuscitation. 2011 Nov;82(11):1414–8. doi: 10.1016/j.resuscitation.2011.06.027. PMID: 21745532. Excluded for wrong comparator.21745532
8 Sabzghabaee AM, Eizadi-Mood N, Yaraghi A, . Naloxone therapy in opioid overdose patients: intranasal or intravenous? a randomized clinical trial. Arch Med Sci. 2014 May 12;10(2):309–14. doi: 10.5114/aoms.2014.42584. PMID: 24904666.24904666
9 Sporer KA, Firestone J, Isaacs SM. Out-of-hospital treatment of opioid overdoses in an urban setting. Acad Emerg Med. 1996 Jul;3(7):660–7. PMID: 8816181.8816181
10 Vilke GM, Buchanan J, Dunford JV, . Are heroin overdose deaths related to patient release after prehospital treatment with naloxone? Prehosp Emerg Care. 1999 Jul–Sep;3(3):183–6. PMID: 10424852.10424852
11 Vilke GM, Sloane C, Smith AM, . Assessment for deaths in out-of-hospital heroin overdose patients treated with naloxone who refuse transport. Acad Emerg Med. 2003 Aug;10(8):893–6. PMID: 12896894.12896894
12 Wampler DA, Molina DK, McManus J, . No deaths associated with patient refusal of transport after naloxone-reversed opioid overdose. Prehosp Emerg Care. 2011 Jul–Sep;15(3):320–4. doi: 10.3109/10903127.2011.569854. PMID: 21612385.21612385
13 Wanger K, Brough L, Macmillan I, . Intravenous vs subcutaneous naloxone for out-of-hospital management of presumed opioid overdose. Acad Emerg Med. 1998 Apr;5(4):293–9. PMID: 9562190.9562190