# Appendix A Search Strategies

## Database: Ovid MEDLINE(R)

1. overdose*.mp.
2. drug overdose/or opioid-related disorders/
3. Naloxone/or naloxone.mp.
4. (1 or 2) and 3

## Database: PsychINFO

1. naloxone.mp. or exp NALOXONE/
2. exp DRUG OVERDOSES/
3. overdos*.mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures]
4. 1 and (2 or 3)

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1. naloxone.mp. or exp NALOXONE/
2. exp DRUG OVERDOSES/
3. overdos*.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4. 1 and (2 or 3)

## Database: CINAHL

((MH “Naloxone”) OR “naloxone”) AND ((MH “Overdose”) OR “overdose” OR overdos*)