# Results

## Literature Searches and Evidence Base

The electronic search, grey literature and reference mining identified 32,156 citations. After title and abstract screening, 3,288 studies were retrieved for full text review. A total of 206 studies met eligibility criteria and were included in the analyses (Appendix A, Figure A.1).

For Key Question (KQ) 1, we identified a total of 110 randomized controlled trials (RCTs) and 4 non-randomized comparative studies. 19 RCTs compared drugs to pill placebo. 2 RCTs compared drugs to drugs. 2 RCTs compared cognitive behavioral therapy (CBT) to drugs. 88 studies (84 RCTs and 4 non-randomized comparative studies studies) compared CBT to pill placebo, waitlisting/no treatment, or attention control/treatment as usual. 3 RCTs compared combination treatment to drugs or CBT alone.

For KQ 2, 20 RCTs and non-randomized comparative studies reported adverse events (AEs). Majority of these studies compared drugs to pill placebo, while head-to-head comparisons were rare. In addition, 18 single cohort observational studies reported AEs related to different drugs.

We identified 51 studies (44 RCTs and 7 non-randomized comparative studies) that evaluated non-CBT psychotherapies. We did not quantitatively combine these studies due to the heterogeneity of the interventions. However, these studies are summarized in Appendix Table E.8—19. 52 studies (47 RCTs and 5 non-randomized comparative studies) compared different CBTs in terms of components (exposure session, cognitive strategy, and/or relaxation strategy), treatment intensity, parent involvement, and delivery mode (individual-based versus group-based).

We included 193 studies published in English, 10 studies in Spanish,^32–41^ and 3 studies in German.^42–44^ We excluded one study published in Turkish^45–47^ and three in Persian.^48^ In addition, we identified 225 relevant ongoing trials through clinicaltrials.gov.

Risk of bias in the majority of the included studies was rated as moderate to high (Appendix Table F.1 and F.2). We did not rate down strength of evidence (SOE) due to lack of blinding as this is not feasible in CBT and other psychotherapies.

## Analysis Results

### KQ 1 What is the comparative effectiveness of the available treatments for childhood anxiety disorders, including panic disorder, social anxiety disorder, specific phobias, generalized anxiety disorder, and separation anxiety?

#### Drugs Versus Pill Placebo

##### Key Points

- Selective serotonin reuptake inhibitor (SSRIs) improved primary anxiety symptoms (clinician and parent report), function, remission, and clinical response, compared to pill placebo (moderate to high SOE).
- Serotonin–norepinephrine reuptake inhibitors (SNRIs) improved primary anxiety symptoms, compared to pill placebo (only clinician report) (high SOE).
- Tricyclic antidepressants marginally improved clinical response, compared to pill placebo (low SOE).
- Benzodiazepines did not show significant improvement in anxiety symptoms over pill placebo (low SOE).

##### Discussion

Nineteen RCTs^7, 22, 49–72^ compared medications to pill placebo, including atomoxetine, clonazepam, clomipramine, duloxetine, fluvoxamine, fluoxetine, imipramine, paroxetine, sertraline, and venlafaxine. Overall, 2,498 patients were included with a mean age of 11.6 years old and 54.1 percent male. 13 studies^49–52, 54, 56, 58, 60–65^ (68.4%) included patients without any comorbidity. 6 studies ^7, 22, 53–55, 57, 66, 67, 69–73^ included children with anxiety and comorbidity (attention deficit hyperactivity disorder (ADHD), autism, ODD, obsessive compulsive disorder (OCD) and other internalizing disorders). Details of the included studies can be found in Appendix Table E.1. We were unable to evaluate publication bias due to small number of studies (n<20) included in each comparisons.

As a class, SSRIs improved primary anxiety symptoms (clinician and parent report), function, remission, and clinical response, compared to pill placebo (moderate to high SOE). SNRIs improved primary anxiety symptoms (clinician report, high SOE). TCAs marginally improved clinical response (low SOE), whereas benzodiazepines did not show significant improvement in anxiety symptoms over pill placebo (low SOE). Results of the comparisons of drug classes with pill placebo and associated SOE are presented in Table 5. Results of the individual drugs comparisons with pill placebo are presented in Table 6.

Table 5 Strength of evidence for drug classes versus pill placebo

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of Evidence^b^ | Overall Evidence Strength (Direction of Effect)
Benzodiazepine vs. Pill Placebo | Primary anxiety, clinician report | SMD: 0.30; 95% CI: −0.72 to 1.32; I^2^=N/A | 1 RCT (15 Patients)^57^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | Primary anxiety, child report | SMD: −2.14; 95% CI: −9.75 to 5.48; I^2^= 99.4% | 3 RCTs (622 Patients)^55, 58, 62^ | Severe imprecision (very wide CIs) and inconsistency | Insufficient
SNRI vs. Pill Placebo | Primary anxiety, parent report | SMD: −0.32; 95% CI: −0.63 to 0.00; I^2^=N/A | 1 RCT (153 Patients)^62^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.45; 95% CI: −0.81 to −0.10; I^2^=0.0% | 3 RCTs (601 Patients)^55, 62, 64^ | None | High (reduced anxiety)
SNRI vs. Pill Placebo | Function | SMD: −0.05; 95% CI: −0.24 to 0.13; I^2^=93.4% | 2 RCTs (448 Patients)^55, 64^ | Severe imprecision (wide CIs) and inconsistency | Low (no difference)
SSRI vs. Pill Placebo | Primary anxiety, child report | SMD: −0.42; 95% CI: −0.96 to 0.12; I^2^=27.5% | 4 RCTs (197 Patients)^51, 53, 54, 61, 65^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
SSRI vs. Pill Placebo | Primary anxiety, parent report | SMD: −0.61; 95% CI: −1.03 to −0.20; I^2^=55.1% | 2 RCTs (96 Patients)^53, 61^ | Imprecision (small sample size) | Moderate (reduced anxiety)
SSRI vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.65; 95% CI: −1.10 to −0.21; I^2^=73.4% | 7 RCTs (675 Patients)^7, 22, 49, 51, 53, 54, 61, 65, 67, 69–73^ | Inconsistency | Moderate (reduced anxiety)
SSRI vs. Pill Placebo | Function | SMD: −0.59; 95% CI: to −0.85 to −0.34; I^2^= 0.0% | 4 RCTs (680 Patients)^7, 51, 53, 65, 67, 69–73^ | None | High (improved function)
SSRI vs. Pill Placebo | Secondary measure | SMD: −0.19; 95% CI: −0.55 to 0.17; I^2^=75.1 | 1 RCT (124 Patients)^51, 54^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
SSRI vs. Pill Placebo | Social function | SMD: 0.18; 95% CI: −0.26 to 0.62; I^2^ = N/A | 1 RCT (80 Patients)^51^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
SSRI vs. Pill Placebo | Remission | RR: 2.04; 95% CI: 1.37 to 3.04; I^2^=N/A | 2 RCTs (95 Patients)^53, 54^ | Imprecision small sample size) | Moderate (improved remission)
SSRI vs. Pill Placebo | Response | RR: 1.96; 95% CI: 1.60 to 2.40; I^2^=0.0% | 2 RCTs (396 Patients)^53, 65^ | Imprecision (small sample size) | Moderate (improved response)
TCA vs. Pill Placebo | Primary anxiety, child report | SMD: 0.36; 95% CI: −0.27 to 0.99; I^2^=45.6% | 2 RCTs (41 Patients)^54, 74^ | Severe imprecision (small sample size and wide CIs). | Low (no difference)
TCA vs. Pill Placebo | Primary anxiety, parent report | SMD: 0.46; 95% CI: −0.41 to 1.33; I^2^=N/A | 1 RCT (21 Patients)^74^ | Methodological limitations, severe imprecision (small sample size and wide CI) | Insufficient
TCA vs. Pill Placebo | Remission | RR: 1.83; 95% CI: 0.74 to 4.55; I^2^=N/A | 1 RCT (20 Patients)^54^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
TCA vs. Pill Placebo | Response | RR: 1.72; 95% CI: 1.01 to 2.91; I^2^=N/A | 1 RCT (35 Patients)^56^ | Severe imprecision (small sample size and wide CIs) | Low (improved response)

CI: confidence interval, N/A: not applicable, RCT: randomized control trial, RR: relative risk, SMD: standardized mean difference, SNRI: serotonin–norepinephrine reuptake inhibitor, SSRI: selective serotonin reuptake inhibitor, TCA: tricyclic antidepressants.

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.

Table 6 Strength of evidence for individual drugs versus pill placebo

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of Evidence^b^ | Overall Evidence Strength (Direction of Effect)
Atomoxetine (class: SNRI) vs. Pill Placebo | Primary anxiety, child report | SMD: −0.29; 95% CI: −0.51 to − 0.08; I^2^=0.0% | 2 RCTs (331 Patients)^55, 62^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Atomoxetine (class: SNRI) vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.56; 95% CI: −0.78 to −0.34; I^2^=0.0% | 2 RCTs (331 Patients)^55, 62^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Atomoxetine (class: SNRI) vs. Pill Placebo | Primary anxiety, parent report | SMD: −0.23; 95% CI: −0.55 to 0.08; I^2^ = N/A | 1 RCT (155 Patients)^62^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
Atomoxetine (class: SNRI) vs. Pill Placebo | Function | SMD: −0.46; 95% CI: −0.76 to −0.16; I^2^ = N/A | 1 RCT (176 Patients)^55^ | Imprecision (small sample size) | Moderate (improved function)
Clomipramine (class: TCA) vs. Pill Placebo | Primary anxiety, child report | SMD: −0.07; 95% CI: −0.95 to 0.81; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
Duloxetine (class: SNRI) vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.43; 95% CI: −0.67 to −0.19; I^2^=N/A | 1 RCT (272 Patients)^64^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Duloxetine (class: SNRI) vs. Pill Placebo | Function | SMD: −0.35; 95% CI:−0.59 to −0.11; I^2^=N/A | 1 RCT (272 Patients)^64^ | Imprecision (small sample size) | Moderate (improved function)
Fluoxetine (class: SSRI) vs. Pill Placebo | Primary anxiety, child report | SMD:−0.38; 95% CI: −1.26 to 0.50; I^2^=43.3% | 2 RCTs (154 Patients)^51, 53, 54^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Fluoxetine (class: SSRI) vs. Pill Placebo | Primary anxiety, parent report | SMD:−0.46; 95% CI: −0.92 to 0.01; I^2^=N/A | 1 RCT (74 Patients)^53^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Fluoxetine (class: SSRI) vs. Pill Placebo | Primary anxiety, clinician report | SMD:−0.40; 95% CI: −0.72 to −0.01; I^2^=N/A | 2 RCTs (154 Patients)^51, 53^ | Severe imprecision (wide CIs and small sample size) | Low (reduced anxiety)
Fluoxetine (class: SSRI) vs. Pill Placebo | Function | SMD: −0.75; 95% CI: −1.07 to −0.42; I^2^= 0.0% | 2 RCTs (154 Patients)^51, 53^ | Imprecision (small sample size) | Moderate (improved function)
Fluoxetine (class: SSRI) vs. Pill Placebo | Secondary measure | SMD: −0.19; 95% CI: −0.55 to 0.17; I^2^=75.1% | 1 RCT (124 Patients)^51, 54^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Fluoxetine (class: SSRI) vs. Pill Placebo | Social function | SMD: 0.18; 95% CI: −0.26 to 0.62; I^2^=N/A | 1 RCT (80 Patients)^51^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Fluoxetine (class: SSRI) vs. Pill Placebo | Remission | RR: 2.04; 95% CI: 1.32 to 3.04; I^2^=N/A | 2 RCTs (95 Patients)^53, 54^ | Imprecision (small sample size) | Moderate (improved remission)
Fluoxetine (class: SSRI) vs. Pill Placebo | Response | RR: 1.70; 95% CI: 1.01 to 2.82; I^2^=0.0% | 1 RCT (74 Patients)^53^ | Severe imprecision (wide CIs and small sample size) | Low (improved response)
Fluvoxamine (class: SSRI) vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.97; 95% CI: −1.31 to −0.63; I^2^=69.1% | 2 RCTs (153 Patients)^22, 49^ | Imprecision (small sample size) and inconsistency | Low (reduced anxiety)
Imipramine (class: TCA) vs. Pill Placebo | Primary anxiety, child report | SMD: 0.80; 95% CI: −0.10 to 1.70; I^2^=N/A | 1 RCT (21 Patients)^74^ | Methodological limitations, severe imprecision (small sample size and wide CI) | Insufficient
Imipramine (class: TCA) vs. Pill Placebo | Primary anxiety, parent report | SMD: 0.46; 95% CI: −0.41to 1.33; I^2^=N/A | 1 RCT (21 Patients)^74^ | Methodological limitations, severe imprecision (small sample size and wide CI) | Insufficient
Paroxetine (class: SSRI) vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.71; 95% CI: −1.06 to −0.37; I^2^=N/A | 1 RCT (137 Patients)^65^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Paroxetine (class: SSRI) vs. Pill Placebo | Function | SMD: −0.61; 95% CI: −0.83 to −0.38; I^2^=N/A | 1 RCT (317 Patients)^65^ | Imprecision (small sample size) | Moderate (improved function)
Paroxetine (class: SSRI) vs. Pill Placebo | Response | RR: 2.02; 95% CI:1.62 to 2.51; I^2^=N/A | 1 RCT (322 Patients)^65^ | Imprecision (small sample size) | Moderate (improved response)
Sertraline (class: SSRI) vs. Pill Placebo | Primary anxiety, child report | SMD: −0.75; 95% CI: −1.62 to 0.12; I^2^=N/A | 1 RCT (22 patients)^61^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | Primary anxiety, parent report | SMD: −0.24; 95% CI: −2.16 to −0.32; I^2^=N/A | 1 RCT (22 Patients)^61^ | Severe imprecision (wide CIs and small sample size) | Low (reduced anxiety)
Sertraline (class: SSRI) vs. Pill Placebo | Primary anxiety, clinician report | SMD: −71; 95% CI: −0.99 to −0.42; I^2^=89.9% | 2 RCTs (231 Patients)^7, 61, 67, 69–73^ | Imprecision (small sample size), inconsistency | Low (reduced anxiety)
Sertraline (class: SSRI) vs. Pill Placebo | Function | SMD: −0.46; 95% CI: −0.74 to −0.17; I^2^=N/A | 1 RCT (209 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (improved function)
Venlafaxine (class: SNRI) vs. Pill Placebo | Primary anxiety, child report | SMD: −1.96; 95% CI: −2.23 to −1.64; I^2^=99.6% | 2 RCTs (443 Patients)^58, 62^ | Inconsistency | Moderate (reduced anxiety)
Venlafaxine (class: SNRI) vs. Pill Placebo | Primary anxiety, parent report | SMD: −0.32; 95% CI: −0.63 to 0.00; I^2^=N/A | 1 RCT (153 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.42; 95% CI: −0.74 to −0.10; I^2^=N/A | 1 RCT (153 Patients)^62^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Clonazepam (class: Benzodiazepine) vs. Pill Placebo | Primary anxiety, clinician report | SMD: 0.30; 95% CI: −0.72 to 1.32; I^2^=N/A | 1 RCT (15 Patients)^57^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Venlafaxine (class: SNRI) vs. Attention Control or Treatment As Usual | Primary anxiety, child report | SMD: −0.40; 95% CI: −0.72 to −0.09; I^2^=N/A | 1 RCT (158 Patients)^62^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Venlafaxine (class: SNRI) vs. Attention Control or Treatment As Usual | Primary anxiety, parent report | SMD: −0.42; 95% CI: −0.73 to −0.10; I^2^=N/A | 1 RCT (158 Patients)^62^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Venlafaxine (class: SNRI) vs. Attention Control or Treatment As Usual | Primary anxiety, clinician report | SMD: −0.09; 95% CI: −0.40 to 0.22; I^2^=N/A | 1 RCT (158 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Atomoxetine (class: SNRI) vs. Attention Control or Treatment As Usual | Primary anxiety, child report | SMD: −0.26; 95% CI: −0.57 to 0.05; I^2^=N/A | 1 RCT (154 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Atomoxetine (class: SNRI) vs. Attention Control or Treatment As Usual | Primary anxiety, parent report | SMD: −0.34; 95% CI: −0.65 to −0.03; I^2^=N/A | 1 RCT (154 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (reduced anxiety)
Atomoxetine (class: SNRI) vs. Attention Control or Treatment As Usual | Primary anxiety, clinician report | SMD: −0.33; 95% CI: −0.65 to −0.02; I^2^=N/A | 1 RCT (154 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (reduced anxiety)

CI: confidence interval, N/A: not applicable, RCT: randomized control trial, RR: relative risk, SMD: standardized mean difference, SNRI: serotonin–norepinephrine reuptake inhibitor, SSRI: selective serotonin reuptake inhibitor, TCA: tricyclic antidepressants.

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.

#### Drugs Versus Drugs

##### Key Points

- Only two RCTs conducted head-to-head comparison.
- Compared to clomipramine, fluoxetine was more effective in improving primary anxiety symptoms (child report) (low SOE).
- No significant difference was found between venlafaxine and atomoxetine on primary anxiety symptoms (child, parent, and clinician reports) (low SOE).

##### Discussion

One RCT^54, 62^ compared fluoxetine to clomipramine^54^ and another RCT compared venlafaxine to atomoxetine.^62^ Overall, 39 patients were included with age range of 6–17 years old and 52.2% male. These 2 studies^54, 62^ included patients without any comorbidity. Details of the included studies can be found in Appendix Table E.2. We were unable to evaluate publication bias due to small number of studies (n<20) included in each comparisons.

Compared to clomipramine, fluoxetine was more effective in improving primary anxiety symptoms (child report, low SOE); while venlafaxine and atomoxetine were not significantly different in improving primary anxiety symptoms (low SOE). Results of the individual drugs comparisons with drugs are presented in Table 7.

Table 7 Strength of evidence for drugs versus drugs

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of evidence^b^ | Overall Evidence Strength (Direction of Effect)
Fluoxetine (class: SSRI) vs. Clomipramine (class: TCA) | Primary anxiety, child report | SMD: −1.01; 95% CI: −2.02 to −0.09; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (wide CIs and small sample size) | Low (reduced anxiety)
Fluoxetine (class: SSRI) vs. Clomipramine (class: TCA) | Remission | RR: 1.20; 95% CI: 0.69 to 2.09; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Venlafaxine (class: SNRI) vs. Atomoxetine (class: SNRI) | Primary anxiety, child report | SMD: −0.12; 95% CI: −0.43 to 0.20; I^2^=N/A | 1 RCT (154 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Venlafaxine (class: SNRI) vs. Atomoxetine (class: SNRI) | Primary anxiety, parent report | SMD: −0.08; 95% CI: −0.39 to 0.24; I^2^=N/A | 1 RCT (154 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Venlafaxine (class: SNRI) vs. Atomoxetine (class: SNRI) | Primary anxiety, clinician report | SMD: 0.25; 95% CI: −0.07 to 0.57 I^2^=N/A | 1 RCT (154 Patients)^62^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)

CI: confidence interval, N/A: not applicable, RCT: randomized control trial, RR: relative risk, SMD: standardized mean difference, SNRI: serotonin–norepinephrine reuptake inhibitor, SSRI: selective serotonin reuptake inhibitor, TCA: tricyclic antidepressants.

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.

#### Drugs Versus CBT

##### Key Points

- Only two RCTs compared CBT to SSRIs.
- CBT reduced primary anxiety symptoms and improved function more than fluoxetine (moderate SOE).
- CBT was more likely to increase remission than sertraline (moderate SOE).

##### Discussion

One RCT compared CBT to fluoxetine.^51, 63^ Overall, 102 patients were included with a mean age of 11.6 years old and 51.5 percent male. Details of the included study can be found in Appendix Table E.3. CBT was more effective in improving primary anxiety symptoms (clinician report), function, and secondary anxiety measures (moderate SOE). Table 8 includes summary of the results and assessment of SOE.

Table 8 Strength of evidence for drugs versus CBT

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of Evidence^b^ | Overall Evidence Strength (Direction of Effect)
Fluoxetine (class: SSRI) vs. CBT | Primary anxiety, child report | SMD:−0.16; 95% CI: −0.55 to 0.24; I^2^=N/A | 1 RCT (102 Patients)^51^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Fluoxetine (class: SSRI) vs. CBT | Primary anxiety, clinician report | SMD:0.78; 95% CI: 0.37 to 1.18; I^2^=N/A | 1 RCT (102 Patients)^51^ | Imprecision (small sample size) | Moderate (increased anxiety)
Fluoxetine (class: SSRI) vs. CBT | Function | SMD: 0.54; 95% CI: 0.14 to 0.94; I^2^=N/A | 1 RCT (102 Patients)^51^ | Imprecision (small sample size) | Moderate (reduced function)
Fluoxetine (class: SSRI) vs. CBT | Secondary measure | SMD: 0.51; 95% CI: 0.11 to 0.90; I^2^=N/A | 1 RCT (102 Patients)^51^ | Imprecision (small sample size) | Moderate (increased anxiety)
Fluoxetine (class: SSRI) vs. CBT | Social function | SMD: −0.19; 95% CI: −0.58 to 0.21; I2=N/A | 1 RCT (102 Patients)^51^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Sertraline (class: SSRI) vs. CBT | Primary anxiety, clinician report | SMD: −0.15; 95% CI: −0.31 to 0.02; I^2^= N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Sertraline (class: SSRI) vs. CBT | Function | SMD: −0.12; 95% CI: −0.35 to 0.12; I^2^= N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
Sertraline (class: SSRI) vs. CBT | Remission | RR: 0.57; 95% CI: 0.48 to 0.69; I^2^=N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (reduced remission)
Sertraline (class: SSRI) vs. CBT | Response | RR: 0.97; 95% CI: 0.80 to 1.17; I^2^=N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)

CI: confidence interval, CBT: cognitive behavioral therapy, N/A: not applicable, RCT: randomized control trial, RR: relative risk, SMD: standardized mean difference, SNRI: serotonin–norepinephrine reuptake inhibitor, SSRI: selective serotonin reuptake inhibitor, TCA: Tricyclic antidepressants

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.

One RCT of 272 patients with a primary diagnosis of social anxiety disorder, generalized anxiety disorder, or social anxiety disorder (mean age: 10.7 years), compared CBT to sertraline.^7, 67, 69–73^ Patients were randomized to receive either 14 sessions of CBT or sertraline (up to 200 mg per day). Details of the included study can be found in Appendix Table E.3. CBT was more likely to increase remission (moderate SOE). There were no other significant differences in other outcomes (low SOE) (Table 8).

#### CBT Versus Control (Pill Placebo, Waitlisting/No Treatment, or Attention Control/Treatment as Usual)

##### Key Points

- Compared to pill placebo, CBT improved secondary anxiety measures (low SOE).
- Compared to waitlisting or no treatment, CBT improved primary anxiety symptoms (clinician, child, and parent report), function, remission, and clinical response (low to moderate SOE).
- Compared to attention control or treatment as usual, CBT reduced primary anxiety symptoms (child report) (moderate SOE).

##### Discussion

Eighty-four RCTs and 4 non-randomized comparative studies compared CBT to controls. 29 RCTs^7, 33, 38, 41, 63, 67–72, 75–101^ and 1 non-randomized comparative study ^102^ compared CBT to attention control/treatment as usual, 60 RCTs ^33, 34, 36, 39–42, 44, 84, 86, 89, 100, 101, 103–153^ and 3 non-randomized comparative study ^154–156^ compared CBT versus waitlisting/no treatment, and 3 RCTs compared CBT versus pill placebo.^7, 51, 63, 67–72^ Overall, 6,978 patients were included with a mean age of 11.2 years and 47.9 percent male. 59 studies^33, 34, 36, 38–42, 44, 51, 63, 75–81, 83, 85–87, 89, 90, 92, 94, 96, 100, 102–105, 107–109, 110, 113, 117, 118, 120, 123–126, 130, 131, 133, 135, 137, 139–145, 147, 154–156^ (67.0%) of included patients without any comorbidity. 30 studies^7, 67–73, 82, 84, 88, 91, 93, 95, 97–99, 101, 106, 111, 112, 114–116, 119, 121, 122, 127–129, 134, 136, 138, 146, 148–150, 152, 153^ included children with anxiety and other comorbidities. 8 studies^39, 42, 44, 89, 98, 99, 104, 113, 133^ (9.1%) didn’t provide enough quantitative data and were excluded from meta-analyses. Details of the included studies can be found in Appendix Tables E.4 to E.6. We found indications of potential publication bias when CBT was compared to waitlisting on primary anxiety symptoms (Appendix Figures H.1 to H.3). We were unable to evaluate publication bias due to small number of studies (n<20) included in other comparisons.

Compared to pill placebo, CBT improved secondary anxiety measures (low SOE). Compared to waitlisting or no treatment, CBT improved primary anxiety symptoms (clinician, child, and parent report), function, remission, and clinical response (low to moderate SOE). Compared to attention control or treatment as usual, CBT reduced primary anxiety symptoms (child report, moderate SOE). Table 9 includes summary of the results and assessment of SOE.

Table 9 Strength of evidence for CBT versus pill placebo, waitlisting/no treatment, or attention control/treatment as usual

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of Evidence^b^ | Overall Evidence Strength (Direction of Effect)
CBT vs. Pill Placebo | Primary anxiety, child report | SMD: −0.22; 95% CI: −0.64 to 0.19; I^2^=N/A | 1 RCT (96 Patients)^51^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
CBT vs. Pill Placebo | Primary anxiety, clinician report | SMD: −0.61; 95% CI: −0.85 to −0.37; I^2^=89.1% | 2 RCTs (311 Patients)^7, 51, 67, 69–73^ | Methodological limitations, inconsistency, imprecision (small sample size) | Insufficient
CBT vs. Pill Placebo | Function | SMD:−0.60; 95% CI: −0.84 to −0.36; I^2^=90.5% | 2 RCTs (311 Patients)^7, 51, 67, 69–73^ | Methodological limitations, inconsistency, imprecision (small sample size) | Insufficient
CBT vs. Pill Placebo | Social function | SMD: 0.35; 95% CI: −0.07, 0.76; I^2^=N/A | 1 RCT (96 Patients)^51^ | Methodological limitations, severe imprecision (small sample size and wide CI) | Insufficient
CBT vs. Pill Placebo | Secondary measure | SMD: −0.02; 95% CI: −0.42 to 0.37; I^2^=99.1% | 1 RCT (96 Patients)^51, 63^ | Imprecision (small sample size) and inconsistency | Low (no difference)
CBT vs. Waitlisting or No Treatment | Primary anxiety, child report | SMD: −0.77; 95% CI: −1.06 to −0.47; I^2^=86.5% | 41 RCTs, 2 non-randomized comparative studies (2,297 Patients)^33, 36, 40, 86, 105–112, 114–117, 119, 120, 122–130, 134–139, 141–146, 150, 151, 153–155, 157, 158^ | Inconsistency^c^ | Moderate (reduced anxiety)
CBT vs. Waitlisting or No Treatment | Primary anxiety, parent report | SMD: −0.88; 95% CI: −1.23 to −0.54; I^2^=81.2% | 27 RCTs 2 non-randomized comparative studies (1,540 Patients)^33, 103, 105, 106, 110, 111, 114–116, 121–124, 126–128, 131, 132, 134, 136–138, 141, 143, 145, 146, 150, 151, 153, 155, 158^ | Inconsistency^c^ | Moderate (reduced anxiety)
CBT vs. Waitlisting or No Treatment | Primary anxiety, clinician report | SMD: −1.38; 95% CI: −1.95 to −0.81; I^2^=88.3% | 32 RCTs, 2 non-randomized comparative studies (1,926 Patients)^33, 36, 40, 86, 106, 107, 109, 111, 112, 114, 117–122, 126, 127, 129, 131, 132, 136, 137, 139, 143–146, 148–150, 152–154, 158^ | Inconsistency^c^ | Moderate (reduced anxiety)
CBT vs. Waitlisting or No Treatment | Function | SMD: −0.80, 95% CI; −1.41 to − 0.20; I^2^=91.6% | 18 RCTs, 1 non randomized control trial (937 Patients)^33, 36, 106, 108, 114, 117, 119, 122, 126, 128, 129, 132, 134, 136, 141, 146, 148, 152, 154^ | Inconsistency | Moderate (improved function)
CBT vs. Waitlisting or No Treatment | Social function | SMD: −0.02; 95% CI; −0.77 to 0.74; I^2^=86.1% | 9 RCTs, 1 non-randomized control trial (385 Patients)^36, 41, 114–117, 119, 122, 123, 144, 154^ | Severe imprecision (wide CI and small sample size), inconsistency | Insufficient
CBT vs. Waitlisting or No Treatment | Satisfaction | SMD: 0.90; 95% CI: −0.58 to 1.21; I^2^=0.0% | 2 RCTs (146 Patients)^86, 157^ | Severe imprecision (wide CI and small sample size) | Low (no difference)
CBT vs. Waitlisting or No Treatment | Secondary measure | SMD: 0.37; 95% CI: −0.32 to 1.05; 92.4% | 16 RCTs, 2 non-randomized control (1,111 Patients)^33, 36, 40, 86, 108, 110, 115, 116, 119, 121–125, 130, 135, 137, 144, 147, 154^ | Imprecision (wide CI), inconsistency | Low (no difference)
CBT vs. Waitlisting or No Treatment | Remission | RR: 4.08; 95% CI: 1.05 to 15.80; I^2^=80.8% | 7 RCTs (307 Patients)^33, 34, 108, 111, 122, 134, 149^ | Methodological limitations, imprecision (small sample size), inconsistency | Low (improved remission)
CBT vs. Waitlisting or No Treatment | Response | RR: 4.72; 95% CI: 2.39 to 9.32; I^2^=80.4% | 14 RCTs (733 Patients)^36, 81, 86, 115, 116, 120–122, 124, 126–128, 136, 143, 144, 148, 149^ | Inconsistency | Moderate (improved response)
CBT vs. Attention Control or Treatment As Usual | Primary anxiety, child report | SMD:−0.36; 95% CI: −0.67 to −0.05; I^2^=60.5% | 12 RCTs, 1 non-randomized comparative study (704 Patients)^38, 76, 79, 80, 82, 83, 87, 88, 92, 94–96, 102^ | Borderline imprecision and inconsistency | Moderate (reduced anxiety)
CBT vs. Attention Control or Treatment As Usual | Primary anxiety clinician report | SMD:−0.11; 95% CI: −0.36 to 0.14; I^2^=28.6% | 9 RCTs (486 Patients)^77–79, 82, 87, 92, 94, 97, 100^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
CBT vs. Attention Control or Treatment As Usual | Primary anxiety, parent report | SMD: 0.04; 95% CI: −0.17 to 0.24; I^2^=0.0% | 7 RCTs, 1 non-randomized comparative study (533 Patients)^78–81, 92, 94, 96, 97, 102^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
CBT vs. Attention Control or Treatment As Usual | Function | SMD: −0.70, 95% CI: −1.76 to −0.36; I^2^=83.5% | 5 RCTs (293 Patients)^38, 82, 95, 96, 101^ | Methodological limitations, imprecision (small sample size), inconsistency | Insufficient
CBT vs. Attention Control or Treatment As Usual | Social function | SMD: −0.23, 95% CI: −0.66 to 0.21; I^2^=40.9% | 5 RCTs (330 Patients)^38, 78, 92, 101, 102^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
CBT vs. Attention Control or Treatment As Usual | Satisfaction | SMD: −0.03, 95% CI: −0.71 to 0.65; I^2^=N/A | 1 RCT ( 33 Patients)^82^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT vs. Attention Control or Treatment As Usual | Secondary measure | SMD: −0.50; 95% CI: −1.28 to 0.29; I^2^=N/A | 3 RCTs (156 Patients)^38, 80, 81, 87^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT vs. Attention Control or Treatment As Usual | Remission | RR: 1.51; 95% CI: 0.95 to 2.40; I^2^=0.0% | 4 RCTs (366 Patients}^79, 90, 92, 94^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT vs. Attention Control or Treatment As Usual | Response | RR:1.90, 95% CI: 0.68 to 5.30; I^2^=67.2% | 5 RCTs (374 Patients)^79–81, 92, 94, 96^ | Methodological limitations, severe imprecision (small sample size and wide CIs), inconsistency | Insufficient

CI: confidence interval, CBT: cognitive behavioral therapy, N/A: not applicable, RCT: randomized control trial, RR: relative risk, SMD: standardized mean difference.

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.

c There was a suggestion of publication bias; however, we did not rate down SOE.

#### CBT Combined With Drugs

##### Key Points

- Compared to CBT alone, the combination of imipramine and CBT reduced primary anxiety symptoms (child report) and function (moderate SOE).
- The combination of fluoxetine and CBT was found to have lower remission rate compared to CBT alone (low SOE).
- The combination of sertraline and CBT reduced primary anxiety symptoms (clinician report), improved function, and increased clinical response, compared to CBT alone (moderate SOE).
- The combination of sertraline and CBT improved primary anxiety symptoms (clinician report), function, and clinical response (moderate SOE), compared to sertraline alone (moderate SOE).

##### Discussion

One RCT with 63 patients compared the combination of imipramine and CBT to CBT alone^159^. All patients had major depressive disorder and at least one anxiety disorder. The mean age of the included patients was 13.9 years and 90.5 percent were Caucasians. Details of the included study can be found in Appendix Table E.7. Compared with CBT alone, adding imipramine to CBT reduced primary anxiety symptoms (child report) and improved function (moderate SOE).

One RCT of 41 anxious school refusing adolescents compared fluoxetine plus CBT to CBT^160^. Details of the included study can be found in Appendix Table E.7. Patients in the CBT and fluoxetine group had lower remission than CBT alone (low SOE).

One RCT of 272 patients compared the combination of CBT and sertraline to CBT, or to sertraline^7, 67, 69–73^. Patients (7–17 years old; mean age: 10.7; primary diagnosis of social anxiety disorder, generalized anxiety disorder, or social anxiety disorder) were randomized to receive either 14 sessions of CBT or sertraline (up to 200 mg per day). Details of the included study can be found in Appendix Table E.7. Compared to CBT alone, adding sertraline reduced primary anxiety symptoms (clinician report), improved function, and improved clinical response (moderate SOE). The addition of CBT to sertraline (compared to sertraline alone) improved primary anxiety symptoms (clinician report), function, and likelihood of clinical response (moderate SOE) (Table 10).

Table 10 Strength of evidence for CBT combined with drugs

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of Evidence^b^ | Overall Evidence Strength (Direction of Effect)
Imipramine (class: TCA) + CBT vs. CBT | Primary anxiety, child report | SMD: −0.74; 95% CI: −1.26 to −0.23; I^2^=N/A | 1 RCT (63 Patients)^159^ | Imprecision (small sample size) | Moderate (reduced anxiety)
Imipramine (class: TCA) + CBT vs. CBT | Primary anxiety. clinician report | SMD: −0.61; 95% CI: −1.11 to 0.10; I^2^=N/A | 1 RCT (63 Patients)^159^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Imipramine (class: TCA) + CBT vs. CBT | Function | SMD: −1.27; 95% CI: −1.81 to −0.73; I^2^=N/A | 1 RCT (63 Patients)^159^ | Imprecision (small sample size) | Moderate (improved function)
Fluoxetine (class: SSRI) + CBT vs. CBT | Function | SMD: −0.13; 95% CI: −0.74 to 0.48; I^2^=N/A | 1 RCT (41 Patients)^160^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluoxetine (class: SSRI) + CBT vs. CBT | Secondary measure | SMD: −0.03; 95% CI: −0.59 to 0.64; I^2^=N/A | 1 RCT (41 Patients)^160^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluoxetine (class: SSRI) + CBT vs. CBT | Response | RR: 1.71; 96% CI: 0.69 to 4.24; I^2^=N/A | 1 RCT (41 Patients)^160^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluoxetine (class: SSRI) + CBT vs. CBT | Remission | RR: 0.24; 95% CI: 0.06 to 0.99; I^2^=N/A | 1 RCT (41 Patients)^160^ | Severe imprecision (small sample size and wide CI) | Low (reduced remission)
CBT + Sertraline (class: SSRI) vs. CBT | Primary anxiety, clinician report | SMD: −0.69; 95% CI: −0.93 to −0.45; I^2^=N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (reduced anxiety)
CBT + Sertraline (class: SSRI) vs. CBT | Function | SMD: −0.47; 95% CI: −0.70 to −0.23; I^2^=N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (improved function)
CBT + Sertraline (class: SSRI) vs. CBT | Remission | RR: 0.45; 95% CI: 0.36 to 0.59; I^2^=N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (reduced remission)
CBT + Sertraline (class: SSRI) vs. CBT | Response | RR: 1.27; 95% CI: 1.09 to 1.49; I^2^=N/A | 1 RCT (272 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (improved response)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | Primary anxiety, clinician report | SMD: −0.46; 95% CI: −0.70 to −0.22; I^2^=N/A | 1 RCT (273 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (reduced anxiety)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | Function | SMD: −0.34; 95% CI: −0.58 to −0.10; I^2^=N/A | 1 RCT (273 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (improved function)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | Remission | RR: 0.78; 95% CI: 0.69, 4.24; I^2^=N/A | 1 RCT (273 Patients)^7, 67, 69–73^ | Severe imprecision (wide CIs and small sample size) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | Response | RR: 1.32; 95% CI: 1.12 to 1.55; I^2^=N/A | 1 RCT (273 Patients)^7, 67, 69–73^ | Imprecision (small sample size) | Moderate (improved response)

CI: confidence interval, CBT: cognitive behavioral therapy, N/A: not applicable, RCT: randomized control trial, RR: relative risk, SMD: standardized mean difference, SSRI: selective serotonin reuptake inhibitor, TCA: tricyclic antidepressants

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.

#### Subgroup Analysis

##### Key Points

- Treatment effects observed immediately post intervention were larger than those observed after a period of followup.
- Individual-based CBT had statistically significantly more improvement on function than group-based CBT.
- Relaxation and cognitive strategies in CBT were not associated with improvements on primary anxiety symptoms, function, secondary measures, social function, and clinical response; while exposure statistically significantly reduced primary anxiety symptoms (parent report).
- Compared to waitlisting or no treatment, CBT was found to have more improvement on functioning in age group 13–18 than age group 7–12.

##### Discussion

We were not able to conduct a large number of the planned subgroup analyses, including those based on race/ethnicity, parent education level, family income, disease severity (measured by CGI), treatment sequence, and provider. This was due to studies not providing sufficient stratified data per subgroup variable. The results of the feasible exploratory analyses are reported in Appendix Tables G.1 to G.12 and were summarized as follows:

- Age: when CBT compared to waitlisting or no treatment, we found statistically significantly more improvement in function in age group 13–18 than age group 7–12.
- Comorbidity: when CBT compared to pill placebo, patients without comorbidity had statistically significantly more improvement in secondary anxiety measures than patient with any comorbidity. However, the finding was limited by the fact that CBT delivered to children with comorbidities was different in children without comorbidities. Inference from subgroup analyses evaluating comorbidities is less reliable.
- ADHD: when fluvoxamine compared to pill placebo, we found no statistically significant difference on primary anxiety symptoms (clinician report).
- Autism: When CBT was compared to waitlisting or no treatment, we did not find statistically significant difference in outcomes (primary anxiety symptoms, clinician, child, and parent report), function, or clinical response in patients with autism than patients without autism.
- School refusal: when CBT compared to pill placebo, patients without school refusal were found to have statistically significant better outcome (secondary anxiety measures) than patient with school refusal.
- Diagnosis: when CBT compared to attention control/treatment as usual, patients with social anxiety disorder were found to have more improvement on secondary anxiety measures than patients with panic disorder.
- Treatment settings: when CBT compared to attention control or treatment as usual, we found statistically significantly more improvement in secondary anxiety measures in school settings than mental health clinic.
- Length of follow-up: when CBT compared to waitlisting or no treatment, post intervention response rate was significantly higher than those reported at less than 6-month followup. Post intervention reduction of primary anxiety symptoms (child report) and remission rate were also significantly larger than those reported after more than 6 month followup.
- Exposure sessions in CBT: Compared with non-exposure CBT, exposure sessions statistically significant reduced primary anxiety symptoms (parent report only).
- Cognitive strategies in CBT: CBT with cognitive strategies were found to have statistically significant less improvement in primary anxiety symptoms (parent report) than CBT without cognitive strategies. No other significant differences were found on primary anxiety symptoms (clinician and child report), function, secondary measures, social function, or clinical response.
- Relaxation strategies in CBT: We found no statistically significant differences between CBT with relaxation and CBT without relaxation on primary anxiety symptoms (clinician, child, and parent report), function, secondary measures, social function, and clinical response.
- Individual-based CBT versus group-based CBT: we found that individual-based CBT had statistically significantly more improvement on function than group-based CBT.
- Treatment intensity: we found no statistically significant difference in any outcome based on treatment intensity.

### KQ 2 What are the comparative harms and safety concerns regarding the available treatments for childhood anxiety disorders, including panic disorder, social anxiety disorder, specific phobias, generalized anxiety disorder, and separation anxiety?

#### Key Points

- SSRIs and SNRIs were associated with increased risk of various short-term AEs that were overall not serious (low to moderate SOE).
- Studies were generally too small or too short to assess the effect of SSRIs on suicidal behavior. One study found that venlafaxine was associated with a statistically nonsignificant increase in the risk of suicidal ideation (low SOE).
- No differences or fewer dropout rates were found when CBT was compared to pill placebo, waitlisting, or active control therapies (low SOE).

#### Discussion

Twenty RCTs^7, 22, 49–51, 53–58, 60–62, 64–72, 74, 161^ compared medications to pill placebo, including atomoxetine, clonazepam, clomipramine, duloxetine, fluvoxamine fluoxetine, imipramine, sertraline, and venlafaxine, and reported AEs. Overall, 2,610 patients were included with a mean age of 11.6 years old and 53.4 percent male. 14 studies ^49–52, 56, 58, 60–65 49–52, 54, 56, 58, 60–65^ (70.0%) included patients without any comorbidity. 6 studies ^7, 22, 53–55, 57, 66, 67, 69–73^ included children with anxiety and comorbidity (ADHD, autism, ODD, OCD and other internalizing disorder). Details of the included studies can be found in Appendix Table E.1. We were unable to evaluate publication bias due to small number of studies (n<20) included in each comparisons.

Compared with pill placebo, SSRIs as a class was not significantly different on number of dropouts, dropouts due to any AEs, or any AEs. In terms of specific SSRIs, AEs that were associated with low to moderate SOE were any AEs (fluoxetine, paroxetine), AEs related to gastrointestinal symptoms (fluvoxamine), behavior change (paroxetine), cold/infection/allergies (paroxetine), and difficulties in sleeping (paroxetine). In terms of SNRIs, AEs that were associated with moderate SOE included atomoxetine (any AE and GI AEs) and venlafaxine (gastrointestinal AE and somnolence). These adverse effects were not serious (i.e., were not described as severe by the included trials, or did not lead to discontinuation of treatment or significant morbidity or mortality). Imipramine (class: TCA) was found to have higher risk of AEs related to oral symptoms (moderate SOE). Evidence on AE of benzodiazepines was sparse and of lower quality.

CBT was associated with fewer dropouts than pill placebo or sertraline (class: SSRI) (low SOE). Compared to sertraline, CBT was found to have lower risk of any AEs, AEs related to behavior change, and difficulties in sleeping.

Three studies reported suicide/suicidal ideation/self-harm.^7, 58, 67–72, 162^ The CAMS trial^7, 67–72^ compared CBT, sertraline, CBT plus sertraline, and pill placebo. The study found no suicide attempts in any group and no statistical difference between groups on suicide ideation. In a RCT of 293 children with generalized social anxiety disorder, March et al. ^58^ compared venlafaxine ER to pill placebo and found 3 cases of suicide ideation (3/140) in the venlafaxine group and no incidence in the pill placebo group (p=0.18). In an observational study ^162^, Renaud et al. found no suicide attempts or ideation among 12 children treated by SSRIs and benzodiazepines.

Eighteen single-cohort observational studies reported AEs related to different drugs. Those AEs included gastrointestinal symptoms, behavior change, difficulties in sleeping, headache, fatigue, and somnolence. No serious AEs were reported. The characteristics of these studies are summarized in Appendix Table E.21.

In summary, SOE supporting specific AE for specific drugs was low in general. However, as a class, SSRIs and SNRIs increased the risk of short-term AEs that were mostly not serious with the exception of increased suicidal ideation with venlafaxine. Studies were generally too small or too short to assess the effect of SSRIs on suicidal behavior, but one study found increased suicidal behavior with venlafaxine (low SOE). Results of the AEs are presented in Tables 11 and 12.

Table 11 Strength of evidence for adverse events of drugs versus pill placebo

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of Evidence^b^ | Overall Evidence Strength (Direction of Effect)
Benzodiazepine vs. Pill Placebo | Dropouts | RR: 6.22; 95% CI: 0.38 to 102.94; I^2^=N/A | 1 RCT (15 Patients)^57^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
SNRI vs. Pill Placebo | Dropouts | RR: 0.93; 95% CI: 0.70 to 1.25; I^2^=0.0% | 4 RCTs (786 Patients)^62^ ^55, 58^ ^64^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | Dropouts due to AEs | RR: 0.99; 95% CI: 0.39 to 2.47; I^2^=7.9% | 4 RCTs (786 Patients)^62^ ^55, 58, 64^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | Any AEs | Rate ratio: 1.55; 95% CI: 0.35 to 6.77; I^2^=94.8% | 3 RCTs (786 Patients)^55, 58, 62^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 2.15; 95% CI: 0.63 to 7.34; I^2^=78.8% | 3 RCTs (786 Patients)^55, 58, 62^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | AEs related to accidental injury | Rate ratio: 1.16, 95% CI: 0.58 to 2.29; I^2^=N/A | 21 RCTs (320 Patients)^62^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | AEs related to behavior change | Rate ratio: 1.48; 95% CI: 0.71 to 3.10; I^2^=0.0% | 2 RCTs (466 Patients)^55, 58^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | AEs related to cold/infection/allergies | Rate ratio: 1.05; 95% CI: 0.16 to 7.10; I^2^=83.6% | 3 RCTs (786 Patients)^55, 58, 62^ | Methodological limitations, imprecision (wide CIs), inconsistency | Insufficient
SNRI vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 2.14; 95% CI: 1.13 to 4.07; I^2^=N/A | 1 RCT (290 Patients)^58^ | Imprecision (small sample size) | Moderate (increased AEs)
SNRI vs. Pill Placebo | AEs related to headache/dizzy/vision problems | Rate ratio: 0.76; 95% CI: 0.52 to 1.11; I^2^=60.2% | 2 RCTs (496 Patients)^55, 62^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SNRI vs. Pill Placebo | AEs related to suicide/ideation/self-harm | Rate ratio: 4.29; 95% CI: 0.48 to 38.44; I^2^=N/A | 1 RCT (290 Patients)^58^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
SSRI vs. Pill Placebo | Dropouts | RR: 0.82; 95% CI: 0.59 to 1.13; I^2^=0.0% | 7 RCTs (856 Patients)^7, 22, 51, 53, 54, 61, 65, 67–72^ | Imprecision (wide CIs) | Moderate (no difference)
SSRI vs. Pill Placebo | Dropouts due to AEs | RR: 2.60; 95% CI: 0.64 to 10.65; I^2^=0.0% | 4 RCTs (733 Patients)^7, 22, 53, 65, 67–72^ | Severe imprecision (extremely wide CIs) | Low (no difference)
SSRI vs. Pill Placebo | Any AEs | Rate ratio: 1.28; 95% CI: 0.71 to 2.30; I^2^=79.1% | 8 RCTs (930 Patients)^7, 22, 49, 50, 53, 54, 60, 61, 65, 67–72^ | Imprecision (wide CIs), inconsistency | Low (no difference)
SSRI vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 1.40; 95% CI: 0.68 to 2.87; I^2^=54.8% | 6 RCTs (780 Patients)^7, 22, 49, 53, 61, 65, 67–72^ | Imprecision (wide CIs) | Moderate (no difference)
SSRI vs. Pill Placebo | AEs related to behavior change | Rate ratio: 1.66; 95% CI: 0.92 to 2.98; I^2^=48.2% | 7 RCTs (823 Patients)^7, 22, 49, 53, 60, 61, 65, 67–72^ | Imprecision (wide CIs) | Moderate (no difference)
SSRI vs. Pill Placebo | AEs related to cold/infection/allergies | Rate ratio: 1.09; 95% CI: 0.67 to 1.79; I^2^=36.0% | 4 RCTs (684 Patients)^7, 22, 49, 65, 67–72^ | Imprecision (wide CIs) | Moderate (no difference)
SSRI vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 1.24; 95% CI: 0.42 to 3.69; I^2^=80.5% | 5 RCTs (739 Patients)^7, 22, 49, 50, 65, 67–72^ | Imprecision (wide CIs), inconsistency | Low (no difference)
SSRI vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 1.61; 95% CI: 0.83 to 3.11; I^2^=0.0% | 4 RCTS (679 Patients)^7, 22, 61, 65, 67–72^ | Methodological limitations, imprecision (wide CIs) | Low (no difference)
SSRI vs. Pill Placebo | AEs related to headache/dizzy/vision problem | Rate ratio: 1.24; 95% CI: 0.57 to 2.67; I^2^=21.3% | 4 RCTS (384 Patients)^7, 22, 49, 61, 67–72^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
SSRI vs. Pill Placebo | AEs related to accidental injury | Rate ratio: 2.29; 95% CI: 0.26 to 20.45; I^2^=N/A | 1 RCT (209 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
SSRI vs. Pill Placebo | AEs related to suicide/ideation/self-harm | 0 case in each group | 1 RCT (209 Patients)^7, 67–72^ | No data | Insufficient
SSRI vs. Pill Placebo | AEs related to dry mouth/bad taste/oral symptoms | Rate ratio: 1.10; 95% CI: 0.34 to 3.58; I^2^=62.0% | 2 RCTs (47 Patients)^49, 61^ | Severe imprecision (wide CI, small sample size), inconsistency | Insufficient
TCA vs. Pill Placebo | Any AEs | Rate ratio: 1.39; 95% CI: 0.82 to 2.63; I^2^=86.6 % | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI), inconsistency | Insufficient
TCA vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 0.62; 95% CI: 0.21 to 1.86; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
TCA vs. Pill Placebo | AEs related to behavior change | Rate ratio: 5.45; 95% CI: 0.66 to 45.30; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
TCA vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 0.34; 95% CI: 0.07 to 1.63; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
TCA vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 2.73; 95% CI: 0.28 to 26.22; I^2^=N/A | 1 RCT (21 Patients)^74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
TCA vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 0.34; 95% CI: 0.07 to 1.63; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
TCA vs. Pill Placebo | AEs related to dry mouth/bad taste/oral symptoms | Rate ratio: 3.81; 95% CI: 1.25 to 11.62; I^2^= 0.0% | 2 RCTs (56 Patients )^56, 74^ | Imprecision (small sample size) | Moderate (increased AEs)
Atomoxetine (class: SNRI) vs. Pill Placebo | Dropouts | RR: 1.07, 95% CI: 0.64 to 1.79; I^2^=N/A | 1 RCT (176 Patients)^55^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Atomoxetine (class: SNRI) vs. Pill Placebo | Dropouts due to AEs | RR: 0.98, 95% CI: 0.06 to 15.38; I^2^=N/A | 1 RCT (176 Patients)^55^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Atomoxetine (class: SNRI) vs. Pill Placebo | Any AEs | Rate ratio: 1.74; 95% CI: 1.17 to 2.61; I^2^=N/A | 1 RCT (176 Patients)^55^ | Imprecision (small sample size) | Moderate (increased AEs)
Atomoxetine (class: SNRI) vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 2.48; 95% CI: 1.31 to 4.71; I^2^=N/A | 1 RCT (176 Patients)^55^ | Imprecision (small sample size) | Moderate (increased AEs)
Atomoxetine (class: SNRI) vs. Pill Placebo | AEs related to behavior change | Rate ratio: 1.63; 95% CI: 0.39 to 6.82; I^2^=N/A | 1 RCT (176 Patients)^55^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Atomoxetine (class: SNRI) vs. Pill Placebo | AEs related to Cold/Infection/Allergies | Rate Ratio: 1.19; 95% CI: 0.59 to 2.41; I^2^=N/A | 1 RCT (176 Patients)^55^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Atomoxetine (class: SNRI) vs. Pill Placebo | AEs related to headache/dizzy/vision | Rate ratio: 1.54; 95% CI: 0.60 to 3.96; I^2^=N/A | 1 RCT (176 Patients)^55^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Clomipramine (class: TCA) vs. Pill Placebo | Dropouts | RR: 3.60; 95% CI: 0.16 to 79.00; I^2^=N/A | 1 RCT (20 Patients)^54^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Clomipramine (class: TCA) vs. Pill Placebo | Any AEs | Rate ratio: 0.52; 95% CI: 0.14 to 2.03; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Clonazepam (class: Benzodiazepine) vs. Pill Placebo | Dropouts | RR: 6.22; 95% CI: 0.38 to 102.94; I^2^=N/A | 1 RCT (15 Patients)^57^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Duloxetine (class: SNRI) vs. Pill Placebo | Dropouts | RR: 1.02; 95% CI: 0.76 to 1.35; I^2^=N/A | 1 RCT (272 Patients)^64^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Duloxetine (class: SNRI) vs. Pill Placebo | Dropouts due to AEs | RR: 1.17; 95% CI: 0.58 to 2.37; I^2^=N/A | 1 RCT (272 Patients)^64^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluoxetine (class: SSRI) vs. Pill Placebo | Dropouts | RR: 1.39; 95% CI: 0.38 to 5.09; I^2^=0.0 | 3 RCTs (175 Patients)^51, 53, 54^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
Fluoxetine (class: SSRI) vs. Pill Placebo | Dropouts due to AEs | RR: 3.00; 95% CI: 0.13 to 71.34; I^2^=N/A | 1 RCT (74 Patients)^53^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
Fluoxetine (class: SSRI) vs. Pill Placebo | Any AEs | Rate ratio: 2.77; 95% CI: 1.71 to 4.47; I^2^=0.0% | 2 RCTs (95 Patients)^53, 54^ | Methodological limitations, imprecision (small sample size) | Low (increased AEs)
Fluoxetine (class: SSRI) vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 2.29; 95% CI: 0.94 to 5.56; I^2^=N/A | 1 RCT (74 Patients)^53^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
Fluoxetine (class: SSRI) vs. Pill Placebo | AEs related to behavior Change | Rate ratio: 1.75; 95% CI: 0.51 to 5.98; I^2^=N/A | 1 RCT (74 Patients)^53^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
Fluvoxamine (class: SSRI) vs. Pill Placebo | Dropouts | RR: 0.74; 95% CI: 0.35 to 1.54; I^2^=N/A | 1 RCT (128 Patients)^22^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluvoxamine (class: SSRI) vs. Pill Placebo | Dropouts due to AEs | RR: 5.16; 95% CI: 0.62 to 42.93; I^2^=N/A | 1 RCT (128 Patients)^22^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluvoxamine (class: SSRI) vs. Pill Placebo | Any AEs | Rate ratio: 1.18; 95% CI: 0.15 to 9.45; I^2^=83.5 % | 4 RCTs (303 Patients)^22, 49, 50, 60^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluvoxamine (class: SSRI) vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 1.58; 95% CI: 1.13 to 2.20; I^2^=0.0% | 2 RCTs (153 Patients)^22, 49^ | Imprecision (small sample size) | Moderate (increased AEs)
Fluvoxamine (class: SSRI) vs. Pill Placebo | AEs related to behavior change | Rate ratio: 2.12; 95% CI: 0.08 to 54.36; I^2^=79.0 % | 3 RCTs (198 Patients)^22, 49, 60^ | Severe imprecision (small sample size and wide CI), inconsistency | Insufficient
Fluvoxamine (class: SSRI) vs. Pill Placebo | AEs related to cold/infection/allergies | Rate ratio: 1.05; 95% CI: 0.75 to 1.47; I^2^= 53.1% | 2 RCTs (153 Patients)^22, 49^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluvoxamine (class: SSRI) vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 0.76; 95% CI: 0.14 to 3.86; I^2^=55.2% | 3 RCTs (258 Patients)^22, 49, 50^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluvoxamine (class: SSRI) vs. Pill Placebo | AEs related to headache/dizzy/vision | Rate ratio: 1.22; 95% CI: 0.74 to 2.00; I^2^= 0.0% | 2 RCTs (153 Patients)^22, 49^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluvoxamine (class: SSRI) vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 1.65; 95% CI: 0.87 to 3.15; I^2^=N/A | 1 RCT (128 Patients) ^22^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluvoxamine (class: SSRI) vs. Pill Placebo | AEs related to dry mouth/bad taste/oral symptoms | Rate ratio: 0.22; 95% CI: 0.02 to 2.13; I^2^=N/A | 1 RCT (25 Patients)^49^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Imipramine (class: TCA) vs. Pill Placebo | Any AEs | Rate ratio: 1.40; 95% CI: 0.82 to 2.63; I^2^=86.6 % | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI), inconsistency | Insufficient
Imipramine (class: TCA) vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 0.62; 95% CI: 0.21 to 1.86; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Imipramine (class: TCA) vs. Pill Placebo | AEs related to behavior change | Rate ratio: 5.45; 95% CI: 0.66 to 45.30; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Imipramine (class: TCA) vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 0.34; 95% CI: 0.07 to1.63; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Imipramine (class: TCA) vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 2.73; 95% CI: 0.28 to 26.22; I^2^=N/A | 1 RCT (21 Patients)^74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Imipramine (class: TCA) vs. Pill Placebo | AEs related to difficulties sleeping | Rate Ratio: 0.34; 95% CI: 0.07 to 1.63; I^2^=0.0% | 2 RCTs (56 Patients)^56, 74^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Imipramine (class: TCA) vs. Pill Placebo | AEs related to dry mouth/bad taste/oral symptoms | Rate Ratio: 3.81; 95% CI: 1.25 to 11.62; I^2^= 0.0% | 2 RCTs (56 Patients)^56, 74^ | Imprecision (small number of patients) | Moderate (increased AEs)
Paroxetine (class: SSRI) vs. Pill Placebo | Dropouts | RR: 0.71; 95% CI: 0.50 to 1.02; I^2^=N/A | 1 RCT (322 Patients)^65^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Paroxetine (class: SSRI) vs. Pill Placebo | Dropouts due to AEs | RR: 4.28; 95% CI: 0.94 to 19.51; I^2^=N/A | 1 RCT (322 Patients)^65^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Paroxetine (class: SSRI) vs. Pill Placebo | Any AEs | Rate ratio: 1.85; 95% CI: 1.45 to 2.35; I^2^=N/A | 1 RCT (210 Patients)^65^ | Imprecision (small sample size) | Moderate (increased AEs)
Paroxetine (class: SSRI) vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 3.49; 95% CI: 0.97 to 12.51; I^2^=N/A | 1 RCT (322 Patients)^65^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Paroxetine (class: SSRI) vs. Pill Placebo | AEs related to behavior change | Rate ratio: 2.16; 95% CI: 1.06 to 4.40; I^2^=N/A | 1 RCT (322 Patients)^65^ | Severe imprecision (small sample size and wide CI) | Low (increased AEs)
Paroxetine (class: SSRI) vs. Pill Placebo | AEs related to cold/infection/allergies | Rate ratio: 2.00; 95% CI: 1.39 to 2.89; I^2^=N/A | 1 RCT (274 Patients)^65^ | Imprecision (small sample size) | Moderate (increased AEs)
Paroxetine (class: SSRI) vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 6.17; 95% CI: 3.58 to 10.63; I^2^=N/A | 1 RCT (157 Patients)^65^ | Imprecision (small sample size) | Moderate (increased AEs)
Paroxetine (class: SSRI) vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 1.52; 95% CI: 0.76 to 3.03; I^2^=N/A | 1 RCT (320 Patients)^65^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | Dropouts | RR: 0.73; 95% CI: 0.38 to 1.42; I^2^=0.0% | 2 RCTs (231 Patients) ^7, 61, 67–72^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
Sertraline (class: SSRI) vs. Pill Placebo | Dropouts due to AEs | RR: 1.33; 95% CI: 0.36 to 5.00; I^2^=N/A | 1 RCT (209 Patients) ^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | Any AEs | Rate ratio: 1.2 95% CI: 0.94 to 1.55; I^2^=50.1% | 2 RCTs (231 Patients)^7, 61, 67–72^ | Methodological limitations, severe imprecision (small sample size and wide CIs) | Insufficient
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 0.88; 95% CI: 0.50 to 1.53; I^2^=78.6% | 2 RCTs (231 Patients)^7, 61, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to behavior change | Rate ratio: 1.57; 95% CI: 0.88 to 2.81; I^2^=0.00% | 2 RCTs (231 Patients)^7, 61, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to cold/infection/allergies | Rate ratio: 0.86; 95% CI: 0.49 to 1.51; I^2^=N/A | 1 RCT (209 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 1.94; 95% CI: 0.72 to 5.27; I^2^=N/A | 1 RCT (209 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 1.68; 95% CI: 0.76 to 3.74; I^2^=0.0% | 2 RCTs (231 Patients)^7, 61, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to headache/dizzy/vision | Rate ratio: 1.29; 95% CI: 0.59 to 2.85; I^2^=72.6% | 2 RCTs (231 Patients)^7, 61, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to accidental injury | Rate ratio: 2.29; 95% CI: 0.26 to 20.45; I^2^=N/A | 1 RCT (209 patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to suicide/ideation/self-harm | 0 case in each group | 1 RCT (209 patients)^7, 67–72^ | No data | Insufficient
Sertraline (class: SSRI) vs. Pill Placebo | AEs related to dry mouth/bad taste/oral symptoms | Rate ratio: 2.0; 95% CI: 0.50 to 8.00; I^2^=N/A | 1 RCT (22 patients)^61^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | Dropouts | RR: 0.84; 95% CI: 0.65 to 1.09; I^2^=0.0% | 2 RCTs (610 Patients)^62,58^ | Imprecision (wide CIs) | Moderate (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | Dropouts due to AEs | RR: 0.78; 95% CI: 0.36 to 1.66; I^2^=64.9% | 2 RCTs (610 Patients)^58, 62^ | Imprecision (wide CIs), inconsistency | Low (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | Any AEs | Rate ratio: 1.13; 95% CI: 0.98 to 1.31; I^2^=97.5% | 2 RCTs (610 Patients)^58, 62^ | Imprecision (wide CIs), inconsistency | Low (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 1.92; 95% CI: 1.44 to 2.57; I^2^=88.8% | 2 RCTs (610 Patients)^58, 62^ | Inconsistency | Moderate (increased AEs)
Venlafaxine (class: SNRI) vs. Pill Placebo | AEs related to behavior change | Rate ratio: 1.43; 95% CI: 0.60 to 3.39; I^2^=N/A | 1 RCT (290 Patients)^58^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | AEs related to cold/Infection/allergies | Rate ratio: 0.87; 95% CI: 0.57 to 1.32; I^2^= 91.4% | 2 RCTs (610 Patients)^58, 62^ | Severe imprecision (small sample size and wide CI), inconsistency | Insufficient
Venlafaxine (class: SNRI) vs. Pill Placebo | AEs related to fatigue/somnolence | Rate ratio: 2.14; 95% CI: 1.13 to 4.07; I^2^=N/A | 1 RCT (290 Patients)^58^ | Imprecision (small sample size) | Moderate (increased AEs)
Venlafaxine (class: SNRI) vs. Pill Placebo | AEs related to headache/dizzy/vision | Rate ratio: 0.67; 95% CI: 0.44 to 1.01; I^2^=N/A | 1 RCT (320 Patients)^62^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | AEs related to suicide/ideation/self-harm | Rate ratio: 4.29; 95% CI: 0.48 to 38.34; I^2^=N/A | 1 RCT (290 Patients)^58^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Venlafaxine (class: SNRI) vs. Pill Placebo | AEs related to accidental injury | Rate ratio: 1.16; 95% CI: 0.58 to 2.29; I^2^=N/A | 1 RCT (320 Patients)^62^ | Severe imprecision (small sample size and wide CI) | Low (no difference)

AE: adverse event, CI: confidence interval, GI: gastrointestinal, N/A: not applicable, RCT: randomized controlled trial, RR: relative risk, SNRI: serotonin–norepinephrine reuptake inhibitor, SMD: standardized mean difference, SSRI: selective serotonin reuptake inhibitor, TCA: tricyclic antidepressants

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.

Table 12 Strength of evidence for adverse events reported in other comparisons, including combination treatments

Comparison | Outcome | Conclusion | Study Design and Sample Size^a^ | Factors That Affect the Strength of Evidence^b^ | Overall Evidence Strength (Direction of Effect)
TCA vs. SSRI | Dropouts | RR: 0.56; 95% CI: 0.06 to 5.14; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
TCA vs. SSRI | Any AEs | Rate ratio: 6.90; 95% CI: 2.10 to 22.98; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (small sample size and wide CI) | Low (increased AEs)
Clomipramine (class: TCA) vs. Fluoxetine (class: SSRI) | Dropouts | RR: 0.56; 95% CI: 0.06 to 5.14; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Clomipramine (class: TCA) vs. Fluoxetine (class: SSRI) | Any AEs | Rate ratio: 6.90; 95% CI: 2.10 to 22.98; I^2^=N/A | 1 RCT (19 Patients)^54^ | Severe imprecision (small sample size and wide CI) | Low (increased AEs)
Sertraline (class: SSRI) vs Paroxetine (class: SSRI) | Any AEs | Rate ratio: 5.00; 95% CI 0.31 to 79.94; I^2^=N/A | 1 RCT (19 patients)^54^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Fluoxetine (class: SSRI) vs. CBT | Dropouts | RR: 1.26; 95% CI: 0.61 to 2.58; I^2^=N/A | 1 RCT (102 Patients)^51^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs CBT | Dropouts | RR: 2.79; 95% CI: 1.12 to 6.91; I^2^=N/A | 1 RCT (272 Patients)^7, 67–72^ | Methodological limitations, imprecision (small sample size) | Low (increased dropouts)
Sertraline (class: SSRI) vs CBT | Dropouts due to AEs | RR: 15.67; 95% CI: 0.90 to 271.71; I^2^=N/A | 1 RCT (272 Patients)^7, 67–72^ | Methodological limitations, severe imprecision (small sample size and wide CI) | Insufficient
Sertraline (class: SSRI) vs CBT | Any AEs | Rate ratio: 1.39; 95% CI: 1.09 to 1.77; I^2^=N/A | 1 RCT (272 Patients)^7, 67–72^ | Methodological limitations, imprecision (small sample size) | Low (increased AEs)
Sertraline (class: SSRI) vs CBT | AEs related to abdominal/GI/appetite | Rate ratio: 0.71; 95% CI: 0.41 to 1.20; I^2^=0.0% | 2 RCT (274 Patients)^7, 67–72, 161^ | Methodological limitations, severe imprecision (small sample size and wide CI) | Insufficient
Sertraline (class: SSRI) vs CBT | AEs related to behavior change | Rate ratio: 2.09; 95% CI: 1.17 to 3.74; I^2^=0.0% | 2 RCT (321 Patients)^7, 66–72^ | Methodological limitations, imprecision (small sample size) | Low (increased AEs)
Sertraline (class: SSRI) vs CBT | AEs related to cold/infection/allergies | Rate ratio: 0.64; 95% CI: 0.41 to 1.01; I^2^=N/A | 1 RCT (272 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs CBT | AEs related to difficulties sleeping | Rate ratio: 4.44; 95% CI: 1.50 to 13.20; I^2^=N/A | 1 RCT (272 Patients)^7, 67–72^ | Imprecision (small sample size) | Moderate (increased AEs)
Sertraline (class: SSRI) vs CBT | AEs related to headache/dizzy/vision | Rate ratio: 1.83; 95% CI: 0.90 to 3.72; I^2^=N/A | 1 RCT (272 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs CBT | AEs related to accidental injury | Rate ratio: 1.05; 95% CI: 0.26 to 4.18; I^2^=N/A | 1 RCT (272 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
Sertraline (class: SSRI) vs CBT | AEs related to suicide/ideation/self-harm | 0 events | 1 RCT (272 Patients)^7, 67–72^ | No data | Insufficient
CBT vs. Pill Placebo | Dropouts | RR: 0.53; 95% CI: 0.30 to 0.95; I^2^=74.4 % | 2 RCTs (311 Patients)^7, 51, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (reduced dropouts)
CBT vs. Pill Placebo | Dropouts due to AEs | RR: 0.08; 95% CI: 0.00 to 1.50; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | Any AEs | Rate ratio: 0.97; 95% CI: 0.71 to 1.30; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | AEs related to abdominal/GI/appetite | Rate ratio: 0.84; 95% CI: 0.44 to 1.61; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | AEs related to behavior change | Rate ratio: 0.72; 95% CI: 0.35 to 1.47; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | AEs related to cold/infection/allergies | Rate ratio: 1.34; 95% CI: 0.80 to 2.25; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | AEs related to difficulties sleeping | Rate ratio: 0.44; 95% CI: 0.12 to 1.63; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | AEs related to headache/dizzy/vision | Rate ratio: 1.09; 95% CI: 0.41 to 2.92; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | AEs related to suicide/ideation/self-harm | Rate ratio: 2.73; 95% CI: 0.32 to 23.40; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Pill Placebo | AEs related to accidental injury | Rate ratio: 2.19; 95% CI: 0.24 to 19.57; I^2^=N/A | 1 RCT (215 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT vs. Waitlisting or No Treatment | Dropouts | RR: 1.19; 95% CI: 0.81 to 1.73; I^2^=14.52 % | 29 RCTs (1345 Patients)^84, 105–108, 110, 111, 114–116, 120–122, 126, 127, 129, 136–138, 140–144, 146, 149, 152, 153^ | Methodological limitations, imprecision (wide CI) | Low (no difference)
CBT vs. Waitlisting or No Treatment | Dropouts due to AEs | RR: 0.31; 95% CI: 0.12 to 0.79; I^2^=NA | 1 RCT (125 Patients) ^119^ | Methodological limitations, imprecision (small sample size) | Low (reduced dropouts)
CBT vs. Attention Control or Treatment As Usual | Dropouts | RR: 0.87; 95% CI: 0.65 to 1.16 I^2^=0.0% | 16 RCTs and 1 non-randomized comparative study (1053 Patients)^76, 78–80, 82–84, 86, 88, 90, 92, 94–97, 100, 102^ | Methodological limitations, imprecision (wide CI) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. CBT | Dropouts | RR: 1.99; 95% CI: 0.77 to 5.14; I^2^=N/A | 1 RCT and 1 non-randomized comparative study (327 patients)^7, 67–72, 163^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. CBT | Dropouts due to AEs | RR: 2.98; 95% CI: 0.12 to 72.50; I^2^=N/A | 1 RCT (279 patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. CBT | Any AEs | Rate ratio:1.67; 95% CI: 1.32 to 2.07 I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (increased AEs)
CBT+ Sertraline (class: SSRI) vs. CBT | AEs related to abdominal/GI/appetite | Rate ratio: 1.42; 95% CI: 0.84 to 2.42; I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. CBT | AEs related to behavior change | Rate ratio: 3.80; 95% CI: 2.23 to 6.48; I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Imprecision (small sample size) | Moderate (increased AEs)
CBT+ Sertraline (class: SSRI) vs. CBT | AEs related to cold/infection/allergies | Rate ratio: 0.95; 95% CI: 0.64 to 1.42; I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. CBT | AEs related to difficulties sleeping | Rate ratio: 3.23; 95% CI: 1.05 to 9.90; I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (increased AEs)
CBT+ Sertraline (class: SSRI) vs. CBT | AEs related to headache/dizzy/vision | Rate ratio: 1.49; 95% CI: 0.72 to 3.09; I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. CBT | AEs related to suicide/ideation/self-harm | Rate ratio: 0.99; 95% CI: 0.29 to 3.43; I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. CBT | AEs related to accidental injury | Rate ratio: 1.00; 95% CI: 0.25 to 3.80; I^2^=N/A | 1 RCT (279 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | Dropouts | RR: 0.71; 95% CI: 0.35 to 1.45; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | Dropouts due to AEs | RR: 0.14; 95% CI: 0.02 to 1.09; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | Any AEs | Rate ratio: 1.2; 95% CI: 0.97 to 1.45; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to abdominal/GI/appetite | Rate ratio: 1.01; 95% CI: 0.62 to 1.65; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to behavior change | Rate ratio: 1.82; 95% CI: 1.20 to 2.75; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Imprecision (small sample size) | Moderate (increased AEs)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to cold/infection/allergies | Rate ratio: 1.49; 95% CI: 0.94 to 2.35; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to difficulties Sleeping | Rate ratio: 0.73; 95% CI: 0.35 to 1.50; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CIs) | Low (no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to fatigue/somnolence | Rate ratio: 0.20; 95% CI: 0.06 to 0.71; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Imprecision (small sample size) | Moderate (reduced AEs)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to headache/dizzy/vision | Rate ratio: 0.81; 95% CI: 0.43 to 1.53; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low(no difference)
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to suicide/ideation/self-harm | 0 case in each group | 1 RCT (273 Patients)^7, 67–72^ | No data | Insufficient
CBT+ Sertraline (class: SSRI) vs. Sertraline (class: SSRI) | AEs related to accidental injury | Rate ratio: 0.95; 95% CI: 0.24 to 3.80; I^2^=N/A | 1 RCT (273 Patients)^7, 67–72^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT+ Imipramine (class: TCA) vs. CBT | Dropouts | RR: 0.80; 95% CI: 0.34 to 1.89; I^2^=N/A | 1 RCT (63 Patients)^159^ | Severe imprecision (small sample size and wide CI) | Low (no difference)
CBT+ Fluoxetine (class: SSRI) vs. CBT | Dropouts | RR: 1.54; 95% CI: 0.60 to 3.88; I^2^=N/A | 1 RCT(41 Patients)^160^ | Severe imprecision (small sample size and wide CI) | Low (no difference)

AE: adverse event, CBT: cognitive behavioral therapy, CI: confidence interval, GI: Gastrointestinal, N/A: not applicable, RCT: randomized controlled trial, RR: relative risk, SNRI: serotonin–norepinephrine reuptake inhibitor, SMD: standardized mean difference, SSRI: selective serotonin reuptake inhibitor, TCA: tricyclic antidepressants

a The sample size includes the number of patients from each comparison.

b Only SOE domains that led to rating down SOE are reported in this column. Domains that are not reported were satisfactory.