# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Jennie M. Kuckertz, M.S.
  SDSU/UC San Diego Joint Doctoral Program in Clinical Psychology
  San Diego, CA
- Eli Lebowitz, Ph.D.
  Yale School of Medicine
  New Haven, CT
- David Rettew, M.D.
  University of Vermont Larner College of Medicine
  Burlington, VT
- Karen T. G. Schwartz, M.S.
  SDSU/UC San Diego Joint Doctoral Program in Clinical Psychology
  San Diego, CA
- John T. Walkup, M.D.
  Weill Cornell Medicine and New York-Presbyterian
  New York, NY
- V. Robin Weersing, Ph.D.
  SDSU/UC San Diego Joint Doctoral Program in Clinical Psychology
  San Diego, CA