# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Jonathan Comer, Ph.D.
  Florida International University
  Miami, FL
- Stephanie C. Eken, M.D., FAAP
  Rogers Behavioral Health
  Tampa, FL
- Abbe Garcia, Ph.D.^*^
  The Warren Alpert Medical School of Brown University
  East Providence, RI
- Amie E. Grills, Ph.D.^*^
  Boston University
  Boston, MA
- Jill Ehrenreich May, Ph.D.
  University of Miami
  Coral Gables, FL
- Moira A. Rynn, M.D.^*^
  Chair of Department of Psychiatry & Behavioral Sciences
  Duke University Medical Center
  Durham, NC

* Provided input on Draft Report.